# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-32, Atlanta, Georgia 30333.

## Refractory Ceramic Fibers Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Refractory Ceramic Fibers
CAS Number: | None
Date: | July 13, 2004
Profile Status: | Final Post Public Comment
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [ ] Intermediate [ X ] Chronic
Graph Key: | 78
Species: | Fischer 344 Rats

[underlined: Minimal Risk Level]: 0.03 [ ] mg/kg/day [ ] ppm [X] WHO fiber/cc

[underlined: References]:

Mast RW, McConnell EE, Anderson R, . 1995a. Studies on the chronic toxicity (inhalation) of four types of refractory ceramic fiber in male Fischer 344 rats. Inhal Toxicol 7:425–467.21539476

Mast RW, McConnell EE, Hesterberg TW, . 1995b. Multiple dose chronic inhalation toxicity study of size-separated kaolin refractory ceramic fiber in male Fischer 344 rats. Inhal Toxicol 7(4):469–502.21539475

Bernstein DW, Sintes JMR, Ersboell BK, . 2001b. Biopersistence of synthetic mineral fibers as a predictor of chronic inhalation toxicity in rats. Inhal Toxicol 13:823–849.11696863

Maxim LD, Yu CP, Oberdörster G, . 2003. Quantitative risk analyses for RCF: survey and synthesis. Regul Toxicol Pharmacol 38:400–416.14623489

[underlined: Experimental design and effects noted]:

In the multiple-exposure level study (Mast et al. 1995b), four groups of about 140 male F344 rats were exposed via nose-only inhalation to 0 (filtered air controls), 3, 9, or 16 mg/m^3^ of a refractory ceramic fiber called RCF1, 6 hours/day, 5 days/week for up to 24 months. The companion study (Mast et al. 1995a) exposed two groups of about 140 male F344 rats to 0 or 30 mg/m^3^ RCF1 (from the same lot as the multiple-exposure level study) via the same protocol.

The RCF1 test material was prepared from a bulk sample of kaolin-based refractory ceramic fiber obtained from Carborundum Company, Niagara Falls, New York. The bulk material was separated (before aerosol generation) to concentrate the numbers of fibers with a targeted nominal arithmetic mean diameter of 1 µm and length of 20–30 µm. These dimensions were chosen based on results of an unpublished simulated workplace exposure study showing airborne fibers to be principally of this size range. The generated aerosols had the characteristics listed in Table A-1. In addition to fibers (i.e., particles with length:diameter ≥3:1), the aerosols contained nonfibrous particles, often referred to as “shot”. In the experimental aerosols, the ratios of nonfibrous particles (with diameters <3 µm) to total fibers or to WHO fibers were reported by Mast et al. (1995b) to range from 0.9 to 1.5 or from 1.3 to 1.96, respectively (Table A-1).

Table A-1 RCF1 Aerosol Characteristics in the 2-Year Inhalation Bioassays with F344 Rats (Mast et al. 1995a, 1995b)

Character (mean [± standard deviation]) | 3 mg/m^3^ | 9 mg/m^3^ | 16 mg/m^3^ | 30 mg/m^3^
Gravimetric concentration (mg/m^3^) | 3.0±0.4 | 8.8 ±0.7 | 16.5±1.1 | 29.1±5.2
Total fibers/cc (L:D≥3) | 36±17 | 91±34 | 162±37 | 234±35
WHO fibers/cc (L>5 µm; D<3 µm; L:D≥3) | 26±12 | 75±35 | 120±35 | 187±53
Diameter (D) range (µm) | 0.08–5.32 | 0.08–5.37 | 0.07–4.83 | 0.12–4.53
Length (L) range (µm) | 0.77–93.93 | 1.09–98.25 | 1.24–97.88 | 1.30–76.6
Arithmetic mean D (µm) | 1.02±0.73 | 1.02±0.71 | 1.02±1.70 | 0.98±0.61
Geometric mean D (µm) | 0.80±2.06 | 0.80±2.03 | 0.82±1.99 | 0.82±1.89
Arithmetic mean L (µm) | 20.2±18.10 | 20.3±17.1 | 19.6±16.5 | 22.3±17.0
Geometric mean L (µm) | 13.5±2.60 | 13.9±2.50 | 13.8±2.4 | 15.9±2.4
Nonfibrous particle counts
≤1 µm/cc | 28.3±19.3 | 85.7± 63.2 | 88.0±52.4 | 17±154
1–3 µm/cc | 23.0±11.8 | 54.8±38.4 | 68.4±24.2 | 135±45
3 µm/cc | 17.1±8.4 | 43.6±25.2 | 58.6±27.1 | 81±29
Ratio nonfibrous particles (<3 µm):total fibers | 1.41 | 1.54 | 0.97 | 1.31
Ratio nonfibrous particles (<3 µm):WHO fibers | 1.96 | 1.87 | 1.30 | 1.63

Groups of 3–6 rats from each exposure group were killed at 3, 6, 12, 18, and 24 months of exposure. Additional groups of 3–6 rats were removed from exposure at 3, 6, 12, and 18 months and exposed to filtered air until they were sacrificed at 24 months. Remaining rats exposed for 24 months (15–32 rats per group) were held without further exposure until 30 months when survivors were killed. All rats were necropsied. Lung tissues were removed, and weighed, and the left lung was prepared for routine histopathology that included staining for collagen deposition. Other tissues processed for histopathology included the nasal cavity, larynx, trachea, bronchi, mediastinal and mesenteric lymph nodes, liver, spleen, kidneys, heart, and all tissues with grossly visible lesions. The concentration and size distributions of fibers in lung tissue were determined after ashing of accessory lung lobes. All fibers detected in lungs had diameters <3 µm. Concentrations were expressed as total fibers per mg dry lung (length:diameter >3) or WHO fibers per mg dry lung (length >5 µm, diameter <3 µm, and length:diameter ≥3).

Observed nonneoplastic lung lesions were classified with two different grading scales. One scale (the Wagner scale) contained eight grades ranging from a normal grade of 1 (with no lesions observed), through “cellular change” grades 2 and 3 (few to conspicuous macrophages in terminal bronchioles and alveoli and no collagen deposition at the bronchiolo-alveolar junction), to five “fibrosis” grades. The fibrosis grades increased in severity as follows: grade 4 (minimal), minimal collagen deposition at the bronchoalveolar junction, increased bronchiolization, and associated mucoid debris; grade 5 (mild), interlobular linking of collagen deposition; grade 6 (moderate), early consolidation and decrease in parenchyma tissue; grade 7 (severe), marked fibrosis and consolidation; and grade 8, complete obstruction of most airways. The other scale contained five grades (0=normal; 1=minimal; 2=mild; 3=moderate; 4=marked; 5=severe) and was applied to specific histopathological findings (macrophage aggregation, bronchiolization, granuloma presence, interstitial [i.e., pulmonary] fibrosis, and pleural fibrosis).

Survival was not statistically significantly affected in any of the exposed groups compared with controls. Body weights and body weight gains were not affected in the two lowest exposure groups (3 and 9 mg/m^3^). At sporadic intervals of exposure, rats exposed to 16 or 30 mg/m^3^ displayed statistically significant decreases in body weight, compared with controls. The decreases were not >10% of control values, and are not considered an adverse effect. In 16- and 30-mg/m^3^ rats, absolute and relative lung weights were significantly greater than in control rats, as early as after 3 months of exposure. After 24 months of exposure, mean absolute lung weights in these groups were respectively increased by 32 and 65%, compared with controls. The lung weight changes are considered to be an indicator of pulmonary inflammation from repeated exposure to RCF1.

Lung fiber concentrations increased with increasing exposure duration and concentration. At 24 months, mean values of WHO fibers/mg lung were 4.29x10^4^, 15.60x10^4^, 22.10x10^4^, and 27.50x10^4^ for the 3-, 9-, 16-, and 30-mg/m^3^ groups, respectively. Mean values for total fibers/mg lung were 5.55±1.71, 18.80±3.59, 27.80±6.06, and 37.00±8.01, respectively.

Exposure-related nonneoplastic histopathological lesions were restricted to the lung or pleura. Signs of pulmonary inflammation (macrophage aggregation, bronchiolization, and granuloma presence) were observed in all exposed groups after 3 months of exposure, whereas these lesions did not occur in the control rats at any interval (see Table A-2). At 24 months, mean scores (on the five-grade scale) in the 3- and 30-mg/m^3^ groups ranged from 2 to 3.2 for macrophage aggregation, from 1.2 to 2.7 for bronchiolization, and from 1.5 to 2 for granuloma presence (Table A-2). The mean scores reflect progression of the severity of the inflammatory lesions with increasing exposure concentration (Table A-2). There is also some evidence of progression of the severity of the inflammatory lesions with increasing duration of exposure, most notably between 3 and 12 months (Table A-2).

Signs of interstitial (i.e., pulmonary) fibrosis and pleural fibrosis appeared in rats exposed to concentrations ≥9 mg/m^3^ (Table A-2). The five-grade scores for interstitial fibrosis and pleural fibrosis (see note about these scores below) showed some progression in severity with exposure duration and concentrations, but the average severity scores for the exposed groups did not progress beyond a score of 3 (moderate) for pulmonary fibrosis or a score of 2 (mild) for pleural fibrosis (Table A-2). Signs of fibrosis did not appear until 12 months of exposure. Using the eight-grade Wagner scale to classify the pulmonary cellular changes and fibrosis, the mean scores at 24 months were 1.0 (normal), 3.2, 4.0, 4.2, and 4.0 for the control, 3-, 9-, 16-, and 30-mg/m^3^ groups, respectively. In rats exposed for 24 months and allowed to live without exposure to 30 months, respective mean scores were 1.0, 2.9, 3.8, 4.0, and 4.3 (Table A-2). These scores indicate that the pulmonary lesions produced by 24 months of exposure showed only minor, if any, regression and that, on average, the most severe nonneoplastic lesions formed were classified as minimal to mild fibrosis. It was reported that the principal difference between 24-month exposed rats killed at 24 and 30 months was a reduction in the number of pulmonary macrophages and granulomas in the 30-month rats; pulmonary or pleural fibrosis showed no signs of regression.

In a later published report, Bernstein et al. (2001b) reported that the pathologist, who originally scored the histological slides from the RCF1 2-year bioassay, had provided scores for collagen deposition at the bronchoalveolar junction. This lesion was scored in each rat on a five-scale system as follows:

- 0=normal;
- 1=minimal–very few (1 or 2 foci) and very small foci of collagen deposition of insufficient severity to score as Grade 4 in the eight-grade Wagner scale;
- 2=mild–slight, but easily detected, few, small foci of collagen deposition, minimally sufficient to classify in Grade 4 of the Wagner scale;
- 3=moderate–easily detected foci of collagen deposition in considerably enlarged areas, corresponding to Grade 4 of the Wagner scale;
- 4=marked–marked, obvious, or extensive foci of collagen deposition extending into the interstitium, and corresponding to Grade 4 of the Wagner scale;
- 5=severe–widespread collagen deposition with consolidation at the bronchoalveolar junction, sometimes with interlobular linking, corresponding to Grade 4 to 5 of the Wagner scale.

In accordance with this scale, collagen deposition at the bronchoalveolar junction is taken as an early response at the site where fibrosis can develop. The lesion is not classified as pulmonary fibrosis at a minimal score of 1, but is classified as minimal to mild fibrosis at scores of 2–5. The mean scores (±standard deviations) for the collagen deposition scores reported by Bernstein et al. (2001b) for the six rats in each of the groups sacrificed at 24 months were: control (n=12), 0 (normal); 3 mg/m^3^, 0.67±0.8; 9 mg/m^3^, 2.0±0; 16 mg/m^3^, 2.83±0.4; and 30 mg/m^3^, 2.17±0.4. These mean scores for collagen deposition are identical to the mean scores for the lesion named “pulmonary fibrosis” in the Mast et al. (1995a, 1995b) report and shown in Table A-2. Thus, the scores for “pulmonary fibrosis” shown in Table A-2 are actually for collagen deposition as per the original pathology reports.

Neoplastic lesions (lung adenomas, lung carcinomas, and mesotheliomas) were found most prominently in rats exposed to 30 mg/m^3^. The tumors appeared predominately late in life. The first adenoma occurred in rats sacrificed at 18 months; carcinomas and mesotheliomas were detected only in the 30-month-sacrifice animals. Incidences for rats (that survived to 12 months) with bronchoalveolar hyperplasia were 8/129, 10/123, 16/127, 13/124, and 17/123 for the control through high-exposure groups. Combined incidences for lung adenomas or carcinoma were 1/129, 2/123, 5/127, 2/124, and 16/123. Incidences for mesothelioma were 0/129, 0/123, 1/127, 0/124, and 2/123. Incidences for mesothelial proliferation were 1/129, 0/123, 1/127, 1/124, and 9/123.

Table A-2 Mean Severity Scores for Pulmonary Lesions in F344 Rats Exposed to RCF1 (Mast et al. 1995a, 1995b)^a^

Exposure level/sacrifice month | Number of rats | Macrophage Aggregation (0–5 scale) | Bronchiolization (0–5 scale) | Granuloma (0–5 scale) | Pulmonary fibrosis (0– 5 scale) | Pleural fibrosis (0– 5 scale)^c^ | 8-Grade Wagner scale score
Control
3 | 3 | 0 | 0 | 0 | 0 | 0 | 1.0
6 | 3 | 0 | 0 | 0 | 0 | 0 | 1.0
12 | 6 | 0 | 0 | 0 | 0 | 0.3 | 1.0
18 | 6 | 0 | 0 | 0 | 0 | 0 | 1.0
24 | 6 | 0 | 0 | 0 | 0 | 0 | 1.0
30^b^ | 32 | 0.1 | 0.1 | 0 | 0 | 0 | 1.0
3 mg/m^3^
3 | 3 | 1.7 | 0 | 0.7 | 0 | 0 | 2.0
6 | 3 | 1.7 | 0 | 1 | 0 | 0 | 2.0
12 | 6 | 2 | 1 | 1.3 | 0.2 | 0 | 3.0
18 | 6 | 2 | 1.2 | 1.7 | 0.7 | 0.7 | 3.2
24 | 6 | 2 | 1.2 | 1.5 | 0.7 | 0.5 | 3.2
30^b^ | 23 | 2.4 | 1.7 | 1.5 | 0.8 | 0.5 | 2.9
9 mg/m^3^
3 | 3 | 2 | 0.3 | 1.3 | 0 | 0 | 2.3
6 | 3 | 2 | 0.7 | 2 | 0 | 0.3 | 2.7
12 | 6 | 2.3 | 1.2 | 2.2 | 1.7 | 0.2 | 4.0
18 | 6 | 2.3 | 1.8 | 2.2 | 1.8 | 0.7 | 4.0
24 | 6 | 2.5 | 1.8 | 2.2 | 2 | 0 | 4.0
30^b^ | 25 | 2.7 | 1.7 | 1.7 | 1.7 | 0.5 | 3.8
16 mg/m^3^
3 | 3 | 2 | 1 | 2 | 0 | 0 | 3.0
6 | 3 | 2.3 | 1.3 | 2 | 0 | 0 | 3.0
12 | 6 | 3 | 1.8 | 2.8 | 2.8 | 0.7 | 4.0
18 | 6 | 3 | 2.7 | 2.7 | 2.2 | 1.2 | 4.0
24 | 6 | 3 | 2.7 | 2.7 | 2.8 | 1.5 | 4.2
30^b^ | 20 | 3 | 2.5 | 2.1 | 2 | 1 | 4.0
30 mg/m^3^
3 | 3 | 2 | 1 | 2 | 2 | 0 | 3.3
6 | 3 | 2.7 | 2 | 2 | 2 | 0 | 4.0
12 | 6 | 3 | 2.3 | 2.5 | 2.5 | 1.5 | 4.0
18 | 3 | 3 | 2 | 2.3 | 2.3 | 1 | 4.3
24 | 6 | 3.2 | 2.7 | 2 | 2 | 0.5 | 4.0
30^b^ | 15 | 2.8 | 2.9 | 1.9 | 1.9 | 1.3 | 4.3

a 0–5 Scale for different types of lesions: 0=normal; 1=minimal; 2=mild; 3=moderate; 4=marked: 5=severe. 8-Grade Wagner Scale for pulmonary cellular change and fibrosis: 1=normal; 2 or 3=cellular change consistent with inflammation; 4=minimal fibrosis with collagen deposition, bronchiolization, and mucoid debris; 5=mild fibrosis with some interlobular linking of collagen; 6=moderate fibrosis with consolidation and parenchymal decrease; 7=severe fibrosis and consolidation; 8=complete obstruction of airways.

b Exposed for 24 months and sacrificed at 30 months.

c Bernstein et al. (2001b) reported that the original pathologist’s score for this lesion was for collagen deposition at the bronchoalveolar junction, not for pulmonary fibrosis; in the five-grade scale used for collagen deposition, a minimal score of 1 is of insufficient severity to be classified as minimal fibrosis (Grade 4 on the Wagner scale).

[underlined: Dose and end point used for MRL derivation]:

Benchmark concentration analysis was conducted for lung weights (absolute weight expressed as percent of control), macrophage aggregation scores, bronchiolization scores, and scores for collagen deposition at the bronchoalveolar junction. Changes in the first three variables are taken as signs of pulmonary inflammation induced by refractory ceramic fibers deposited in the lung. ATSDR policy considers pulmonary fibrosis to be a serious adverse effect that is inappropriate for MRL derivation. Scores for collagen deposition at the bronchoalveolar junction were included in the analysis, because a score of 1 for this lesion is not of sufficient severity to be considered fibrosis; only scores ≥2 were classified as pulmonary fibrosis.

Continuous-variable models available in the EPA Benchmark Dose Software were fit to the lung weight, macrophage, bronchiolization, and bronchoalveolar collagen deposition data shown in Table A-3. Each of these end points was increasingly affected with increasing exposure level and increasing concentrations of fibers in the lungs at 24 months (Table A-3). Group means and standard deviations of the lung weight, macrophage aggregation scores, and bronchiolization scores were obtained from a report of an analysis of the Mast et al. (1995a, 1995b) 24-month-sacrifice data by Yu and Oberdörster (2000). The mean scores and standard deviations for collagen deposition at the bronchoalveolar junction were obtained from data in the report by Bernstein et al. (2001b). The published report by Mast et al. (1995a, 1995b) only cited mean values and did not cite standard deviations. Dr. Yu’s analysis did not include scores (and standard deviations) for granuloma presence.

The benchmark response level for lung weight was set at 10% increase in weight. Percentage change below this value is assumed to be nonadverse. Benchmark response levels for scores for macrophage aggregation, bronchiolization, and bronchoalveolar collagen deposition were set at 1.0 (minimal rating on the 0–5 scale, where 0=normal).

Table A-3 Non-neoplastic Lung Responses in F344 Rats Exposed for 24 Months to RCF1 (Mast et al. 1995a, 1995b)

Exposure level | Fiber concentrations in lungs at 24 months | Lung weight | Mean score±standard deviation (0–5 Scale)
(total fibers/cc) | (mean total fibers per mg lung x10^4^) | (Percent of control) | Macrophage aggregation | Bronchiolization | Collagen deposition at the bronchoalveolar junction
0 (n=12) | NR | 100.0±14.0 | 0±0 | 0±0 | 0±0
36 (n=6) | 5.55±1.71 | 116.8±12.3 | 2.0±0 | 1.2±0.4 | 0.7±0.82
91 (n=6) | 18.80±3.59 | 110.9±8.1 | 2.5±0.6 | 1.8±0.4 | 2±0
162 (n=6) | 27.80±6.06 | 131.8±15.3 | 3.0±0 | 2.7±0.5 | 2.8±0.4
234 (n=6) | 37.00±8.01 | 164.7±44.2 | 3.2±0.4 | 2.7±0.5 | 2.2±0.4

0–5 Scale: 0=normal; 1=minimal; 2=mild; 3=moderate; 4=marked; 5=severe; NR= not reported

[ ] NOAEL [ ] LOAEL [X] Benchmark Concentration: Lower 95% confidence limits on benchmark concentrations (BMCLs = lower 95% confidence limit on the estimated concentrations associated with a mean score of 1.0 for macrophage aggregation, bronchiolization, or collagen deposition, or 10% increase in lung weight) were considered for selection of the point of departure for the MRL. The rat exposure-response data for these four end points were first fit to continuous-variable models. The best-fitting models were then used to calculate rat BMCLs for each of the end points. The point of departure for the MRL was selected from the rat BMCLs. The selected rat BMCL was then converted to a BMCL_HEC_ using a cross-species scaling factor derived from the lung deposition and clearance models developed for RCF1 in rats and humans (Maxim et al. 2003b; Yu and Oberdörster 2000; Yu et al. 1995a, 1995b, 1996, 1997, 1998a, 1998b).

Benchmark Concentration Modeling Results. Available continuous-variable models in the EPA Benchmark Dose Software (linear, polynomial, power, and Hill models; BMDS version) were fit to the data shown in Table A-3.

Lung Weight. Adequate fits to the data (as assessed by chi-square residuals and log-likelihood ratio fit tests in the BMDS) were obtained with the linear, polynomial, power, and Hill models with constant variance assumed. Statistical tests indicated that variances were not constant across exposure groups (this is reflected in the standard deviations listed in Table A-3). Models with non-homogeneous variance (i.e., variance as a power function of dose) generally provided improved fits to the data as assessed with Aikake’s Information Criteria, AIC (Table A-4). Comparing across models, a better fit is indicated by a lower AIC. The best-fitting model, as indicated by the AIC, was the power model with non-homo-geneous variance, which predicted a rat BMC and BMCL of 133 and 79 total fibers/cc, respectively (Figure A-1).

Table A-4 BMC Modeling Results for Lung Weights in Rats Exposed to RCF1 for 24 Months (Mast et al. 1995a, 1995b)

Model | BMC (total fibers/cc) | BMCL (total fibers/cc) | AIC-fitted
Linear | 40 | 30 | 220.12
Linear-nonhomogeneous | .9 | 32 | 213.51
Polynomial | 95 | 34 | 220.08
Polynomial-nonhomogeneous | 94 | 43 | 211.52
Power | 110 | 35 | 222.00
Power-nonhomogeneous^*^ | 133^*^ | 79^*^ | 209.30^*^
Hill | 10 | 35 | 224.00
Hill-nonhomogeneous | 60 | 6 | 228.90

* Best Fitting Model

Figure A-1 Predicted (Power Model with Nonhomogeneous Variance) and Observed Lung Weights in Rats Exposed to RCF1 for 24 Months (Mast et al. 1995a, 1995b) (Dose Refers To Rat Exposure Concentrations, Total Fibers/cc)

Macrophage Aggregation Scores. Adequate fits to the data (as assessed by chi-square residuals and log-likelihood fit tests in the BMDS) were obtained with the polynomial, power, and Hill models with constant variance assumed. Models with variance as a power function of dose did not improve the fits to the data. As assessed by AIC (Table A-5), the Hill model provided the best fit to the data, yielding a rat BMC and BMCL of 12 and 9 total fibers/cc, respectively (Figure A-2).

Table A-5 BMC Modeling Results for Scores for Pulmonary Macrophage Aggregation in Rats Exposed to RCF1 for 24 Months (Mast et al. 1995a, 1995b)

Model | BMC (total fibers/cc) | BMCL (total fibers/cc) | AIC-fitted
Hill^*^ | 12^*^ | 9^*^ | -33.05^*^
Polynomial | 21 | 13 | -12.08
Polynomial-nonhomogeneous | 13 | 0 | -8.44
Power | 6 | 0 | 13.67
Power-nonhomogeneous | 51 | 0 | 15.02

* Best Fitting Model

Figure A-2 Predicted (Polynomial Model with Constant Variance) and Observed Scores for Pulmonary Macrophage Aggregation in Rats Exposed to RCF1 for 24 Months (Mast et al. 1995a, 1995b) (Dose Refers to Rat Exposure Concentrations, Total Fibers/cc)

Bronchiolization Scores. Adequate fits to the data (as assessed by chi-square residuals and log-likelihood fit tests in the BMDS) were obtained with the polynomial and Hill models with constant variance assumed. Benchmark concentration calculations failed when models with variance as a power function of dose were fit to the data. The best-fitting model, as assessed by AIC, was the polynomial (2-degree) model (Table A-6), which yielded a rat BMC and BMCL of 37 and 30 total fibers/cc, respectively (Figure A-3).

Table A-6 BMC Modeling Results for Scores for Bronchiolization in Rats Exposed to RCF1 for 24 Months (Mast et al. 1995a 1995b)

Model | BMC (total fibers/cc) | BMCL (total fibers/cc) | AIC-fitted
Polynomial^*^ | 37^*^ | 30^*^ | -19.91^*^
Hill | 30 | 22 | -18.28

* Best Fitting Model

Figure A-3 Predicted (Polynomial Model with Constant Variance) and Observed Scores for Bronchiolization in Rats Exposed to RCF1 for 24 Months (Mast et al. 1995a, 1995b) (Dose Refers to Rat Exposure Concentrations, Total Fibers/cc)

Collagen Deposition Scores. Adequate fits to the data (as assessed by chi-square residuals and log-likelihood ratio fit tests in the BMDS) were obtained with the polynomial and Hill models with constant variance assumed. Benchmark concentration calculations failed when models with variance as a power function of dose were fit to the data. The best-fitting model, as assessed by AIC, was the polynomial (2-degree) model (Table A-7), which yielded a rat BMC and BMCL of 37 and 32 total fibers/cc, respectively (Figure A-4).

Table A-7 BMC Modeling Results for Scores for Collagen Deposition at the Bronchoalveolar Junction in Rats Exposed to RCF1 for 24 Months (Mast et al. 1995a, 1995b)

Model | BMC (total fibers/cc) | BMCL (total fibers/cc) | AIC-fitted
Polynomial^*^ | 37^*^ | 32^*^ | -12.52^*^
Hill | 45 | 37 | -5.25

* Best Fitting Model

Figure A-4 Predicted (Polynomial Model with Constant Variance) and Observed Scores for Collagen Deposition at the Bronchoalveolar Junction in Rats Exposed to RCF1 for 24 Months (Mast et al. 1995a, 1995b) (Dose Refers to Rat Exposure Concentrations, Total Fibers/cc)

Selection of Point of Departure for the MRL. BMCs and BMCLs for the four modeled end points are shown in Table A-8. The BMCL for lung weight represents the 95% lower confidence limit on the concentration estimated to increase lung weight by a mean of 10% over control values. The BMCLs for the pulmonary lesion scores represent the 95% lower confidence limits on the concentration estimated to produce a mean score of 1 (minimal severity) for each lesion.

Table A-8 BMCs and BMCLs for Lung Weight and Pulmonary Lesion Scores in Rats Exposed to RCF1 for 24 Months (Mast et al. 1995a, 1995b)

End point | BMC (total fiber/cc) | BMCL (total fiber/cc)
Lung weight | 133 | 79
Pulmonary macrophage aggregation | 12 | 9
Bronchiolization | 37 | 30
Collagen deposition at the bronchoalveolar junction | 37 | 32

The rat BMCL of 9 total fiber/cc for pulmonary macrophage aggregation was selected as the point of departure for the MRL, because this lesion is the most sensitive among those measured in the bioassay (as indicated by having the lowest BMCL in Table A-8). ATSDR considers minimal pulmonary inflammation a reversible response to fibers and nonfibrous particles that, although near the boundary between adverse and nonadverse, is an appropriate critical effect on which to base the MRL. As shown in the data in Table A-3, the severity of pulmonary macrophage aggregation in rats in the principal study showed a clear increase in severity with increasing exposure levels of RCF1, as well as with increasing concentrations of fibers in the lungs of the rats sacrificed after 24 months of exposure.

Dosimetric Adjustment of Rat Benchmark Concentrations to Human Equivalent Concentrations (HECs) The BMC and BMCL for pulmonary aggregation in rats were converted to human equivalent exposure levels using an average scaling factor derived from rat and human lung deposition and clearance models for RCF1 developed by Dr. C.P. Yu and colleagues (Yu et al. 1995a, 1995b, 1996, 1997, 1998a, 1998b). Equations for deposition in the models are functions of fiber length, fiber diameter, and time. The equations for mechanical macrophage-mediated clearance rate are functions of fiber length, alveolar macrophage volume, and lung burden (total accumulated volume of fibers and particles). The clearance models include dissolution-rate and transverse breakage-rate equations.

Values for key parameters in the dosimetric models included the following (Maxim et al. 2003b;Yu and Oberdörster 2000):

- Rat lung weight: 1.48 g; Human lung weight: 1,000 g
- Rat lung surface area: 4.3x10^3^ cm^2^; Human lung surface area: 6.5x10^5^ cm^2^
- Rat macrophage volume per lung: 26 mm^3^; Human macrophage volume per lung: 1.75x10^4^ mm^3^
- Rat macrophage diameter: 10.68 µm; Human macrophage diameter: 16.82 µm
- Dissolution rate (same in rats and humans): 6.46x10^-5^ (µm/day) or 0.73 ng/cm^2^/hour
- Breakage rate and scheme: same in rats and humans
- Size distribution of refractory ceramic fibers in the human model:
- Bivariate lognormal distribution (geometric mean±standard deviation) similar to workplace RCF size data: fiber diameter: 0.84 µm (±2.05); fiber length: 14.1 µm (±2.48)
- Rat model: retained volume of nonfibrous plus fibrous particles (lung burden) impacts clearance rate
- Human model: only retained fibrous particle volume impacts clearance rate.

Initially, Yu and Oberdörster (2000) calculated HECs from the rat exposure levels, using number of WHO fibers per cm^2^ of lung surface area as the cross species lung burden normalization unit. The rat models were set to the exposure scenarios experienced by rats in the Mast et al. (1995a, 1995b) bioassays (6 hours/day, 5 days/week for 2 years), and two human exposure scenarios were examined, one involving continuous, lifetime (70-year) exposure assuming a tidal volume of 750 cc and nasal breathing with a respiratory frequency of 14.5 per minute, and a second involving occupational exposure (8 hours/day, 5 days/week, 50 weeks/year for 40 years) assuming a tidal volume of 1290 cc and nasal breathing with a respiratory frequency of 15.5 per minute. Calculated HECs for the two human exposure scenarios from the rat exposure levels are shown in Table A-9. The mean ratios of the rat:human equivalent exposure concentrations were 14.7 for the continuous exposure scenario and 7.3 for the occupational exposure scenario. From these ratios, mean rat-to-human dosimetric scaling factors are 0.07 (1/14.7) for the continuous exposure scenario and 0.13 (1/7.3) for the occupational exposure scenario.

Table A-9 HECs Calculated for Two Human Exposure Scenarios from Rat Exposure Levels Using WHO Fibers per cm^2^ of Lung Surface area for Cross-Species Normalization. (Source: Tables 7.1 and 7.2; Yu and Oberdörster, 2000)

Human exposure scenario | Rat exposure levels (total fibers/cc) | | | | | Mean ratio rat:human (±SD)
Human exposure scenario | 0 | 36 | 91 | 162 | 234 | Mean ratio rat:human (±SD)
Human exposure scenario | HECs (WHO fibers/cc) | | | | | Mean ratio rat:human (±SD)
Continuous | 0 | 2.4 | 8.1 | 11.0 | 13.2 | 14.7 ±2.7
Occupational | 0 | 4.7 | 16.2 | 22.3 | 27.1 | 7.3 ±1.3

More recently, Maxim et al. (2003) showed that selection of the cross species lung burden normalization unit (i.e., number of fibers per cm2 of lung surface area versus number of fibers per mg dry weight of lung) is a key determinant in species conversion of exposure levels when using the lung and deposition models developed by Yu and colleagues. Using a human occupational exposure scenario assuming a tidal volume of 1,060 cc and nasal breathing with a respiratory frequency of 12.74 per minute and a minute ventilation of 13.5 L per minute, human equivalent concentrations corresponding to a rat exposure level of 36 total fiber/cc were calculated to be 5.7 total fiber/cc, based on a WHO fibers per cm^2^ of lung surface area normalization, compared with 33.8 total fibers/cc, based on a WHO fibers per lung mg dry weight normalization. The ratios of rat:human equivalent exposure concentrations for these occupational exposure scenarios were 6.3 on a lung surface area basis (similar to the mean of 7.3 shown in Table A-9) and 1.1 on a lung dry weight basis. For this occupational exposure scenario, rat-to-human dosimetric scaling factors based on lung surface area normalization or lung dry weight normalization are 0.16 (i.e., 1/6.3) and 0.9 (1/1.1), respectively, indicating an approximate 6-fold difference between lung surface area and lung dry weight normalizations.

A rat-to-human scaling factor of 0.07, based on a human continuous exposure scenario and lung surface area cross-species normalization, was used to convert the rat BMC and BMCL of 12 and 9 total fibers/cc to human equivalent concentrations of 0.8 and 0.6 WHO fibers/cc, respectively. This scaling factor was used, because data are not available to confirm which cross-species lung burden normalization method is more accurate, and calculations of mean rat-to-human dosimetric scaling factors, based on lung dry weight normalization with continuous exposure scenarios, are not available. It is recognized that the analysis by Maxim et al. (2003) indicates that an alternative scaling factor, based on lung dry weight cross species normalization, could be about 6-fold higher. The point of departure for the MRL is the BMCLHEC of 0.6 WHO fibers/cc, rounded to 1 WHO fibers/cc.

[underlined: Uncertainty Factors used in MRL derivation]:

[X] 3 for interspecies extrapolation with dosimetric adjustment. The dosimetric adjustment takes into account physiological differences between rats and humans expected to influence deposition and clearance of refractory ceramic fibers from the lung. It is recognized that the cross species dosimetric scaling factor used (based on fiber per lung surface area normalization) may underestimate the human equivalent concentration associated with the development of pulmonary lesions, compared with a scaling factor based on a fiber per lung dry weight basis. As such, the scaling factor based on lung surface area normalization is likely to be protective of the public health, and an additional factor to account for this dosimetric uncertainty is unnecessary. The derivation assumes that rats and humans are equally responsive to retained fibers in the lung, in the absence of conclusive evidence to indicate otherwise. The uncertainty factor of 3 accounts for the uncertainty associated with this assumption of interspecies pharmacodynamic equivalence.

[ ] 10 for use of a LOAEL: No uncertainty factor was necessary for the use of a BMCLHEC for minimal pulmonary macrophage aggregation, an effect just above the boundary between nonadverse and adverse.

[ X ] 10 for human variability

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose]? No.

[underlined: Was a conversion used from intermittent to continuous exposure]? Yes. The human lung and deposition model used a continuous, 70-year, exposure scenario, whereas the rat lung and deposition model used the experimental exposure conditions, 6 hours/day, 5 days/week for 2 years.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: See previous discussion of the derivation of the rat-to-human dosimetric scaling factor of 0.07.

Other additional studies or pertinent information which lend support to this MRL: The Mast et al. (1995a, 1995b) study provides the best available data describing exposure-response relationships for nonneoplastic lesions in the lung and pleura from chronic inhalation exposure to refractory ceramic fibers. The study identifies pulmonary inflammation as the critical nonneoplastic end point of concern and identifies other more serious effects at higher exposure levels (pulmonary and pleural fibrosis and cancer of the lung and pleura). Other studies of rats exposed to RCF1 by inhalation provide strong support for pulmonary inflammation as the critical end point (Bellman et al. 2001; Everitt et al. 1997; Gelzleichter et al. 1999; McConnell et al. 1995), as well as other animal inhalation studies of other refractory ceramic fibers (Mast et al. 1995a) and other synthetic vitreous fibers such as insulation glass wools, MMVF10 and MMVF11 (Hesterberg et al. 1993c; McConnell et al. 1999), slag wool MMVF22 (McConnell et al. 1994), and rock wool MMVF21 (McConnell et al. 1994).

There are distinct differences between laboratory animal species and humans in respiratory tract size and geometry, ventilation rate and pattern, and macrophage sizes that influence the retention (the net result of deposition and clearance) of fibers in the lung. Yu and colleagues (Yu et al. 1995a, 1995b, 1996, 1997, 1998a, 1998b) have developed lung retention models for RCF1 in rats and humans that incorporate many of these interspecies differences. Although these models significantly decrease uncertainty in extrapolating doses from rats to humans, in vivo human data on internal doses of inhaled synthetic vitreous fibers are limited, and validation exercises with the human model are correspondingly limited.

Several reviewers of draft versions of this Toxicological Profile disagreed with ATSDR’s selection of macrophage aggregation as the critical effect for the MRL. Reasons for not selecting macrophage aggregation included: (1) this end point is not a response that is specific to fibers (nonfibrous particles can also cause this effect), and (2) it is a reversible and adaptive effect and therefore nonadverse. The ATSDR MRL Workgroup acknowledged that although there were confounding effects from nonfibrous particles in the principal study, the data in Table 2 show that there was a clear relationship between concentrations of fibers in the lung and increasing severity of macrophage aggregation. The MRL Workgroup acknowledged the reversibility of macrophage aggregation, but does not consider reversibility as a criterion for not selecting a critical effect for MRL derivation.

The ATSDR MRL Workgroup discussed an alternative MRL derivation with collagen deposition as the critical effect, but preferred selection of macrophage aggregation as the critical effect. If collagen deposition was selected as the critical effect for the MRL, an alternative MRL of 0.02 WHO fibers/cc was derived as follows (using a benchmark response=a concentration that would produce an average score of 1 for bronchoalveolar collagen deposition in a population and a total uncertainty factor of 90: 3 for cross-species extrapolation, 10 for human variability, and 3 for the selection of a potentially serious adverse effect as the critical effect):

1. [Rat BMCL_collagen deposition_] × [cross-species scaling factor] = BMCL_collagen depositionHEC_
  32 total fiber/cc × 0.07 = 2.24 WHO fibers/cc = 2 WHO fibers/cc (rounded)
2. MRL = BMCL_collagen depositionHEC_ ÷ 90 = 2 ÷ 90 = 0.02 WHO fibers/cc.

The Workgroup noted the similarity of the values of the MRLs based on macrophage aggregation (0.03 WHO fibers/cc) or collagen deposition (0.02 WHO fibers/cc). The approximate 3-fold difference in the benchmark concentrations (9 total fibers/cc for macrophage aggregation and 32 total fibers/cc for collagen deposition) was offset by the 3-fold difference in the total uncertainty factors (30 for macrophage aggregation and 90 for collagen deposition).

The MRL derivation assumes that rats and humans are equally sensitive to the inflammatory effects of refractory ceramic fibers. Understanding of the relative pharmacodynamic sensitivity of rodents and humans to synthetic vitreous fibers, asbestos fibers, or nonfibrous particulate matter is poor. Varying opinions on the relative sensitivity of rodents and humans to deposited fibers have been expressed by Rodelsperger and Woitowitz (1995), Rowe and Springer (1986), Yu and Oberdörster (2000), Maxim and McConnell (2001), and Maxim et al. (2003). The uncertainty factor of 3 is used in the MRL derivation to account for the uncertainty of the assumption of pharmacodynamic equivalence between rats and humans.

Available comparative data with other refractory ceramic fibers (e.g., data for RCF2, RCF3, and RCF4 reported by Mast et al. 1995a) suggest that RCF1 is as potent or more potent in inducing various pulmonary effects than other refractory ceramic fibers. Thus, the chronic MRL based on RCF1 data is expected to be protective of the public health for exposure to other refractory ceramic fibers.

A significant contributing factor to the high potency of RCF1 relative to other refractory ceramic fibers is the high content of nonfibrous particles in RCF1. Bellmann et al. (2001) have reported that the mass concentration of total fibers (particles with aspect ratio >3:1) and nonfibrous particles (with aspect ratios <3:1) in RCF1 are 0.76 and 0.26 ng/ng RCF1, respectively. Evidence that the presence of the nonfibrous particles can enhance the effects on the lung was provided by comparing responses in rats exposed by inhalation for 3 weeks to concentrations of about 125 fibers (with lengths >20 µm)/cc of either RCF1 or a sample of refractory ceramic fibers, called RCF1a, in which only 2% of the mass was accounted for by nonfibrous particles (Bellmann et al. 2001). Expressed as WHO fibers/cc, the respective mean concentrations were 481 fibers/cc for RCF1a and 679 fibers/cc for RCF1. Pulmonary clearance ability was markedly depressed by RCF1, but not by RCF1a, and indices of pulmonary inflammation were more persistently increased by RCF1 than by RCF1a (Bellmann et al. 2001).

The ratio of nonfibrous particles:fibers for the RCF1 material used in the 2-year rat bioassay (Mast et al., 1995a, 1995b) has been reported to be about 3:1 by Bellmann et al. (2001), about 1-2:1 from data reported by Mast et al. (1995a, 1995b), and 9:1 by Maxim et al. (1997) and Mast et al. (2000). In contrast, workplace air samples (n=10) showed a ratio of about 0.5:1 (Mast et al. 2000; Maxim et al. 1997). Thus, a key uncertainty associated with the MRL is that the nonfibrous particles likely contributed to the observed lung responses to some undetermined degree. As such, the MRL may underestimate the daily human exposure that is likely to be without appreciable risk of adverse noncancer health effects, and is expected to be protective of public health.

Bernstein et al. (2001b) conducted an analysis to determine if there was a statistically significant relationship between scores for collagen deposition at the bronchoalveolar junction and lung fiber concentrations (of various size classes) in the data collected in chronic rat bioassays with five types of synthetic vitreous fibers (RCF1, MMVF21—a stone wool, MMVF 11—an insulation glass wool, MMVF10—an insulation glass wool, and MMVF22—a slag wool). In the analysis, logistic and proportional odds regression models were fit to data for scores for collagen deposition at the bronchoalveolar junction and associated lung fiber concentrations in the rats sacrificed after 24 months of exposure. In these analyses, lesion score was the dependent variable and lung fiber concentration (of various size classes) was the explanatory variable. Bernstein et al. (2001b; Figure 2) noted that the score for collagen deposition showed a statistically significant relationship with increasing lung concentrations of the five types of fibers with lengths >20 µm (and not with lung concentrations of fibers in smaller length categories).

In comments provided to ATSDR (ATSDR Docket No. ATSDR-187; January 23, 2003), Dr. Bernstein noted that his analysis extended to 10 other pulmonary end points evaluated in these bioassays (including scores for macrophage aggregation and bronchiolization), and that he did not find statistically significant relationships for these scores with the concentrations of the various types of fibers in the lungs of the rats. Dr. Bernstein’s analysis indicates that only the scores for collagen deposition (and not the other pulmonary end points) showed a statistically significant relationship with lung burden across the five types of synthetic vitreous fibers included in the analysis. Dr. Bernstein interpreted this to mean that, among the 11 pulmonary end points evaluated in these bioassays and this analysis, only collagen deposition had a statistically significant relationship with fiber lung burden at 24 months. Dr. Bernstein proposed that one reason for selecting bronchoalveolar collagen deposition as the critical end point for MRL derivation is that there was a lack of association for the other end points with lung fiber concentration at 24 months. An alternative interpretation of Dr. Bernstein’s analysis is that it shows that only the most biopersistent of the fibers evaluated (i.e., those, such as RCF1, that accumulated to a sufficiently high level in the lung after 2 years) produced moderate collagen deposition and that all of the fiber types included in the analysis induced the other less adverse responses (such as macrophage aggregation and bronchiolization) to degrees that were indistinguishable between fiber types. The data from the principal RCF1 study shown in Table A-3 clearly show that the severity of all of the pulmonary end points (including scores for macrophage aggregation and bronchiolization) increased with increasing exposure level and with increasing lung fiber concentration at 24 months. Thus, even though the nonfibrous particles in the RCF1 atmospheres may have contributed to the pulmonary responses in the rats, the data show a clear relationship between the severity of macrophage aggregation (and other more severe end points) and the internal dose of fibers deposited in the lung. As such, it appears reasonable to select macrophage aggregation as the critical effect for MRL derivation.

The chronic MRL is expected to be appropriately applied to intermediate-duration exposure scenarios, based on evidence from interim sacrifice data from the Mast et al. (1995b) bioassay that exposure-response relationships for pulmonary inflammation and chronic exposure are similar to those for intermediate-duration exposure. Scores for pulmonary inflammation progressed to only a limited degree with progression from intermediate to chronic duration. For example, mean scores for macrophage aggregation in rats exposed to 3, 9, 16, and 30 mg/m^3^ at 3 months were 1.7, 2, 2, and 2, respectively. The respective scores were 2, 2.3, 3, and 3 at 12 months and 2, 2.5, 3, and 3.2 at 24 months.

Exposure-response relationships for pulmonary inflammation from acute inhalation exposure to synthetic vitreous fibers are inadequately characterized for deriving an acute inhalation MRL for any type of synthetic vitreous fiber.

Any use of the MRL for refractory ceramic fibers in assessing health hazards from the insulation wools should acknowledge the evidence that many of the insulation wools are markedly less durable and less potent than refractory ceramic fibers (Bernstein et al. 2001a, 2001b; Eastes and Hadley 1996; Eastes et al. 2000; Hesterberg et al. 1998a). There are data from multiple-exposure-level 2-year rat inhalation bioassays on the glass wools, MMVF10 and MMVF11 (Hesterberg et al. 1993c; McConnell et al. 1999), the slag wool MMVF22 (McConnell et al. 1994), and the rock wool MMVF21 (McConnell et al. 1994) that adequately describe exposure-response relationships for nonneoplastic pulmonary effects from intermediate- and chronic-duration exposure to these materials. However, lung deposition and clearance models for these synthetic vitreous fibers (such as those developed by C.P. Yu and colleagues for RCF1) are not yet fully developed to carry out physiologically based dosimetric calculations of human equivalent concentrations. When these models are available, they could be used to convert rat exposure concentrations to human equivalent concentrations, and use the data for MMVF10, MMVF11, MMVF22, and MMVF21 to derive inhalation MRLs for insulation wools.

There are no adequate data (from multiple-exposure level studies) for deriving inhalation MRLs for the other types of synthetic vitreous fibers (special applications glass fibers or continuous filament glass fibers that are woven).

[underlined: Agency Contact (Chemical Manager)]: Malcolm Williams, D.V.M., Ph.D.