# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Information regarding the chemical identity of sulfur trioxide, sulfuric acid, and oleum (fuming sulfuric acid) is located in Table 3-1.

The acid strength of sulfuric acid is designated as percentage sulfuric acid or degrees Baume (ºBé) (IARC 1992). Degrees Baume is a mathematical relationship with specific gravity (Bé = 145 - [145/specific gravity]) that is consistent at concentrations below 93.2% sulfuric acid. At higher concentrations, the acid is referred to in terms of percentage sulfuric acid. The strength of oleum is indicated by the percentage of free dissolved sulfur trioxide, or as the equivalent percentage of 100% sulfuric acid.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of sulfur trioxide, sulfuric acid, and oleum (fuming sulfuric acid) is located in Table 3-2.

Table 3-1 Chemical Identity of Sulfur Trioxide, Sulfuric Acid, and Oleum

Characteristic | Sulfur trioxide | Sulfuric acid | Oleum | Reference
Synonyms | Sulfur trioxide; sulfur oxide; sulfuric anhydride; sulfan | Diothionic acid; brown oil; oil of vitriol; vitriol oleum; vitriol brown oil; dripping acid; BOV | Fuming sulfuric acid; disulphuric acid; dithionic acid; pyrosulphuric acid | HSDB 1998
Registered trade name(s) | Sulfan® | No data | No data | HSDB 1998
Chemical formula | SO_3_ | H_2_SO4 | H_2_SO_4_ with free SO_3_ | HSDB 1998
Chemical structure
Identification numbers:
CAS registry | 7446-11-9 | 7664-93-9 | 8014-95-7 | HSDB 1998
NIOSH RTECS | WT4830000 | WS5600000 | WS5605000 | HSDB 1998
EPA hazardous waste | No data | No data | No data
OHM/TADS | No data | 7216915 | 8500424 | OHM/TADS98
DOT/UN/NA/IMCO shipping | UN 1829, IMO 8.0 (inhibited), IMO 2.0 (uninhibited) | UN1830(≤65.25%), UNI832 (spent), UNI786; IMO 8.0 | UN1831, IMO 8.0 | HSDB 1998
HSDB | 6338 | 1811 | 1236 | HSDB 1998
NCI | No data | No data | No data

CAS = Chemical Abstracts Service; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 3-2 Physical and Chemical Properties of Sulfur Trioxide, Sulfuric Acid, and Oleum^a^

Property | Sulfur trioxide | Sulfuric acid | Oleum | Reference
Molecular weight | 80.06 | 98.07 | 178.14 | HSDB 1998; Lide 1993
Color | Silky fiber needle (∝) asbestos-like fiber (β); metastable | Colorless liq. | colorless or slightly colored
Physical state | Gas, liquid, or solid | liquid | heavy, oily liquid
Melting point | 16.83°C (α); 62.4°C (β) | 10.36°C (100%) | No data
Boiling point | 44.8°C (α); 50°C (β)(subl) | 350 ± 0.5 (100%) | No data
Density | -357 g/L at 0°C, 1.97 g/cm^3^ at 20°C | 1.841 (96-98%) | 114.70 lb/ft^3^
Odor | No data | Odorless | No data
Odor threshold:
Water | No data | No data | No data
Air | No data | Low: 1.0 mg/m^3^; high: 1.0 mg/m^3^; irritating: 1.10 mg/m^3^ | No data
Solubility:
Water at 0°C | No data | No data | No data
Water at 20°C | No data | No data | No data
Water at 25°C | No data | No data | No data
Organic solvent(s) | No data | Decomp. Alcohol | No data | HSDB 1998
Partition coefficients:
Log K_ow_ @ 25°C | No data | 1.92 | No data
Lo K_oc_ | No data | No data | No data
Vapor pressure | 73 mm Hg at 25°C (α); 344 mm Hg at 25°C (β) | 1 mm Hg at 145.8°C | No data | HSDB 1998
Henry’s law constant | No data | No data | No data
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability limits | No data | Noflammable | Nonflammable
Conversion factors | 1 ppm = 0.31 mg/m^3^ | 1 ppm = 4.08 mg/m^3^ | No data
Explosive limits | No data | No data | No data | HSDB 1998

a Lide, David. 1994. CRC Handbook of Chemistry and Physics. 74th ed. Boca Raton, FL: CRC Press.