# 9 REFERENCES

*Cited in text

Aasted A, Darre E, Wulf HC. 1987. Mustard gas clinical toxicological and mutagenic aspects based on modern experience. Ann Plast Surg 19:330–333.3318637
*Aasted A, Wulf HC, Darre E, . 1985. [Fishermen exposed to mustard gas. Clinical experience and evaluation of the cancer risk.] Ugeskrift for Laeger 147:221–2216. (Dutch)
Abe Y, Sugisaki K, Dannenberg AM. 1996. Rabbit vascular endothelial adhesion molecules: ELAM-1 is most elevated in acute inflammation, whereas VCAM-1 and ICAM-1 predominate in chronic inflammation. J Leukoc Biol 60:692–703.8975870
Abramowicz M. 2002. Prevention and treatment of injury from chemical warfare agents. The Medical Letter: On drugs and therapeutics 44(1121):1–4.11856948
*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
*Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles: Notice. Fed Regist 54(174):37618–37634.
*Agency for Toxic Substances and Disease Registry. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Subcommittee on Biomarkers of Organ Damage and Dysfunction.
*Alexander SF. 1947. Medical report of the Bari Harbor mustard casualties. Military Surgeon 101:1–17.20248701
*Ali-Mattila E, Siivinen K, Kenttamaa H, . 1983. Mass spectrometric methods in structural analysis of some vesicants. Int J Mass Spectrom Ion Phys 47:371–374.
*Allon N, Gilat E, Amir A, . 1993. Sulfur mustard inhalation induced respiratory lesions in guinea pigs: Physiological, biochemical and histological study. In: Proceedings of the medical defense bioscience review (1993) held in Baltimore, Maryland on 10-13 May 1993. Volume 1. Springfield, VA: US Department of Commerce, 133–139
*Altman PL, Dittmer DS. 1974. In: Biological handbooks: Biology data book. Vol. III. 2^nd^ ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
Altus Biologics Inc. 2000. Stabilized crystalline OPAA-2 for additive in topical skin protectant. ADB261408.
*Amalric P, Bessou P, Farenc M. 1965. [Delayed relapsing mustard gas keratitis.] Bull Soc Ophtal Franc 65:101–106. (French)5828925
Amir A, Chapman S, Gozes Y, . 1998. Protection by extracellular glutathione against sulfur mustard induced toxicity in vitro. Hum Exp Toxicol 17:652–660.9988369
*Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York: Marcel Dekker, Inc., 9–25.
*Andersen ME, Clewell HJ III, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
*Anderson JS. 1942. The effect of mustard gas vapour on eyes under Indian hot weather conditions. CDRE (India)- Report No. 241.
Anderson DR, Byers SL, Clark CR, . 1997. Biochemical alterations in rat lung lavage fluid following acute sulfur mustard inhalation. Inhal Toxicol 9:43–51.
Anderson DR, Yourick JJ, Moeller RB, . 1996. Pathologic changes in rat lungs following acute sulfur mustard inhalation. Inhal Toxicol 8:285–297.
Andrew DJ, Lindsay CD. 1998. Protection of human upper respiratory tract cell lines against sulphur mustard toxicity by hexamethylenetetramine (HMT). Hum Exp Toxicol 17:373–379.9726533
Anft M. 1988. Burnt offerings: A generation of chemical weapons is scheduled to go up in smoke. Environmental Action 11–13.
*Angelov A, Belchev L, Angelov G. 1996a. Study of some toxic effects of sulfur mustard gas on broiler chickens. Vet Archiv 66:27–34.
Angelov A, Belchev L, Angelov G. 1996b. Experimental sulfur mustard gas poisoning and protective effect of different medicines in rats and rabbits. Indian Vet J 73:546–551.
*Anslow WP, Houck CR. 1946. Systemic pharmacology and pathology of sulfur and nitrogen mustards. In: Chemical warfare agents and related chemical problems. Part 4. Chapter 22. U.S. Office of Scientific Research and Development. Washington, DC: National Defense Research Committee, 440–478.
*Arroyo CM, Schafer RJ, Carmichael AJ. 2000. Reactivity of chloroethyl sulfides in the presence of a chlorinated prophylactic: a kinetic study by EPR/spin trapping and NMR techniques. J Appl Toxicol 20:S7–S12.11428646
Arroyo CM, Schafer RJ, Kurt EM, . 1999. Response of normal human keratinocytes to sulfur mustard (HD): Cytokine release using a non-enzymatic detachment procedure. Hum Exp Toxicol 18:1–11.10025362
*Ashby J, Tinwell H, Callander RD, . 1991. Genetic activity of the human carcinogen sulphur mustard towards salmonella and the mouse bone marrow. Mutat Res 257:307–311.2014034
Atkinson R. 1987. A structure-activity relationship for the estimation of rate constants for the gas-phase reactions of OH radicals with organic compounds. Int J Chem Kinet 19:799–828.
*Auerbach C. 1947. The induction by mustard gas of chromosomal instabilities in Drosophila melanogaster. Proc R Soc Edinb 62B:307–320.
Auerbach C, Robson JM. 1946. Tests of chemical substances for mutagenic action. 1946/1947 Proceedings of the Royal Society Edinburgh, Section B 62:284–291.
Augerson WS, Sivak A, Marley WS. 1986. Chemical casualty treatment protocol development-treatment approaches. Vol II-IV. Cambridge, MA: Arthur D. Little, Inc.
Axelrod DJ, Hamilton JG. 1947. Radio-autographic studies of the distribution of lewisite and mustard gas in skin and eye tissues. Am J Pathol 23:389–411.19970936
*Azizi F, Amini M, Arbab P. 1993. Time course of changes in free thyroid indices, rT3, TSH, and ACTH following exposure to sulfur mustard. Exp Clin Endocrinol 101:303–306.8299707
*Azizi F, Keshavarz A, Roshanzamir F, . 1995. Reproductive function in men following exposure to chemical warfare with sulphur mustard. Med War 11:34–44.7731411
Back KC, Thomas AA, MacEwen JD. 1972. Reclassification of material listed as transportation health hazards. Office of Hazardous Materials of the Assistant Secretary for Safety and Consumer Affairs, Department of Transportation. TSA-2072-3, PB214270.
*Balali-Mood M. 1986. First report of delayed toxic effects of yperite poisoning in Iranian fighters. In: Heyndricks B, ed. Terrorism: Analysis and detection of explosives. Proceedings of the Second World Congress on new compounds in biological and chemical warfare. Gent: Rijksuniversiteit. 489–495.
*Ball CR, Roberts JJ. 1971/72. Estimation of interstrand DNA cross-linking resulting from mustard gas alkylation of HeLa cells. Chem Biol Interact 4:297–303.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
*Bartlett PD, Swain CG. 1949. Kinetics of hydrolysis and displacement reactions of β,β’-dichlorodiethyl sulfide (mustard gas) and of β-chloro-β’-hydroxydiethyl sulfide (mustard chlorohydrin). J Am Chem Soc 71:1406–1415.18140949
*Baskin SI, Prabhaharan V, Bowman JD, . 2000. In vitro effects of anionic sulfur compounds on the spectrophotometric properties of native DNA. J Appl Toxicol 20:S3–S5.11428639
Battista SP, McSweeney ES Jr. 1965. Approaches to a quantitative method for testing eye irritation. J Soc Cosmet Chem 16:119–131.
*BEA. 2001. Chemical Weapons Convention requirements. Schedules of chemicals. U.S. Bureau of Export Administration. Code of Federal Regulations. 15 CFR 745. http://ecfr.access.gpo.gov/otcgi/cfr/otfilter.cgi?DB=…andI&QUERY=8180&RGN=BAPPCT&SUBSET=SUBSET&FROM=1&ITEM=1 (http://ecfr.access.gpo.gov/otcgi/cfr/otfilter.cgi?DB…andI&QUERY=8180&RGN=BAPPCT&SUBSET=SUBSET&FROM=1&ITEM=1). May 24, 2001.
*Beck NV, Carrick WA, Cooper DB, . 2001. Extraction of thiodiglycol from soil using pressurized liquid extraction. J Chromat 907:221–227.
*Beebe GW. 1960. Lung cancer in World War I veterans: Possible relation to mustard gas injury and 1918 influenza epidemic. J Natl Cancer Inst 25:1231–1252.13688610
Belcher DW. 1977. Spray drying of war gas residue. CEP 101–104.
*Benschop HP, van der Schans GP, Noort D, . 1997. Verification of exposure to sulfur mustard in two casualties of the Iran-Iraq Conflict. J Anal Toxicol 21:249–251.9248939
Berenblum I. 1931. The anti-carcinogenic action of dichlorodiethylsulphide (mustard gas). J Pathol Bacteriol 34:731–746.
Berenblum I. 1935. Experimental inhibition of tumor induction by mustard gas and other compounds. J Pathol Bacteriol 40:549–558.
*Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag.
*Bhat KR, Benton BJ, Rosenthal DS, . 2000. Role of poly (ADP-ribose) polymerase (PARP) in DNA repair in sulfur mustard-exposed normal human epidermal keratinocytes (NHEK). J Appl Toxicol 20:S13–S18.11428624
Bhattacharya R, Rao LPV, Pant SC, . 2001. Protective effects of amifostine and its analogues on sulfur mustard toxicity in vitro and in vivo. Toxicol Appl Pharmacol 176:24–33.11578146
*Bide RW, Sawyer TW, DiNinno VL, . 1993. Skin decontamination of G, V, H & L agents by Canadian reactive skin decontamination lotion. In: Proceedings of the medical defense bioscience review (1993) held in Baltimore, Maryland on 10-13 May 1993. Vol. 1. Springfield, VA: US Department of Commerce, 379–387.
*Black RM, Read RW. 1991. Methods for the analysis of thiodiglycol sulphoxide, a metabolite of sulphur mustard, in urine using gas chromatography-mass spectrometry. J Chromatogr 558:393–404.1797813
*Black RM, Read RW. 1995a. Biological fate of sulphur mustard, 1,1’-thiobis(2-chloroethane): Identification of β-lyase metabolites and hydrolysis products in human urine. Xenobiotica 25(2):167–173.7618344
*Black RM, Read RW. 1995b. Improved methodology for the detection and quantization of urinary metabolites of sulphur mustard using gas chromatography-tandem mass spectrometry. J Chromatogr 665:97–105.
*Black RM, Read RW. 1997. Application of liquid chromatography-atmospheric pressure chemical ionization mass spectrometry, and tandem mass spectrometry, to the analysis and identification of degradation products of chemical warfare agents. J Chromatogr 759:79–92.
*Black RM, Brewster K, Clarke RJ, . 1992a. Biological fate of sulphur mustard, 1,1’-thiobis(2-chloroethane): Isolation and identification of urinary metabolites following intra peritoneal administration to rat. Xenobiotica 22(4):405–418.1523861
Black RM, Brewster K, Clarke RJ, . 1993a. Metabolism of thiodiglycol (2,2’-thiobis-ethanol): Isolation and identification of urinary metabolites following intra peritoneal administration to rat. Xenobiotica 23(5):473–481.8342295
*Black RM, Clarke RJ, Cooper DB, . 1993b. Application of head space analysis, solvent extraction, thermal desorption and gas chromatography-mass spectrometry to the analysis of chemical warfare samples containing sulphur mustard and related compounds. J Chromatogr 637:71–81.
*Black RM, Clarke RJ, Harrison JM, . 1997a. Biological fate of sulphur mustard: Identification of valine and histidine adducts in hemoglobin from casualties of sulphur mustard poisoning. Xenobiotica 27(5):499–512.9179990
*Black RM, Clarke RJ, Read RW. 1991. Analysis of 1,1’-sulphonylbis[2-(methylsulphinyl)ethane] and 1-methylsulphinyl-2-[2-(methylthio)ethylsulphonyl]ethane, metabolites of sulphur mustard, in urine using gas chromatography-mass spectrometry. J Chromatogr 558:405–414.1797814
*Black RM, Clarke RJ, Read RW, . 1994. Application of gas chromatography-mass spectrometry and gas chromatography-tandem mass spectrometry to the analysis of chemical warfare samples, found to contain residues of the nerve agent sarin, sulphur mustard and their degradation products. J Chromatogr 662:301–321.
*Black RM, Hambrook JL, Howells DJ, . 1992b. Biological fate of sulfur mustard, 1,1’-thiobis(2-chloroethane) Urinary excretion profiles of hydrolysis products and β-lyase metabolites of sulfur mustard after cutaneous application in rats. J Anal Toxicol 16:79–84.1501468
*Black RM, Harrison JM, Read RW. 1997b. Biological fate of sulphur mustard: In vitro alkylation of human hemoglobin by sulphur mustard. Xenobiotica 27(1):11–32.9041676
Blair A, Kazerouni N. 1997. Reactive chemicals and cancer. Cancer Causes Control 8:473–490.9498905
*Blank JA, Lane LA, Olson CT. 1996. Protein alterations in weanling pig skin following percutaneous sulfur mustard exposure. Medical Research and Evaluation Facility. Columbus, OH.
*BNA. 2001. Environment and Safety Library on the Web States and Territories. Washington, D.C. Bureau of National Affairs, Inc. http://www.esweb.bna.com/. February 23, 2001.
Bodell WJ, Gerosa M, Aida T, . 1985. Investigation of resistance to DNA cross-linking agents in 9L cell lines. Cancer Res 45:3460.3860285
Bongiovanni R, Millard CB, Schultz SM, . 1993. Estimation of neutrophil infiltration into hairless guinea pig skin treated with 2,2’-dichlorodiethyl sulfide. In: Proceedings of the medical defense bioscience review (1993) held in Baltimore, Maryland on 10–13 May 1993. Vol. 1. Springfield, VA: US Department of Commerce, 389–395.
*Borak J, Sidell F. 1992. Agents of chemical warfare: Sulfur mustard. Anal Emerg Med 21:303–308.
Borges HT, Faust RA, Watson AP, . 1996. Preliminary data analysis and derivation of an estimated reference dose (RfD) for sulfur mustard (HD). Toxicologist 30(1 part 2):149.
Boronin AM, Ermakova IT, Sakharovsky VG, . 2000. Ecologically safe destruction of the detoxification products of mustard-lewisite mixtures from the Russian chemical stockpile. J Chem Technol Biotechnol 15:82–88.
*Borrett VT, Matthews RJ, Colton R, . 1996. Verification of the United Nations Chemical Weapons Convention: the application of electrospray mass spectrometry. Rapid Commun Mass Spectrom 10:1114–118.
Bossle PC, Ellzy MW, Martin JJ. 1992. Detection of thiodiglycol and its sulfoxide and sulfone analogues in environmental waters by high performance liquid chromatography. In: Abstracts of papers, part 1, 203^rd^ ACS national meeting, 0-8412-2210-X. San Francisco, CA: American Chemical Society.
Boublik T, Fried V, Hala E. 1984. The vapor pressures of the temperature dependence of the vapor pressures of some pure substances in the normal and low pressure region. 2^nd^ ed. Amsterdam, Oxford, New York, Tokyo: Elsevier.
*Boursnell JC, Cohen JA, Dixon M, . 1946. Studies on mustard gas (ββ’-dichlorodiethyl sulphide) and some related compounds. 5. The fate of injected mustard gas (containing radioactive sulphur) in the animal body. Biochem J 40:757–764.
*Bowden E. 1943. Median detectable concentrations by odor of plant run mustard, plant run lewisite and pilot plant ethyl nitrogen mustard. TDMR 615. Chemical Warfare Service.
*Brankowitz WR. 1987. Chemical weapons movement. History compilation. Aberdeen Proving Ground, MD: Office of the Program Manager for chemical munitions (demilitarization and binary), ADA193348.
Brimfield AA. 1995. Possible protein phosphatase inhibition by bis(hydroxyethyl)sulfide, a hydrolysis product of mustard gas. Toxicol Lett 78:43–48.7604398
Brown RFR, Rice P. 1997. Histopathological changes in Yucatan minipig skin following challenge with sulphur mustard. A sequential study of the first 24 hours following challenge. Int J Exp Pathol 78:9–20.9166101
*Budavari S, O’Neil MJ, Smith A, . eds. 1996. The Merck index. An encyclopedia of chemicals drugs and biologicals. 12^th^ ed. Whitehouse Station, NJ: Merck & Co. Inc., 1082.
*Budiansky S. 1984. Chemical weapons: “United Nations accuses Iraq of military use.” Nature 308:483.6709053
Bullman T, Kang H. 1994. The effects of mustard gas, ionizing radiation, herbicides, trauma, and oil smoke on U.S. military personnel: The results of veteran studies. Annu Rev Public Health 15:69–90.8054100
*Bullman T, Kang H. 2000. A fifty year mortality follow-up study of veterans exposed to low level chemical warfare agent, mustard gas. Ann Endocrinol (Paris) 10(5):333–338.
*Burrows EP. 1998. Analysis of chemical warfare agents and their transformation products. Govt Reports Announcements & Index (GRA&I), Issue 05.
Byrne MP, Broomfield CA, Stites WE. 1996. Mustard gas cross linking of proteins through preferential alkylation of cysteines. J Protein Chem 15(2):131–136.8924198
Calabrese EJ, Baldwin LA, Leonard DA, . 1995. Decrease in hepatotoxicity by lead exposure is not explained by its mitogenic response. J Appl Toxicol 15(2):129–132.7782558
*Calvet JH, Coste A, Levame M, . 1996. Airway epithelial damage induced by sulfur mustard in guinea pigs, effects of glucocorticoid. Hum Exp Toxicol 15:964–971.8981100
Calvet JH, D’Ortho MP, Jarreau PH, . 1994a. Glucocorticoid inhibit sulfur mustard-induced airway muscle hyperresponsiveness to substance P. J Appl Physiol 77(5):2325–2332.7532648
Calvet JH, Gascard JP, Delamanche S, . 1999a. Airway epithelial damage and release of inflammatory mediators in human lung parenchyma after sulfur mustard exposure. Hum Exp Toxicol 18:77–81.10100019
Calvet JH, Jarreau PH, Levame M, . 1994b. Acute and chronic respiratory effects of sulfur mustard intoxication in guinea pig. J Appl Toxicol 76(2):681–688.
Calvet JH, Planus E, Rouet P, . 1999b. Matrix metalloproteinase gelatinases in sulfur mustard-induced acute airway injury in guinea pigs. Am J Physiol 276:L754–L762.10330031
*Calvet JH, Trouiller G, Harf A. 1993. Acute and chronic respiratory lesions induced by sulfur mustard in guinea pigs: Role of Tachykinins. In: Proceedings of the medical defense bioscience review (1993) held in Baltimore, Maryland on 10-13 May 1993. Vol. 1. Springfield, VA: US Department of Commerce, 123–132.
*Cameron GR, Gaddum JH, Short RHD. 1946. The absorption of war gasses by the nose. J Pathol Bacteriol 58:449–455.20283081
*Capizzi RL, Papirmeister B, Mullins JM, . 1974. The detection of chemical mutagens using the L5178Y/Asn-murine leukemia in vitro and in a host-mediated assay. Cancer Res 34:3073–3082.4370835
Capizzi RL, Smith WJ, Field R, . 1973. A host-mediated assay for chemical mutagens using L5178Y/Asn murine leukemia. Mutat Res 21:6.
Carrick WA, Cooper DB, Muir B. 2001. Retrospective identification of chemical warfare agents by high-temperature automatic thermal desorption-gas chromatography-mass spectrometry. J Chromatogr A 925:241–249.11519809
Carter CA, Yvette H, Ludlum DB. 1988. Release of 7-alkylguanines from haloethylnitrosourea-treated DNA by E. coli 3-methyladenine-DNA Glycosylase II. Biochem Biophys Res Comm 155:1261–1265.3052445
*Case RA, M, Lea AJ. 1955. Mustard gas poisoning, chronic bronchitis, and lung cancer: An investigation into the possibility that poisoning by mustard gas in the 1914-18 war might be a factor in the production of neoplasia. Br J Prev Soc Med 9:62–72.14378527
*Casillas RP, Smith KJ, Castrejon LR, . 1996. Effect of topically applied drugs against HD-induced cutaneous injury in the mouse ear edema model. Med Def Biosci Rev. 2:801–809.
*Casselman AA, Gibson NCC, Bannard RAB. 1973. A rapid, sensitive, gas-liquid chromatographic method for the analysis of bis(2-chloroethyl) sulfide collected from air in hydrocarbon solvents. J Chromatogr 78:317–322.
Chakrabarti AK, Ray P, Broomfield CA, . 1998. Purification and characterization of protease activated by sulfur mustard in normal human epidermal keratinocytes. Biochem Pharmacol 56:467–472.9763222
*Chauhan RS, Murty LVR. 1997. Effect of topically applied sulphur mustard on guinea pig liver. J Appl Toxicol 17:415–419.9418951
*Chauhan RS, Murthy LVR, Arora U, . 1996. Structural changes induced by sulphur mustard in rabbit skin. J Appl Toxicol 16:491–495.8956094
*Chauhan RS, Murthy LVR, Malhotra RC. 1993a. Effect of sulphur mustard on mouse skin-an electron microscopic evaluation. Bull Environ Contam Toxicol 51:374–380.8219592
*Chauhan RS, Murthy LVR, Pandey M. 1993b. Histomorphometric study of animal skin exposed to sulphur mustard. Bull Environ Contam Toxicol 51:138–145.8318764
*Chauhan RS, Murthy LVR, Pant SC. 1995. Electron microscopic study of guinea pig skin exposed to sulphur mustard. Bull Environ Contam Toxicol 55:50–57.7545039
CHEMFATE. 2001. Di-2-chloroethyl sulfide. Syracuse Research Corp. http://esc.syrres.com/efdb/Chemfate.htm. May 29, 2001.
Cheng TC, Kolakowski JE, Harvey SP. 1993. Bioprocessing of industrial and agricultural waste 1: Advances in the biodegradation of chemical warfare agents and related materials. J Cell Biochem Suppl 21A:41.
*Chilcott RP, Jenner J, Carrick W, . 2000. Human skin absorption of bis-2-(chloroethyl)sulphide (sulphur mustard) in vitro. J Appl Toxicol 20:349–355.11139165
*Chilcott RP, Jenner J, Hotchkiss SAM, . 2001. In vitro skin absorption and decontamination of sulphur mustard: comparison of human and pig-ear skin. J Appl Toxicol 21:279–283.11481660
*Clark DN. 1989. Review of reactions of chemical agents in water. Final report. Fort Detrick, Frederick, Maryland: U.S. Army Medical Research and Development Command. 88PP8847, 39–43.
*Clark E, Smith WJ. 1993. Activation of poly (ADP-RIBOSE) polymerase by sulfur mustard in hela cell cultures. In: Proceedings of the medical defense bioscience review (1993) held in Baltimore, Maryland on 10-13 May 1993. Vol. 1. Springfield, VA: US Department of Commerce 199–205.
Clark CR, Smith JR, Shih ML. 1999. Development of an in vitro screening method for evaluating decontamination of sulfur mustard by reactive dermal formulations. J Appl Toxicol 19:S77–S81.10594905
Clemedson CJ, Kristoffersson H, Sorbo B, . 1963. Whole body autoradiographic studies of the distribution of sulphur 35-labelled mustard gas in mice. Acta Radiol Ther Phys Biol 1:314–320.14073976
*Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Code of Maryland Regulations (COMAR). 1990. State of Maryland 26.11.15. Toxic Air Pollutants. The Bureau of National Affairs, Inc., Washington, D.C.
Cohen B. 1946. Kinetic reactions of sulfur and nitrogen mustards. In: Chemical warfare agents and related problems parts III-IV. Summary technical report of Division 9, NRDC. Washington, DC: Office of Scientific Research and Development. PB158508, 415–424.
Cohen AM, Prabhaker H. 1983. Carcinogen induced DNA damage in isolated rat liver nuclei. Cancer Lett 18:163–167.6831392
*Cohn JP. 1999. A make over for rocky mountain arsenal. Bioscience 49(4):273–277.
*Colburn EF. 1978. Monitoring the disposal of hazardous materials. 4^th^ ed. Joint Conference on Sensing of Environmental Pollutants, New Orleans, LA, 1977. Washington, DC: American Chemical Society, 489–492.
*Colborn T, Clement C. 1992. Chemically induced alterations in sexual and functional development. The Wildlife/Human Connection. In: Advances in modern environmental toxicology. Volume XXI. Princeton, NJ: Princeton Scientific Publishing Co.
Corsini E, Galli CL. 1998. Cytokines and irritant contact dermatitis. Toxicol Lett 102–103:277–282.10022266
*Coutelier JP, Lison D, Simon O, . 1991. Effect of sulfur mustard on murine lymphocytes. Toxicol Lett 58:143–148.1949073
*Cowan FM, Anderson DR, Broomfield CA, . 1997. Biochemical alterations in rat lung lavage fluid following acute sulfur mustard inhalation: II. Increases in proteolytic activity. Inhal Toxicol 9:53–61.
*Cowan FM, Yourick JJ, Hurst CG, . 1993. Sulfur mustard-increased proteolysis following in vitro and in vivo exposures. In: Proceedings of the medical defense bioscience review (1993) held in Baltimore, Maryland on 10-13 May 1993. Vol. 1. Springfield, MA: US Department of Commerce, 49–55.
Crathorn AR, Roberts JJ. 1965. Reactions of cultured mammalian cells of varying radiosensitivity with the radiomimetic alkylating agent, mustard gas. Prog Biochem Pharmacol 1:320–326.
Crathorn AR, Roberts JJ. 1966. Mechanism of the cytotoxic action of alkylating agents in mammalian cells and evidence for the removal of alkylated groups from deoxyribonucleic acid. Nature 211:150–153.5965513
Creasy WR, Brickhouse MD, Morrissey KM, . 1999. Analysis of chemical weapons decontamination waste from old ton containers from Johnston Atoll using multiple analytical methods. Environ Sci Technol 33:2157–2162.
Creasy WR, Stuff JR, Williams B, . 1997. Identification of chemical-weapons-related compounds in decontamination solutions and other matrices by multiple chromatographic techniques. J Chromatogr 774:253–263.
*Cullumbine H. 1946. The mode of penetration of the skin by mustard gas. Br J Dermatol 58:291–294.
*Cullumbine H. 1947. Medical aspects of mustard gas poisoning. Nature 4031:151–153.
Culp SJ, Gaylor DW, Sheldon WG, . 1998. A comparison of the tumors induced by coal tar and benzo[a]pyrene in a 2-year bioassay. Carcinogenesis 19(1):117–124.9472702
*Currie DJ, Weaver RS, Cameron BG. 1977. Disposal of WW II mustard gas hydrolysate by burning. Proc Annu Meet Air Pollut Control Assoc 70:1–11.
*CWC. 1993. Chemical Weapons Convention Treaty. http://www.cwc.gov/treaty/cwcIndex_html. August 22, 2003.
*Dabney BJ. 1991. Mustard gas MEDITEXT medical management. In: Hall AH, Rumack BH, eds. TOMES Plus Information System Micromedex, Inc., Denver, CO.
Dabrowska MI, Becks LL, Lelli JL, . 1996. Sulfur mustard induces apoptosis and necrosis in endothelial cells. Toxicol Appl Pharmacol 141:568–583.8975783
Dachir S, Fishbeine E, Meshulam Y, . 2002. Potential anti-inflammatory treatments against cutaneous sulfur mustard injury using the mouse ear vesicant model. Hum Exp Toxicol 21:197–203.12099621
*Dacre JC. 1994. Hazard evaluation of army compounds in the environment. Drug Metab Rev 26:649–662.7875059
*Dacre JC, Goldman M. 1996. Toxicology and pharmacology of the chemical warfare agent sulfur mustard. Pharmacol Rev 48(2):289–326.8804107
*Dacre JC, Beers R, Goldman M, . 1995. Toxicology and pharmacology of the chemical warfare agent sulfur mustard - A review. Govt Reports Announcements & Index. No. 23. ADA294927.
*D’Agostino PA, Provost LR. 1988a. Capillary column isobutane chemical ionization mass spectrometry of mustard and related compounds. Biomed Environ Mass Spectrom 15:553–564.3408824
*D’Agostino PA, Provost LR. 1988b. Gas chromatographic retention indices of sulfur vesicants and related compounds. J Chromatogr 436:399–411.3360883
*D’Agostino PA, Provost LR. 1992. Determination of chemical warfare agents, their hydrolysis products and related compounds in soil. J Chromatogr 589:287–294.
*D’Agostino PA, Provost LR, Hansen AS, . 1989. Identification of mustard related compounds in aqueous samples by gas chromatography/mass spectrometry. Biomed Environ Mass Spectrom 18:484–491.
*Dahl H, Gluud B, Vangsted P, . 1985. Eye lesions induced by mustard gas. Acta Ophthalmol [Suppl] (Copenh) 173:30–31.
Dangi RS, Jeevaratnam K, Sugendran K, . 1994. Solid-phase extraction and reversed-phase high-performance liquid chromatographic determination of sulphur mustard in blood. J Chromatogr 661:341–345.
*Dannenberg AM, Tsuruta J. 1993. Role of cytokines and reactive oxygen intermediates in the inflammatory response produced by sulfur mustard. A progress report. In: Proceedings of the medical defense bioscience review (1993) held in Baltimore, Maryland on 10-13 May 1993. Vol. 1. Springfield, VA: US Department of Commerce, 58–65.
Dannenberg AM Jr, Pula PJ, Liu LH, . 1985. Inflammatory mediators and modulators released in organ culture from rabbit skin lesions produced in vivo by sulfur mustard: I. Quantitative histopathology, polymorphonuclear leukocyte, basophil, and mononuclear cell survival, and unbound (serum) protein content. Am J Pathol 121:15–27.4050973
Davis KG, Aspera G. 2001. Exposure to liquid sulfur mustard. Ann Emerg Med 37(6):653–656.11385337
*Davison C, Rozman RS, Smith PK. 1961. Metabolism of bis-B-chloroethyl sulfide. Biochem Pharmacol 7:65–74.13720264
Demek MM, Davis GT, Dennis WH Jr, . 1970. Behavior of chemical agents in seawater. Edgewood Arsenal, MD: Department of the Army Edgewood Arsenal. AD873242.
*Detheux M, Jijakli H, Lison D. 1997. Effect of sulphur mustard on the expression of urokinase in cultured 3T3 fibroblasts. Arch Toxicol 71:243–249.9101041
De Young LM, Mufson RA, Boutwell RK. 1977. An apparent inactivation of initiated cells by the potent inhibitor of two-stage mouse skin tumorigenesis, bis(2-chloroethyl)sulfide. Cancer Res 37:4590–4594.200356
*D’Halluin F, Roels H. 1984. Autopsy observations in an Iranian soldier exposed to war gases. Arch Belges (Suppl):284–290.
*DHHS. 1988. Final recommendations for protecting the health and safety against potential adverse effects of long-term exposure to low doses of agents: GA, GB, VX, mustard agent (H, HD, T), and lewisite (L). Fed Regist 53(50):8504–8507.
DOA. 1985. Protection against the acute and delayed toxicity of mustards and mustard-like compounds: Annual report. Frederick, MD: U.S. Army Medical Research and Development Command, Department of the Army. AD-A182 468.
*DOA. 1987. Teratology studies of lewisite and sulfur mustard agents: Effects of sulfur mustard in rats and rabbits: Final Report: Frederick, MD: U.S. Army Medical Research and Development Command, Department of the Army. AD-A187 495.
*DOA. 1988. Chemical stockpile disposal program: Final programmatic environmental impact statement. Aberdeen Proving Ground, MD: Department of the Army V–IX, 1–6.
DOA. 1989. Toxicology studies on lewisite and sulfur mustard agents: Subchronic toxicity study on lewisite in rats: Final report. Frederick, MD: U.S. Army Medical Research and Development Command, Department of the Army. ADA217886.
DOA. 1994a. Environmental chemistry and fate of chemical warfare agents: Draft: Final report. San Antonio, TX: Corps of Engineers. Huntsville Division. Department of the Army. SwRI Project 01–5864.
DOA. 1994b. Mechanism of cutaneous vesication. Frederick, MD: U.S. Army Medical Research, Development, Acquisition and Logistics Command, Department of the Army. ADA283085.
DOA. 1995. Host factors contributing to disability following sulfur mustard exposure. Frederick, MD: U.S. Army Medical Research and Material Command, Department of the Army. ADA294497.
*DOA. 1996. Health risk assessment for sulfur mustard (HD): draft report. Oak Ridge, TN: U.S. Army Environmental Center, Department of the Army. 1769-1769-A1.
DOA. 1998. Characterization and modulation of proteins involved in sulfur mustard vesication. Frederick, MD: U.S. Army Medical Research and Material Command, Department of the Army. ADA366 664.
*DOA. 2000. Anniston chemical agent disposal facility. Department of the Army. http://www.pmcd.apgea.army.mil/CSDP/IP/FS/QF/ANCA/index.asp. March 8, 2001.
*DOA. 2003. News release. Mustard leak detected at Deseret Chemical Depot. U.S. Department of the Army. http://www.pmcd.army.mil/. August 27, 2003.
*DOD. 2003. Blue Grass Army Depot, Kentucky. Chemical weapons disposal in Kentucky. U.S. Department of Defense. http://www.pmacwa.army.mil/ky/cw_disposal_Ky.htm. August 27, 2003.
*Doebler JA. 2002. Blockade of sulfur mustard cytotoxicity in vitro. U.S. Army Medical Research Institute of Chemical Defense, Neurotoxicology Branch, Pharmacology Division. Aberdeen Proving Ground, MD.
*DOS. 2001. International traffic in arms. United States munitions list. Chemical agents. U.S. Department of State. Code of Federal Regulations. 22 CFR 121.7. http://ecfr.access.gpo.gov/otcgi/cfr/otfilter.cgi…TI&QUERY=1682&RGN=BSECCT&SUBSET=SUBSE T&FROM=1&ITEM=1. May 24, 2001.
*DOT. 2001. Hazardous materials table. U.S. Department of Transportation. Code of Federal Regulations. 49 CFR 172.101. http://ecfr.access.gpo.gov/otcgi/cfr/otfilter.cgi?DB=…I&QUERY=971312&RGN=BSECCT&SUBSET=S UBSET&FROM=1&ITEM=1. May 24, 2001.
Dowlati A, Pierard GE. 1993. Epidermal hyperplasia with or without atypia in patients exposed to mustard gas. Arch Dermatol 129:245.8434986
*Drasch G, Kretschmer E, Pahrm M, . 1987. Concentrations of mustard gas bis-2-chloroethylsulfide in the tissue of a victim of a vesicant exposure. J Forensic Sci 32:1788–1793.3430139
*Dreisbach RH, Robertson WO. 1987. Handbook of poisoning: Prevention, diagnosis and treatment. 12^th^ ed. Norwalk, CT: Appleton and Lange.
*DTIC. 2002. DTIC research summaries. Defense Technical Information Center. Ft. Belvoir, VA. October 22, 2002.
Dube SN, Husain K, Sugendran K, . 1998. Dose response of sulphur mustard: Behavioral and toxic signs in rats. Indian J Physiol Pharmacol 42(3):389–394.9741654
Dumez H, Guetens G, De Boeck G, . 2001. Quantitation of suspensions (MESED). Application of MESED-GC/MS in the quantitation of ifosfamide mustard in erythrocytes, plasma, and plasma water. J Sep Sci 24(2):123–128.
*Easton DF, Peto J, Doll R. 1988. Cancers of the respiratory tract in mustard gas workers. Br J Ind Med 45:652–659.3196660
Ebtekar M, Hassan ZM. 1993. Effect of immunomodulators pyrimethamine and cimetidine on immunosuppression induced by sulfur mustard in mice. Immunopharmacology 15(4):533–541.
*Eisenmenger W, Drasch G, von Clarmann M, . 1991. Clinical and morphological findings on mustard gas [bis(2-chloroethyl)sulfide] poisoning. J Forensic Sci 36(6):1688–1698.1770337
*Eldad A, Meir PB, Breiterman S, . 1998a. Superoxide dismutase (SOD) for mustard gas burns. Burns 24:114–119.9625234
*Eldad A, Weinberg A, Breiterman S, . 1998b. Early nonsurgical removal of chemically injured tissue enhances wound healing in partial thickness burns. Burns 24:166–172.9625245
*Ellenhorn MJ, Barceloux DG. 1988. Medical toxicology. New York, NY: Elsevier Science Publishing Company.
*Emad A, Rezaian GR. 1997. The diversity of the effects of sulfur mustard gas inhalation on respiratory system 10 years after a single, heavy exposure. Analysis of 197 cases. Chest 112(3):734–738.9315808
Emad A, Rezaian GR. 1999a. Characteristics of broncho alveolar lavage fluid in patients with sulfur mustard gas-induced asthma or chronic bronchitis. Am J Med 106:625–628.10378619
Emad A, Rezaian GR. 1999b. Immunoglobulins and cellular constituents of the BAL fluid of patients with sulfur mustard gas-induced pulmonary fibrosis. Chest 115:1346–1351.10334151
Emison ES, Smith WJ. 1997. Cytometric analysis of DNA damage in cultured human epithelial cells after exposure to sulfur mustard. J Am Coll Toxicol 15:S9–S18.
English F, Brisbane WT, Bennett Y. 1990. The challenge of mustard-gas keratopathy. Med J Aust 152:55–56.
EPA. 1987a. US Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355, Appendix A.
EPA. 1987b. US Environmental Protection Agency. Fed Regist 52:21152.
EPA. 1987c. Recommendations for and documentation of biological values for use in risk assessment. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office. EPA ECAO-CIN-554.
EPA. 1988. US Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, Appendix VIII.
EPA. 1989. Interim methods for development of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA888066F.
*EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066A.
EPA. 1991. Upper-bound quantitative cancer risk estimate for populations adjacent to sulfur mustard incineration facilities. Washington, DC: Human Health Assessment Group, Office of Health and Environmental Assessment, Office of Research and Development. U.S. Environmental Protection Agency. EPA600891053.
EPA. 1994. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066F.
*EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
*EPA. 2001a. Health and environmental protection standards. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 192. http://esweb.bna.com/cgi-bin/om_isa…tID=109873&softpage=es_menu_fedral. February 22, 2001.
*EPA. 2001b. Identification and listing of hazardous waste. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261. http://esweb.bna.com/cgibin/om_isa…tID=109873&softpage=es_menu_fedral. February 22, 2001.
*EPA. 2001c. Reportable quantities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355. http://esweb.bna.com/cgibin/om_isa…tID=109873&softpage=es_menu_fedral. February 22, 2001.
*EPA. 2001d. Toxic chemical release reporting community right-to-know. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. http://esweb.bna.com/cgibin/om_isa…tID=109873&softpage=es_menu_fedral. February 22, 2001.
*Epstein J, Rosenblatt DH, Gallacio A, . 1973. Summary report on a data base for predicting consequences of chemical disposal operation. ADB955399.
Epstein SS, Arnold E, Andrea J, . 1972. Detection of chemical mutagens: Dominant lethal assay in the mouse. Toxicol Appl Pharmacol 23:288–325.5074577
*Fahmy OG, Fahmy MJ. 1971. Mutability at specific euchromatic and heterochromatic loci with alkylating and nitroso compounds in Drosophila melanogaster. Mutat Res 13:19–34.4999910
*Fahmy OG, Fahmy MJ. 1972. Mutagenic selectivity for the RNA-forming genes in relation to the carcinogenicity of alkylating agents and polycyclic aromatics. Cancer Res 32:550–557.4110704
*Fan L, Bernstein IA. 1991. Effect of bis(β-chloroethhyl)sulfide (BCES) on base mismatch repair of DNA in monkey kidney cells. Toxicol Appl Pharmacol 111:233–241.1957309
*FEDRIP. 2002. Federal Research In Progress Database. National Technical Information Service, Springfield, VA.
Ferguson LR, Turner PM. 1988. Mitotic crossing-over by anti-cancer drugs in Saccharomyces cerevisiae strain D5. Mutat Res 204:239–250.3278216
*Fidder A, Moes GWH, Scheffer AG, . 1994. Synthesis, characterization, and quantization of the major adducts formed between sulfur mustard and DNA of calf thymus and human blood. Chem Res Toxicol 7:199–204.8199309
*Fidder A, Noort D, de Jong AL, . 1996a. Monitoring of in vitro and in vivo exposure to sulfur mustard by GC/MS determination of the N-terminal valine adduct in hemoglobin after a modified edman degradation. Chem Res Toxicol 9:788–792.8831824
*Fidder A, Noort D, de Jong LPA, . 1996b. N7-(2-hydroxyethylthioethyl)-guanine: A novel urinary metabolite following exposure to sulphur mustard. Arch Toxicol 70:854–855.8911645
Firooz A, Komeile A, Dowlati Y. 1999. Eruptive melanocytic nevi and cherry angiomas secondary to exposure to sulfur mustard gas. J Am Acad Dermatol 40(4):646–647.10188695
*Fisher TL, Jaskot M, Sass S. 1969. Trace estimation and differentiation of some mustards employing gas-liquid chromatography. Edgewood Arsenal technical report. Edgewood Arsenal, Maryland: Department of the Army, Edgewood Arsenal, Research Laboratories, Chemical Research Laboratory. EATR 4321.
*Fomon SJ. 1966. Body composition of the infant: Part I: The male “reference infant.” In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
*Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Foussereau J, Benezra C, Maibach HI, . 1982. Occupational contact dermatitis, clinical and chemical aspects. Philadelphia, PA: W.B. Saunders Company, 171–176.
*Fowler WK, Smith JE. 1990. Solid sorbent collection and gas chromatographic determination of bis(2-chloroethyl)sulfide in air at trace concentrations. J Chromatogr Sci 28:118–122.2273065
Fox M, Scott D. 1980. The genetic toxicology of nitrogen and sulfur mustard. Mutat Res 75:131–168.6988708
Frank AL. 1982. The epidemiology and etiology of lung cancer. Clin Chest Med 3:219–228.7047057
Frank AL. 1987. Occupational cancers of the respiratory system. Seminars in Occupational Medicine 2:257–266.
*Franke S. 1967. [Textbook of military chemistry.] Vol. I, 2^nd^ ed. Berlin, West Germany: Military Publisher of the German Democratic Republic. (German-English translation by the U.S. Army Medical Intelligence and Information Agency), 114–122, 132–133, 168–178.
*Freitag L, Firusian N, Stamatis G, . 1991. The role of bronchoscopy in pulmonary complications due to mustard gas inhalation. Chest 100:1436–1441.1935306
*Friedberg K, Mengel K, Schlick E. 1983. The action of azimexone on the cells of the hempopietic system in mice, especially after the damage with x-rays. Radiation and Environ Biophy 22:117–131.
Friedenwald JS, Buschke W. 1948. Nuclear fragmentation produced by mustard and nitrogen mustards in the corneal epithelium. Bull Johns Hopkins Hosp 82:161–177.18899056
Friedenwald JS, Scholz RO, Snell Jr A, . 1948. Primary reaction of mustard with the corneal epithelium. Bull Johns Hopkins Hosp 82:102–120.18899053
Fritsche U, Koenig A. 1982. [Luminometric determination of S-lost with sodium hypobromite.] Mikrochim Acta 1:349. (German)
*Gates M, Moore S. 1946. Mustard gas and other sulfur mustards. In: Chemical warfare agents, and related chemical problems, Parts I-II. Summary technical report of Division 9, NDRC, Volume 1, Chapter 5, 30–58.
Gaylor DW, Gold LS. 1995. Quick estimate of the regulatory virtually safe dose based on the maximum tolerated dose for rodent bioassays. Regul Toxicol Pharmacol 22:57–63.7494904
Geeraets WJ, Abedi S, Blanke RV. 1977. Acute corneal injury by mustard gas. South Med J 70(3):348–350.847488
Ghanei M, Vosoghi AA. 2002. An epidemiologic study to screen for chronic myelocytic leukemia in war victims exposed to mustard gas. Environ Health Perspect 110(5):519–521.12003756
Ghotbi L, Hassan Z. 2002. The immunostatus of natural killer cells in people exposed to sulfur mustard. Int Immunopharm 2:981–985.
*Gibson NCC, Casselman AA, Bannard RAB. 1974. An improved gas-liquid chromatographic method for the analysis of bis(2-chloroethyl) sulfide collected from air by solvent entrapment. J Chromatogr 92:162–165.
Gilbert RM, Rowland S, Davison CL, . 1975. Involvement of separate pathways in the repair of mutational and lethal lesions induced by a mono-functional sulfur mustard. Mutat Res 28:257–276.166305
Gililland J, Weinstein L. 1983. The effects of cancer chemotherapeutic agents on the developing fetus. Obstet Gynecol Surv 38:6–13.6338427
Gilman MR. 1982. Skin and eye testing in animals. In: Hayes AW, ed. Principles and methods of toxicology. New York: Raven Press, 209–222.
*Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Gold MB, Scharf BA. 1995. Hematological profile of the euthymic hairless guinea pig following sulfur mustard vesicant exposure. J Appl Toxicol 15:433–438.8603929
Gold MB, Bongiovanni R, Scharf BA, . 1993. Hypochlorite solution as a decontaminant in sulfur mustard contaminated skin defects in the euthymic hairless guinea pig. In: Proceedings of the medical defense bioscience review (1993) held in Baltimore, Maryland on 10–13 May 1993. Vol. 1. Springfield, VA: US Department of Commerce, 369–378.
*Gold MB, Bongiovanni R, Scharf BA, . 1994. Hypochlorite solution as a decontaminant in sulfur mustard contaminated skin defects in the euthymic hairless guinea pig. Drug Chem Toxicol 17(4):499–527.7821235
*Goldfrank LR, Flomenbaum NE, Lewin NA, . 1990. Goldfrank’s toxicologic emergencies. 4^th^ ed. Norwalk, CT: Appleton and Lange.
Goldstein LS. 1984. Use of in vitro technique to detect mutations induced by antineoplastic drugs in mouse germ cells. Cancer Treat Rep 68:855–856.6547366
Gottschall EB. 2002. Occupational and environmental thoracic malignancies. J Thorac Imaging 17:189–197.12082370
*Graef I, Karnofsky DA, Jager VB, . 1948. The clinical and pathologic effects of the nitrogen and sulphur mustards in laboratory animals. Am J Pathol 24:1–47.18921345
*Graham JS, Bryant MA, Braue EH. 1994. Effect of sulfur mustard on mast cells in hairless guinea pig skin. J Toxicol Cutaneous Ocul Toxicol 13(1):47–54.
Graham JS, Schomacker KT, Glatter RD, . 2002. Bioengineering methods employed in the study of wound healing of sulphur mustard burns. Skin Res Tech 8:57–69.
Gray PJ. 1995. Sulphur mustards inhibit binding of transcription factor AP2 in vitro. Nucl Acids Res 23(21):4378–4382.7501459
Gray PJ, Phillips DR. 1993. Effect of alkylating agents on initiation and elongation of the lac UV5 promoter. Biochemistry 32:12471–12477.8241138
*Gresham GL, Groenewold GS, Appelhans AD, . 2001. Static secondary ionization mass spectrometry and mass spectrometry/mass spectrometry (MS^2^) characterization of the chemical warfare agent HD on soil particle surfaces. Int J Mass Spectrom 208:135–145.
Groenewold GS, Appelhans AD, Ingram JC, . 1998. Detection of 2-chloroethyl ethyl sulfide on soil particles using ion trap-secondary ion mass spectrometry. Talanta 47:981–986.18967402
*Groenewold GS, Ingram JC, Appelhans AD, . 1995. Detection of 2-chloroethyl ethyl sulfide and sulfonium ion degradation products on environmental surfaces using static SIMS. Environ Sci Technol 29:2107–2111.22191362
*Gross CL, Smith WJ. 1993. Pretreatment of isolated human peripheral blood lymphocytes with L-oxothiazolidine 4-carboxylate reduces sulfur mustard cytotoxicity. In: Proceedings of the medical defense bioscience review (1993) held in Baltimore, Maryland on 10-13 May 1993. Vol. 1. Springfield, VA: US Department of Commerce, 141–147.
*Guild WJF, Harrison KP, Fairley A, . 1941. The effect of mustard gas vapour on the eyes. Chemical Board, Physiological Sub-Committee and Panel of Ophthalmic Specialists. Porton Report No. 2297. Great Britain.
Guittin P, Schorch F, Fontaine J-J, . 1989. Experimental pathology induced in rat by a single skin application of mustard gas. Pathol Res Pract 185:68–69.
*Guzelian PS, Henry CJ, Olin SS. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
*Haddad LM, Winchester JF. 1990. Clinical management of poisoning and drug overdose. 2^nd^ ed. Philadelphia, PA: W.B. Saunders Company.
*Hambrook JL, Harrison JM, Howells DJ, . 1992. Biological fate of sulphur mustard (1,1’-thiobis(2-chloroethane)): Urinary and fecal excretion of ^35^S by rat after injection or cutaneous application of ^35^S-labeled sulphur mustard. Xenobiotica 22(1):65–75.1615709
*Hambrook JL, Howells DJ, Schock C. 1993. Biological fate of sulphur mustard (1,1’-thiobis(2-chloroethane)): Uptake, distribution and retention of ^35^S in skin and in blood after cutaneous application of ^35^S-sulphur mustard in rat and comparison with human blood in vitro. Xenobiotica 23(5):537–561.8342301
Hancock JR, McAndless JM, Hicken RP. 1991. A solid adsorbent based system for the sampling and analysis of organic compounds in air: An application to compounds of chemical defense interest. J Chromatogr Sci 29:40–45.
Hart BW, Schlager JJ. 1996. G2/M phase cell cycle block by sulfur mustard in normal human keratinocytes. Med Def Biosci Rev 2:835–843.
*Hart BW, Schlager JJ. 1997. Okadaic acid and calyculin a reverse sulfur mustard-induced G_2_/M cell-cycle block in human keratinocytes. J Am Coll Toxicol 15(Suppl. 2):S36–S42.
Hartmann HM. 2002. Evaluation of risk assessment guideline levels for the chemical warfare agents mustard, GB, and VX. Regul Toxicol Pharmacol 35:347–356.12202050
Harvey SP, Szafraniec LL, Beaudry WT. 1998a. Hydrolysis and biodegradation of the vesicant agent HT: two potential approaches. Biorem J 2(3&4):191–203.
Harvey SP, Szafraniek LL, Beaudry WT. 1998b. Neutralization and biodegradation of sulfur mustard. In: Bioremediation. Aberdeen Proving Ground, MD 21010-5423: U.S. Army Edgewood Research, Development and Engineering Center, 615–636.
Hassan ZM, Ebtekar M. 2001. Modeling for immunosupression by sulfur mustard. Int Immunopharm 1:605–610.
Hassan ZM, Ebtekar M. 2002. Immunological consequence of sulfur mustard exposure. Immunol Lett 83:151–152.12095704
Hay A. 1993. Effects on health of mustard gas. Nature 366:398–399.
*HazDat. 2003. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
Helmke B, Starz H, Bachter D, . 2002. Metastasising porocarcinoma following exposure to poison gas. Lancet 359(9318):1685.12020547
Hemminki K, Kallama S, Falck K. 1983. Correlations of alkylating activating and mutagenicity in bacteria of cytostatic drugs. Acta Pharmacol Toxicol 53:421–428.
Heston WE. 1950. Carcinogenic action of the mustards. J Natl Cancer Inst 11:415–423.14795195
*Heston WE. 1953a. Occurrence of tumors in mice injected subcutaneously with sulfur mustard and nitrogen mustard. J Natl Cancer Inst 14:131–140.13097144
*Heston WE. 1953b. Pulmonary tumors in Strain A mice exposed to mustard gas. Proceedings of the Society for Experimental Biology and Medicine 82:457–460.13047431
*Heully F, Gruinger M, . 1956. [Collective intoxication caused by the explosion of a mustard gas shell.] Annales de Medecine Legale 36:195–204. (French)
*Heyndrickx A, Heyndrickx B. 1984. Treatment of Iranian soldiers attacked by chemical and microbiological war gases. Arch Belges (Supplement):S157–S159.
*Hobson DW, Snider TH, Korte DW. 1993. Evaluation of the effects of hypochlorite solutions in the decontamination of wounds exposed to either VX or sulfur mustard. Columbus, OH: Battelle Memorial Institute.
*Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
Hooijschuur EWJ, Keintz CE, Brinkman UAT. 1999. Determination of the sulfur mustard hydrolysis product thiodiglycol by microcolumn liquid chromatography coupled on-line with sulfur flame photometric detection using large-volume injections and peak compression. J Chromatogr 849:433–444.
*Hooijschuur EWJ, Kientz CE, Brinkman UAT. 2001. Application of microcolumn liquid chromatography and capillary electrophoresis with flame photometric detection for the screening of degradation products of chemical warfare agents in water and soil. J Chromatogr A 928:187–199.11587337
Hopkins AR, Lewis NS. 2001. Detection and classification characteristics of arrays of carbon black/organic polymer composite chemiresistive vapor detectors for the nerve agent simulants dimethylphophonate and diisopropylmethylphosponate. Anal Chem 73:884–892.11289432
Horwitz EP, Dietz ML, Fisher DE. 1991. Separation and preconcentration of strontium from biological, environmental, and nuclear waste samples by extraction chromatography using a crown ether. Anal Chem 63:522–525.1829590
*Hosseini K, Moradi A, Mansouri A, . 1989. Pulmonary manifestations of mustard gas injury: a review of 61 cases. Iran J Med Sci 14(2):20–26.
*HSDB. 2002. Hazardous Substances Data Bank. National library of Medicine, National Toxicology Information Program, Bethesda, MD.
Hu J, Mao Y, White K, . 2002. Renal cell carcinoma and occupational exposure to chemicals in Canada. Occup Med 52(3):157–164.
Hua A, Daniel R, Jasseron MP, . 1993. Early cytotoxic effects induced by Bis-chloroethyl sulphide (sulphur mustard): Ca^2^ rise and time-dependent inhibition of B77 fibroblast serum response. J Appl Toxicol 13(3):161–168.8326084
*Hughes WF Jr. 1942. Mustard gas injuries to the eyes. Arch Ophthamol 27:582–601.
Hughes WF Jr. 1945. The importance of mustard burns of the eye as judged by World War I statistics and recent accidents. In: National Research Council, Division of Medical Sciences, Committee on Treatment of Gas Casualties. Fasciculus on chemical warfare medicine. Vol. 1, Eye. Washington, DC: Prepared for the Committee on Medical Research of the Office of Scientific Research and Development, 79–90.
Hur GH, Kim YB, Choi DS, . 1998. Apoptosis as a mechanism of 2-chloroethylethyl sulfide-induced cytotoxicity. Chem Biol Interact 110:57–70.9566725
*Husain K, Dube SN, Sugendran K, . 1996. Effect of topically applied sulphur mustard on antioxidant enzymes in blood cells and body tissues of rats. J Appl Toxicol 16:245–248.8818865
*IARC. 1975. Mustard gas. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans. International Agency for Research on Cancer. 9:181–207.
*IARC. 1987. IARC monographs on the evaluation of carcinogenic risks to humans. Overall evaluations of carcinogenicity: International Agency for Research on Cancer. An updating of IARC monographs, Volumes 1 to 42, Supplement 7:67.
*IARC. 2001. IARC monographs on the evaluation of carcinogenic risks to humans. International Agency for Research on Cancer. http://www.iarc.fr/pageroot/top1.html. February 22, 2001.
*Ichinotsubo D, Mower HF, Setliff J, . 1977. The use of rec- bacteria for testing of carcinogenic substances. Mutat Res 46:53–61.327303
*Inada S, Hiragun K, Seo K, . 1978. Multiple Bowens disease observed in former workers of a poison gas factory in Japan with special reference to mustard gas exposure. J Dermatol 5:49–60.353106
*IRIS. 2003. Mustard gas. Integrated Risk Information System. U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/index.htm. January 28, 2003.
Jackson R, Adams RH. 1973. Horrifying basal cell carcinoma: A study of 33 cases and a comparison with 435 nonhorror cases and a report on 4 metastatic cases. J Surg Oncol 5:431–463.4752463
*Jakubowski EM, Sidell FR, Evans RA, . 2000. Quantification of thiodiglycol in human urine after an accidental sulfur mustard exposure. Toxicol Meth 10:143–150.
*Jakubowski EM, Woodard CL, Mershon MM, . 1990. Quantification of thiodiglycol in urine by electron ionization gas chromatography-mass spectrometry. J Chromatogr 528:184–190.2384552
*Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
*Johnsen BA, Blanch JH. 1984. Analysis of snow samples contaminated with chemical warfare agents. Proceedings of the First World Congress, Med Soc Hyg Chem Warfare Toxicol Eval Pt 22:22–30.
*Johnson MA. 1998. Written communication (July 21, 1999) to Nancy Crowe, Bureau of Export Administration, Regulatory Policy Division, Office of Exporter Services, regarding proposed chemical weapons convention regulations. Fed Regist 64:39194.
*Jorgenson B, Olesen B, Berntsen O. 1985. [Accidents with mustard gas near Bornholm.] Ugeskrift for Laeger 147:2251–2254. (Dutch)4060287
Jones TD, Walsh PJ, Watson AP, . 1988. Chemical scoring by a rapid screening of hazard (RASH) method. Risk Anal 8(1):99–118.3375507
Ju Fang W. 1984. Biological detection of chemical warfare agents. Arch Belg Med Soc Hyg Med Trav Med Leg Suppl:74–80.
Kadar T, Turetz J, Fishbine E, . 2001. Characterization of acute and delayed ocular lesions induced by sulfur mustard in rabbits. Curr Eye Res 22(1):42–53.11402378
Kam CM, Selzler J, Schulz SM, . 1997. Enhanced serine protease activities in the sulfur mustard-exposed homogenates of hairless guinea pig skin. Int J Toxicol 16:625–638.
Karaer F. 1996. Environmental pollution and carcinogenic risk. J Environ Pathol Toxicol Oncol 15(2–4):105–113.9216793
Karlsson JO, Nguyen NV, Foland LD, . 1985. (2-Alkynylethenyl)ketenes: A new benzoquinone synthesis. J Am Chem Soc 107:3392–3393.
Khordagui HK. 1995. Fate and control of nerve chemical warfare agents in the desalination industry of the Arabian-Persian Gulf. Environ Int 21(4):363–379.
Khordagui H, Al-Ajimi D. 1994. Potential fate of blistering chemical warfare agents in the coastal waters of kuwait. J Environ Sci Health A 29:687–700.
*Kientz CE. 1998. Chromatography and mass spectrometry of chemical warfare agents, toxins and related compounds: State of the art and future prospects. J Chromatogr 814:1–23.
*Kindred JE. 1947. Histological changes occurring in the hemopoietic organs of albino rats after single injections of 2-chloroethyl vesicants: A quantitative study. Arch of Path 43:253–295.
*Kircher M, Brendel M. 1983. DNA alkylation by mustard gas in yeast Saccharomyces-cerevisiae strains of different repair capacity. Chem-Biol Interact 44:27–39.6342826
Kjellstrom BT, Persson JKE, Runn P. 1997. Surgical treatment of skin lesions induced by sulfur mustard (“mustard gas”)-An experimental study in the guinea pig. Ann Acad Med Singapore 26:30–36.9140575
*Klain GJ, Omaye ST, Schuschereba ST, . 1991. Ocular toxicity of systemic and topical exposure to butyl 2-chloroethyl sulfide. J Toxicol Cutaneous Ocul Toxicol 10(4):289–302.
*Klehr N. 1984. [Cutaneous late manifestations in former mustard gas workers]. Z Hautkr 59:1161–1170. (German)6237506
Koepke SR, Kroeger-Koepke MB, Bosan W, . 1988. Alkylation of DNA in rats by N-nitrosomethyl-(2-hydroxyethyl)amine: Dose response and persistence of the alkylated lesions in vivo. Cancer Res 48:1537–1542.3345527
*Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
*Koper O, Lucas E, Klabunde KJ. 1999. Development of reactive topical skin protectants against sulfur mustard and nerve agents. J Appl Toxicol 19:S59–S70.10594903
Kosson. 2000. Obstacles to closure of the Johnston atoll chemical agent disposal system. http://www.4.nationalacademies.org/cets/dmst.nsf. May 4, 2000.
*Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3^rd^ ed. New York, NY: Raven Press, Ltd., 149–188.
*Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kroes R, Galli C, Munro I, . 2000. Threshold of toxicological concern for chemical substances present in the diet: A practical tool for assessing the need for toxicity testing. Food Chem Toxicol 38:255–312.
Kumar O, Vijayaraghavan R. 1997. Effect on physiological variables & urinary metabolites following a single dermal application of sulphur mustard in rats. Def Sci J 47(3):389–394.
*Kumar O, Vijayaraghavan R. 1998. Effect of sulphur mustard inhalation exposure on some urinary variables in mice. J Appl Toxicol 18:257–259.9719425
Kumar O, Sugendran K, Vijayaraghavan R. 2001. Protective effect of various antioxidants on the toxicity of sulphur mustard administered to mice by inhalation or percutaneous routes. Chem Biol Interact 134:1–12.11248218
*Kumar P, Sharma US, Vijayaraghavan R. 1991. Study of the efficacy of CC-2 and Fuller’s Earth Combination as a decontaminant against sulphur mustard (Mustard Gas) dermal intoxication in mice. Def Sci J 41(4):363–366.
Kumar P, Vijayaraghavan R, Kulkarni AS, . 2002. In vivo protection by amifostine and DRDE-07 against sulphur mustard toxicity. Hum Exp Toxicol 21:371–376.12269699
Kuperman R, Dunn C. 1994. Ecological effects of soil contamination at Aberdeen Proving Ground, Maryland. Bull Ecol Soc Am 75(1):118–119.
*Kurata H. 1980. Lessons learned from the destruction of the chemical weapons of the Japanese Imperial Forces. In: Stockholm International Peace Research Institute. Chemical weapons: Destruction and conversion. London: Taylor and Francis, 77–93.
Kurozumi S, Haradi Y, Sugimoto Y, . 1977. Airway malignancy in poisonous gas workers. J Laryngol Otol 91:217–226.850101
*Kurt E, Schafer RJ, Arroyo CM. 1998. Effects of sulfur mustard on cytokines released from cultured human epidermal keratinocytes. Int J Toxicol 17:223–229.
Kurt EM, Schafer RJ, Broomfield CA, . 1997. Immunologic cytokine expression in human keratinocytes after exposure to sulfur mustard. J Am Coll Toxicol 15(Suppl. 2):S32–S35.
*Kwong CD, Segers DP. 1996. Antivesication by simultaneous prophylaxis and detoxification. Govt Reports Announcements & Index. ADA230926.
Lal J, Kumar V, Gupta RC. 2002. LC determination of a sulphur mustard decontaminant CC-2 in rat serum. J Pharm Biomed Anal 29:609–615.12093489
*Langenberg JP, van der Schans GP, Spruit HET, . 1998. Toxicokinetics of sulfur mustard and its DNA-adducts in the hairless guinea pig. Drug Chem Toxicol 21(Suppl. 1):131–147.10028407
Lardot C, Dubois V, Lison D. 1999. Sulfur mustard upregulates the expression of interleukin-8 in cultured human keratinocytes. Toxicol Lett 110:29–33.10593592
*Laughlin RC. 1944a. Correlation of eye changes in rabbits with CT exposure to HD. MRL (EA) Report No. 23.
*Laughlin RC. 1944b. Continued exposure of human eyes to H vapor, MIT subjects. MRL (EA) Report No. 9.
*Laughlin RC. 1944c. Eye examination of factory workers handling H, CN and CG. MRL (EA) Report 18.
Lawley PD, Brookes P. 1965. Molecular mechanism of the cytotoxic action of difunctional alkylating agents and of resistance to this action. Nature 206:480–483.5319105
*Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Lefkowitz LJ, Smith WJ. 2002. Sulfur mustard-induced arachidonic acid release is mediated by phospholipase D in human keratinocytes. Biochem Biophys Res Commun 295:1062–1067.12135602
Leggett DC. 1987. Persistence of chemical agents on the winter battlefield. Part 1. Literature review and theoretical evaluation. Defense Technical Information Center, U.S. Army Cold Regions Res Eng Lab: CRREL Report # 87–12.
Lemen RA. 1986. Occupationally induced lung cancer epidemiology. Occup Respir Dis 629–656.
*Leung H-W. 1993. Physiologically-based pharmacokinetic modeling. In: Ballentine B, Marro T, Turner P, eds. General and applied toxicology. Vol. 1. New York NY: Stockton Press, 153–164.
*Lüning KG. 1952. Studies on the origin of apparent gene mutations in Drosophila melanogaster. Acta Zool 33:193.
Lewis DFV, Bird MG, Jacobs MN. 2002. Human carcinogens: An evaluation study via the COMPACT and Hazard Expert procedures. Hum Exp Toxicol 21:115–122.12102536
Li Q, Laval J, Lundlum DB. 1997. Fpg protein releases a ring-opened N-7 guanine adduct from DNA that has been modified by sulfur mustard. Carcinogenesis 18(5):1035–1038.9163692
Lieske C, Gross C. 1992. Reply from the authors. Immunol Lett 34(2):175–176.
Lieske C, Klopcic R, Gross C, . 1992. Development of an antibody that binds sulfur mustard. Immunol Lett 31:117–122.1740349
*Lin P, Bernstein IA, Vaughan FL. 1994. Failure to observe a relationship between bis-(β-chloroethyl) sulfide-induced NAD depletion and cytotoxicity in the rat keratinocyte culture. J Toxicol Environ Health 42:393–405.8051714
*Lin P, Bernstein IA, Vaughan FL. 1996a. Bis(2-chloroethyl)sulfide (BCES) disturbs the progression of rat keratinocytes through the cell cycle. Toxicol Lett 84:23–32.8597174
*Lin P, Vaughan FL, Bernstein IA. 1996b. Formation of interstrand DNA cross-links by bis-(2-chloro-ethyl)sulfide (BCES): A possible cytotoxic mechanism in rat keratinocytes. Biochem Biophys Res Commun 218:556–561.8561795
Lindsay C, Rice P. 1995. Changes in connective tissue macromolecular components of Yucatan mini-pig skin following the application of sulfur mustard vapor. Hum Exp Toxicol 14:341–348.7598994
Lindsay CD, Hambrook JL. 1997. Protection of A549 cells against the toxic effects of sulphur mustard by hexamethylenetetramine. Hum Exp Toxicol 16:106–114.9051415
Lindsay CD, Hambrook JL. 1998. Diisopropylglutathione ester protects A549 cells from the cytotoxic effects of sulphur mustard. Hum Exp Toxicol 17:606–612.9865417
Lindsay CD, Upshall DG. 1995. The generation of a human dermal equivalent to assess the potential contribution of human dermal fibroblasts to the sulphur mustard-induced vesication response. Hum Exp Toxicol 14:580–586.7576818
Lindsay CD, Hambrook JL, Lailey AF. 1997. Monoisopropylglutathione ester protects A549 cells from the cytotoxic effects of sulphur mustard. Hum Exp Toxicol 16:636–644.9426364
Lindsay CD, Hambrook JL, Smith CN, . 1996. Histological assessment of the effects of the percutaneous exposure of sulfur mustard in an in vitro human skin system and the therapeutic properties of the protease inhibitors. Med Def Biosci Rev 2:899–908.
*Liu DK, Wannemacher RW, Snider TH, . 1999. Efficacy of the topical skin protectant in advanced development. J Appl Toxicol 19:S41–S45.
*Livingston, AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
Lodhi IJ, Sweeney JF, Clift RE, . 2001. Nuclear dependence of sulfur mustard-mediated cell death. Toxicol Appl Pharmacol 170:69–77.11141358
Logan TP, Millard CB, Shutz M, . 1999. Cutaneous uptake of ^14^C-HD vapor by the hairless guinea pig. Drug Chem Toxicol 22(2):375–387.10234473
Lohs K. 1975. Delayed toxic effects of chemical warfare agents. Stockholm International Peace Research Institute Monograph. Stockholm: Almqvist & Wilksell International.
*Ludlum DB, Austin-Ritchie P, Hagopian M, . 1994. Detection of sulfur mustard-induced DNA modifications. Chem Biol Interact 91:39–49.8194124
Lundy PM, Sawyer TW, Hand BT, . 1998. Effects of bis(2-chloroethyl)sulfide on ATP receptor-mediated responses of the rat vas deferens: Possible relationship to cytotoxicity. J Pharmacol Exp Ther 285(1):299–306.9536025
*Lyman WJ, Reehl WF, Rosenblatt DH. 1990. Handbook of chemical property estimation methods. 2^nd^ ed. Washington, DC: American Chemical Society.
*MacNaughton, MG. 2001. Monitoring information for sulfur mustard. Southwest Research Institute.
*Maisonneuve A, Callebat I, Debordes L, . 1993. Biological fate of sulphur mustard in rat: Toxicokinetics and disposition. Xenobiotica 23(7):771–780.8237059
*Maisonneuve A, Callebat I, Debordes L, . 1994. Distribution of [^4^C]sulfur mustard in rats after intravenous exposure. Toxicol Appl Pharmacol 125:281–287.8171436
*Mandl H, Freilinger G. 1984. First report on victims of chemical warfare in the Gulf War treated in Vienna. Arch Belges (Supplement):330–340.
*Mann I. 1944. A study of eighty-four cases of delayed mustard gas keratitis fitted with contact lenses. Br J Ophthal 28:441–447.18170043
*Mann I, Pullinger BD. 1944. A study of mustard gas lesions on the eyes of rabbits and men. Am J Ophthmol 26:1253–1277.
*Manning KP, Skegg DCG, Stell PM, . 1981. Cancer of the larynx and other occupational hazards of mustard gas workers. Clin Otolaryngol 6:165–170.7261452
*Marrs TC, Maynard RL, Sidell FR. 1996. Chemical warfare agents. John Wiley & Sons, New York.
Martens ME. 1997. In vitro studies of glucose metabolism in human epidermal keratinocytes exposed to sulfur mustard. J Am Coll Toxicol 15(Suppl. 2):S19–S31.
*Martens ME, Smith WJ. 1993. Mechanisms of sulfur mustard-induced metabolic injury. FASEB J 8(3):A408.
Marzulli FN, Simmon ME. 1971. Eye irritation from topically applied drugs and cosmetics: preclinical studies. Am J Ophthalmol 48:61–79.
*Masta A, Gray PJ, Phillips DR. 1996. Effect of sulphur mustard on the initiation and elongation of transcription. Carcinogenesis 17(3):525–532.8631139
Matijasevic Z, Precopio ML, Snyder JE, . 2001. Repair of sulfur mustard-induced DNA damage in mammalian cells measured by a host cell reactivation assay. Carcinogenesis 22(4):661–664.11285203
*Matijasevic Z, Stering A, Ludlum DB. 1996. Toxicity of sulfur mustard for human fibroblasts grown in cell culture. Med Def Biosci Rev 2:635–50.
*Maumenee AE, Scholz RO. 1948. The histopathology of the ocular lesions produced by sulfur and nitrogen mustards. Bull John Hopkins Hosp 82:121–147.18899054
Maurice DM, Giardini AA. 1951. A simple optical apparatus for measuring the corneal thickness, and the average thickness of the human cornea. Br J Ophthalmol 35:169–177.14821293
*May WG. 1998. Effluents from alternative demilitarization technologies. Netherlands: Kluwer Academic Publishers.
*Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
Mazumder PK, Sugendran K, Vijayaraghavan R. 1998. Protective efficacy of calcium channel blockers in sulphur mustard poisoning. Biomed Environ Sci 11:363–369.10095934
*Mazurek M, Witkiewicz Z, Popiel S, . 2001. Capillary gas chromatography-atomic emission spectroscopy-mass spectrometry analysis of sulphur mustard and transformation products in a block recovered from the Baltic Sea. J Chromatogr A 919:133–145.11459300
*McAdams AJ Jr. 1956. A study of mustard vesication. J Invest Derm 26:317–326.13319819
McCann J, Choi E, Yamasaki E, . 1975. Detection of carcinogens as mutagens in the Salmonella/microsome test: Assay of 300 chemicals. Proc Natl Acad Sci 72:5135–5170.1061098
*McNamara BP, Owens EJ, Christensen MK, . 1975. Toxicological basis for controlling levels of mustard in the environment. Edgewood Arsenal Special Publication. Aberdeen Proving Ground, Maryland: Department of the Army. EB-SP-74030.
*Medvedeva N, Polyak Y, Zaytceva T, . 2000. Microbiological destruction of mustard in soil. Environ Sci Pollut Control Series (bioremediation of contaminated soils) 32:151–176.
Meier HL, Johnson JB. 1992. The determination and prevention of cytotoxic effects induced in human lymphocytes by the alkylating agent 2,2’-dichlorodiethyl sulfide (sulfur mustard, HD). Toxicol Appl Pharmacol 113:234–239.1532867
*Meier HL, Kelly SA. 1993. The identification and ranking of poly (ADP-RIBOSE) polymerase inhibitors as protectors against sulfur mustard induced decrease in cellular energy and viability in vitro assays with human lymphocytes. In: Proceedings of the medical defense bioscience review (1993) held in Baltimore, Maryland on 10-13 May 1993. Vol. 1. Springfield, VA: US Department of Commerce, 227–236.
Meier HL, Millard CB. 1998. Alterations in human lymphocyte DNA caused by sulfur mustard can be mitigated by selective inhibitors of poly(ADP-ribose) polymerase. Biochem Biophys Acta 1404:367–376.9739165
*Meier HL, Clayson ET, Kelly SA, . 1996. Effect of sulfur mustard (HD) on ATP levels of human lymphocytes cultured in vitro. In Vitro Toxicol 9(2):135–139.
*Meier HL, Gross CL, Graham LM, . 1987. The prevention of 2,2-dichlorodiethyl sulfide (sulfur mustard, HD) cytotoxicity in human lymphocytes by inhibitors of the poly(ADP-ribose) polymerase. In: Proceedings of the 6^th^ Chemical Defense Bioscience Review, Frederick, MD, 313–315.
Meisenberg BR, Melaragno AJ, Monroy RL. 1993. Granulocyte colony stimulating factor (G-CSF) for mustard-induced bone marrow suppression. Mil Med 158:470–474.7688884
Mellor SG, Rice P, Cooper GJ. 1991. Vesicant burns. Brit J Plastic Surg 44:434–437.
Mesilaakso MT. 1997. Application of NMR spectroscopy to environmental analysis: detection of trace amounts of chemical warfare agents and related compounds in organic extract, water, and sand. Environ Sci Technol 31:518–522.
*Meylan WM, Howard PH. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26:2293–2299.
*Michaelson S. 2000. DNA fragmentation pattern induced in thymocytes by sulphur mustard. Chem Biol Interact 125:1–15.10724362
Millard CB, Bongiovanni R, Broomfield CA. 1997. Cutaneous exposure to bis-(2-chloroethyl)sulfide results in neutrophil infiltration and increased solubility of 180,000 Mτ subepidermal collagens. Biochem Pharmacol 53:1405–1412.9260866
Millard CB, Meier HL, Broomfield CA. 1994. Exposure of human lymphocytes to bis-(2-chloro-ethyl)sulfide solubilizes truncated and intact core histones. Biochem Biophys Acta 1224:389–394.7803495
Mishima S, Hedbys BO. 1968. Measurement of corneal thickness with the haag-streit pachometer. Arch Ophthalmol 80:710–713.5699322
*Mitretek Systems. 2002. Chemistry of H (mustard). http://www.mitretek.org/home.nsf/homelandsecurity/Mustard.
*Mol MAE, DeVries R, Kluivers AW. 1991. Effects of nicotinamide on biochemical changes and microblistering induced by sulfur mustard in human skin organ cultures. Toxicol Appl Pharmacol 107:439–449.1825735
*Mol MAE, Van De Ruit ABC, Kluivers AW. 1989. NAD+ levels and the glucose uptake of cultured human epidermal cells exposed to sulfur mustard. Toxicol and Applied Pharm 98:159–165.
*Momeni AZ, Aminjavaheri M. 1994. Skin manifestations of mustard gas in a group of 14 children and teenagers: A clinical study. Int J Dermatol 33(3):184–187.8169017
*Momeni AZ, Enshaeih S, Meghdadi M, . 1992. Skin manifestations of mustard gas. Arch Dermatol 128:775–780.1599263
Moore AM, Rockman JB. 1950. A study of human hypersensitivity to compounds of the mustard gas type. Can J Res 28E:169–176.
*Morgenstern P, Koss FR, Alexander WW. 1947. Residual mustard gas bronchitis; effects of prolonged exposure to low concentrations. Ann Intern Med 26:27–40.20278461
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
*Munavalli S, Jakubowski EW. 1989. Thermospray liquid chromatography/mass spectrometry of mustard and its metabolites. Aberdeen Proving Ground, MD: U.S. Army Medical Research Institute of Chemical Defense, U.S. Armament Munitions Chemical Command. CRDEC-TR-066.
*Munavalli S, Jakubowski EM, Durst HD. 1995. Liquid chromatography/thermospray mass spectrometry of mustard and its metabolites. J Mass Spectrom 30:1716–1722.
*Munro NB, Talmage SS, Griffin GD, . 1999. The sources, fate, and toxicity of chemical warfare agent degradation products. Environ Health Perspect 107(12):933–973.10585900
Murphy ML. 1959. Comparison of the teratogenic effects of five polyfunctional alkylating agent on the rat fetus. Pediatrics 23:231–244.13613885
Murphy RJ. 1979. Air pollution aspects of hazardous material disposal. Proc Annu WWEMA Ind Pollut Conf 7:163–170.
*Murray VS, Volans GN. 1991. Management of injuries due to chemical weapons. Br Med J. 19:302(6769):129–30.
*NAC/AEGL. 2001. Acute exposure guideline levels (AEGLs) for sulfur mustard (Agent HD). Final acute exposure guideline levels (AEGLs). National Advisory Committee on Exposure Guideline Levels for Hazardous Substances.
*Nagy SM, Columbic D, Stein WH, . 1946. The penetration of vesicant vapors into human skin. J Gen Physiol 29:441–445.
*Nakamura T. 1956. [Studies on the warfare gas-injury in Japan. Report I: On the general condition of the poison gas island.] Hiroshima Med J 4:1141–1149. (Japanese)
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
Needham DM, Cohen JA, Barrett AM. 1947. The mechanism of damage to the bone marrow in systemic poisoning with mustard gas. Biochemistry 41:631–639.
Nersessians AK. 1992. Activity of human carcinogens in the salmonella and rodent bone marrow cytogenetic tests. Mutat Res 281:239–243.1373216
Newman-Taylor AJ, Morris AJR. 1991. Experience with mustard gas casualties. Lancet 337:242.
*NIOSH. 2003. Mustard Emergency Response Card. National Institute for Occupational Safety and Health. http://www.bt.cdc.gov/agent/mustardgas/erc505-60-2pr.asp. March 20, 2003.
*Nishimoto Y, Burrows B, Miyanishi S, . 1970. Chronic obstructive lung disease in Japanese poisoning gas workers. Am Rev Resp Disease 102:173–179.5431873
Nishimoto Y, Yamakido M, Ishioka S, . 1988. Epidemiological studies of lung cancer in Japanese mustard gas workers. In: Miller RW, . Unusual occurrences as clues to cancer etiology. Tokyo: Japan Science Society Press, 95–101.
*Nishimoto Y, Yamakido M, Shigenobu T, . 1983. Long term observation of poison gas workers with special reference to respiratory cancers. J UOEH 5:89–94.6091215
*Niu T, Matijasevic Z, Austin-Ritchie P, . 1996. A ^32^P-postlabeling method for the detection of adducts in the DNA of human fibroblasts exposed to sulfur mustard. Chem Biol Interact 100:77–84.8599857
*Noort D, Hulst AG, de Jong LPA, . 1999. Alkylation of human serum albumin by sulfur mustard in vitro and in vivo: Mass spectrometric analysis of a cysteine adduct as a sensitive biomarker of exposure. Chem Res Toxicol 12:715–721.10458705
*Noort D, Hulst AG, Trap HC, . 1997. Synthesis and mass spectrometric identification of the major amino acid adducts formed between sulphur mustard and hemoglobin in human blood. Arch Toxicol 71:171–178.9049054
*Noort D, Verheij ER, Hulst AG, . 1996. Characterization of sulfur mustard induced structural modifications in human hemoglobin by liquid chromatography-tandem mass spectrometry. Chem Res Toxicol 9:781–787.8831823
*Norman JE Jr. 1975. Lung cancer mortality in World War I veterans with mustard gas injury 1919-1965. J Natl Cancer Inst 54:311–318.1113317
*NRC. 1985. Possible long-term health effects of short-term exposure to chemical agents. Volume 3. Current health status of test subjects. Govt Reports Announcements & Index (GRA&I). NTIS/AD-A163 614/1. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press.
*NRC. 1993. Pesticides in the diets of infants and children. National Research Council. Washington, DC: National Academy Press.
*NRC. 1994. Recommendations for the disposal of chemical agents and munitions. National Research Council. Washington, DC: National Academy Press.
*NRC. 1996. Review and evaluation of alternative chemical disposal technologies. National Research Council. Washington, DC: National Academy Press.
*NRC. 1997. Review of acute human toxicity estimates for selected chemical-warfare agents. Committee on Toxicology, National Research Council, Washington, DC. http://books.nap.edu/books/0309057493/html/59.html.
*NRC. 1999a. Review and evaluation of alternative technologies for demilitarization of assembled chemical weapons. National Research Council. Washington, DC: National Academy Press.
*NRC. 1999b. Review of the U.S. Army’s health risk assessments for oral exposure to six chemical-warfare agents. National Research Council, Washington, DC. National Academy Press.
*NRC. 2000. Review of the U.S. Army’s health risk assessments for oral exposure to six chemical-warfare agents. National Research Council. Washington, DC: National Academy Press.
*NRC. 2003. Acute exposure guideline levels for selected airborne chemicals. Volume 3. Subcommittee on Acute Exposure Guideline Levels, Committee on Toxicology, National Research Council. Washington, DC: National Academy Press.
*NRL. 1945. Chamber tests with human subjects. IX. Basic tests with H vapor. Naval Research Laboratory, Washington, DC. AD396275.
NTP. 1989. Fifth annual report on carcinogens. Summary NTP Publication No. 89-239. US Department of Health and Human Services. Public Health Service. National Toxicology Program. Research Triangle Park, NC.
*NTP. 2001. National Toxicology Program. http://ntp-server.niehs.nih.gov/. February 27, 2001.
Nyska A, Lomnitski L, Maronpot R, . 2001. Effects of iodine on inducible nitric oxide synthase and cyclooxygenase-2 expression in sulfur mustard-induced skin injury in guinea pigs. Arch Toxicol 74:768–774.11305779
*Oak Ridge National Laboratory. 1996. Health risk assessment for sulfur mustard (HD). Appendix E. Draft Report.
Ohmine H, Fujita M, Goriki K, . 1984. A study of the genetic effects of occupational exposure to mustard gas 2. Jpn J Hum Genet 29:237–238.
*OPCW. 2001. Organization for the prohibition of chemical weapons, decontamination of chemical warfare agents. http://www.opcw.nl/chemhaz/decon.htm. March 13, 2001.
*Opresko DM, Young RA, Faust RA, . 1998. Chemical warfare agents: Estimating oral reference doses. Oakridge, TN: Rev Environ Contam Toxicol 56:1–183.
*Opresko DM, Young RA, Watson AP, . 2001. Chemical warfare agents: Current status of oral reference doses. Rev Environ Contam Toxicol 172:65–85.
Orma PS, Middleton RK. 1992. Aerosolized atropine as an antidote to nerve gas. Ann Pharmacother 26:937–938.1504407
*OSHA. 1982. Occupational Safety and Health Administration. Federal Register. 47:30420.
*Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
*Pant SC, Vijayaraghavan R. 1999. Histomorphological and histochemical alterations following shortterm inhalation exposure to sulfur mustard on visceral organs of mice. Biomed Environ Sci 12:201–213.10674184
*Papirmeister B. 1993. Excitement in vesicant research – yesterday, today, and tomorrow. In: Proceedings of the medical defense bioscience review (1993) held in Baltimore, Maryland on 10-13 May 1993. Vol. 1. Springfield, VA: US Department of Commerce, 1–14.
*Papirmeister B, Feister AF, Robinson SI, . 1991. Medical defense against mustard gas: Toxic mechanisms and pharmacological implications. CRC Press, Boca Raton, FL.
*Papirmeister B, Gross CL, Meier HL, . 1985. Molecular basis for mustard-induced vesication. Fundam Appl Toxicol 5:S134–S149.2419197
*Papirmeister B, Gross CL, Petrali JP, . 1984a. Pathology produced by sulfur mustard in human skin grafts on athymic nude mice: 1. Gross and light microscopic changes. J Toxicol Cutaneous Ocul Toxicol 3:371–392.
*Papirmeister B, Gross CL, Petrali JP, . 1984b. Pathology produced by sulfur mustard in human skin grafts on athymic nude mice: 2. Ultrastructural changes. J Toxicol Cutaneous Ocul Toxicol 3:393–408.
*Pauser G, Aloy A, Caravan M, . 1984. Lethal intoxication by war gases on Iranian soldiers. Therapeutic interventions on survivors of mustard gas and mycotoxin immersion. Archives Belges:S341–S351.
Pearson GS. 1993. Chemical complications. Nature 365(3443):218.11643154
Pechura CM. 1993. The health effects of mustard gas and lewisite. JAMA 269:453.8419656
*Pechura CM, Rall DP. 1993. Veterans at risk: The health effects of mustard gas and lewisite. Washington DC: National Academy Press, 117–118. http://nap.edu/openbook/030904832X/html/R1.html. July 10, 2001.
Peters RA. 1947. Biochemical research at Oxford upon mustard gas. Nature 4031:149–153.
Petrali JP, Oglesby-Megee S. 1997. Toxicity of mustard gas in skin lesions. Microsc Res Tech 37:221–228.9144634
*Pierard GE, Dowlati A, Dowlati Y, . 1990. Chemical warfare casualties and yperite-induced xerodermoid. Am J Dermatopathol 12(6):565–570.2267995
*Platteborze PL. 2000. The effects of sulfur mustard on transcription in human epidermal keratinocytes: Analysis at early time points through DNA arrays. Toxicol Meth 10:151–163.
Pleyer U, Sherif Z, Baatz H, . 1999. Delayed mustard gas keratopathy: Clinical findings and confocal microscopy. Am J Ophthalmol 128:506–507.10577594
Pons F, Calvet J-H, Haag M, . 2001. Altered expression of lung cytochrome P450 3A1 in rat after exposure to sulfur mustard. Pharmacol Toxicol 88:40–44.11169160
*Posner JC. 1991. Evaluation of sorbents for the collection and analysis of trace levels of airborne vapors: Bis(2-chloroethyl)sulfide (mustard). A case study. Chemosphere 22:461–472.
*Pour-Jafari H. 1992. Fetal deaths and parental exposure to chemical warfare agents. Med J Islamic Rep Iran 6:87–88.
*Pour-Jafari H. 1994a. Secondary sex ratios in progenies of Iranian chemical victims. Vet Hum Toxicol 36:475–476.7839578
*Pour-Jafari H. 1994b. Congenital malformations in the progenies of Iranian chemical victims. Vet Human Toxicol 36(6):562–563.
*Pour-Jafari H, Moushtaghi A. 1992. Alterations of libido in gassed Iranian men. Vet Hum Toxicol 34(6):547.
*Prentiss AN. 1937. Chemicals in war. New York: McGraw-Hill.
*Price CC, Bullitt IH. 1947. Hydrolysis and oxidation of mustard gas and related compounds in aqueous solution. J Org Chem 12:238–248.20291131
Price CC, Wakefield LB. 1947. Reactions and analysis of B-chloroethyl sulfide in water. J Org Chem 12:232–237.20291130
Probst GS, Hill LE, Bewsey BJ. 1980. Comparison of 3 in vitro assays for carcinogen-induced DNA damage. J Toxicol Environ Health 6:333–349.7392097
Probst GS, McMahon RE, Hill CZ, . 1981. Chemically-induced unscheduled DNA synthesis in primary rat hepatocyte cultures: A comparison with bacterial mutagenicity using 218 compounds. Environ Mutagen 3:11–32.7021142
*Pu Y, Lin P, Vaughan FL, . 1995. Appearance of interleukin 1α relates DNA interstrand cross-links and cytotoxicity in cultured human keratinocytes exposed to bis-(2chloroethyl)sulfide. J Appl Toxicol 15:477–482.8603935
*Rao PVL, Vijayaraghavan R, Bhaskar ASB. 1999. Sulphur mustard induced DNA damage in mice after dermal and inhalation exposure. Toxicology 139:39–51.10614687
Ray P, Chakrabarti AK, Broomfield CA, . 2002. Sulfur mustard-stimulated protease: a target for antivesicant drugs. J Appl Toxicol 22:139–140.11920939
Ray R, Benton BJ, Anderson DR, . 1999. Poly(ADP-ribose) polymerase (PARP) mediated mechanisms of sulphur mustard (SM) toxicity and its protection. FASEB J 13(7):A1341.
Ray R, Legere RH, Majerus BJ, . 1995. Sulfur mustard-induced increase in intracellular free calcium level and arachidonic acid release from cell membrane. Toxicol Appl Pharmacol 131:45–52.
*Ray R, Majerus BJ, Munavalli GS, . 1993. Sulfur mustard-induced increase in intracellular calcium: A mechanism of mustard toxicity. In: Proceedings of the medical defense bioscience review (1993) held in Baltimore, Maryland on 10-13, May 1993. Vol. 1. Springfield, VA: US Department of Commerce, 267–276.
Reddy PMK, Dubey DK, Kumar P, . 1996. Evaluation of CC-2 as a decontaminant at various time intervals against topically applied sulphur mustard in mice. Indian J Pharmacol 28:227–231.
*Reed CI. 1918. The minimum concentration of mustard gas effective for man. Preliminary Report. War Department, Medical Division, Pharmacological Research Section, American University Experiment Station, Washington, DC. Report 318.
Reed CI, Hopkins EF, Weyand CF. 1918. The minimum concentration of mustard gas effective for man. Final Report. War Department, Medical Division, Pharmacological Research Section, American University Experiment Station, Washington, DC. Report 329.
Reed CI. 1920. The minimum concentration of dichlorethylsulfide (mustard gas) effective for man. J Pharmacol Exp Ther 15:77–80.
Rees J, Harper P, Ellis F. 1991. Mustard gas casualties. Lancet 337:430.
Reid BD, Walker IG. 1969. The response of mammalian cells to alkylating agents. II. On the mechanism of the removal of sulfur-mustard-induced cross-links. Biochem Biophys Acta 179:179–182.5787642
*Renshaw B. 1946. Mechanisms in production of cutaneous injuries by sulfur and nitrogen mustards. In: Chemical warfare agents and related chemical problems. Vol. 4. Chapter 23, Washington, DC: U.S. Office of Scientific Research and Development, National Defense Research Committee, 479–518.
Renwick AG, Lazarus NR. 1998. Human variability and noncancer risk assessment-an analysis of the default uncertainty factor. Regul Toxicol Pharmacol 27:3–20.
Requena L, Requena C, Sanchez G, . 1988. Chemical warfare. Cutaneous lesions from mustard gas. J Am Acad Dermatol 19:529–536.3049698
*Rewick RT, Schumacher ML, Haynes DL. 1986. The UV absorption spectra of chemical agents and stimulants. Appl Spectrosc 40(2):152–156.
*Ribeiro PL, Mitra RS, Bernstein IA. 1991. Assessment of the role of DNA damage and repair in the surviving cultures of rat cutaneous keratinocytes exposed to bis(2-chloroethyl) sulfide. Toxicol Appl Pharmacol 111(2):342–51.1957317
Rikimaru T, Nakamura M, Yano T, . 1991. Mediators, initiating the inflammatory response, released in organ culture by full-thickness human skin explants exposed to the irritant, sulfur mustard. J Invest Dermatol 96:888–897.1710639
Riviere JE, Brooks JD, Williams PL, . 1995. Toxicokinetics of tropical sulfur mustard penetration, disposition, and vascular toxicity in isolated perfused porcine skin. Toxicol Appl Pharmacol 135:25–34.7482537
Riviere JE, Monteiro-Riviere NA, Baynes RE, . 2002. Gulf war related exposure factors influencing topical absorption of ^14^C-permethrin. Toxicol Lett 135:61–71.12243864
Riviere JE, Smith CE, Budsaba K, . 2001. Use of methyl salicylate as a simulant to predict the percutaneous absorption of sulfur mustard. J Appl Toxicol 21:91–99.11288131
*Roberts JJ, Warwick GP. 1963. Studies of the mode of action of alkylating agents-VI. The metabolism of bis-β-chloroethylsulfide (mustard gas) and related compounds. Biochem Pharmacol 12:1239–1334.
*Rohrbaugh DK, Yang YC. 1997. Liquid chromatography/electrospray mass spectrometry of mustard-related sulfonium ions. J Mass Spectrom 32:1247–1252.
Rohrbaugh DK, Yang Y-C, Ward JR. 1988. Identification of degradation products of 2-chloroethyl ethyl sulfide by gas chromatography-mass spectrometry. J Chromatogr 447:165–169.3209662
Romano Jr JA, King JM. 2001. Psychological casualties resulting from chemical and biological weapons. Mil Med 166:21–22.
Rommerim RL, Hackett PL. 1986. Evaluation of the teratogenic potential of the mustards. Teratology 33:70C.
*Rosenblatt DH, Miller TA, Dacre JC, . 1975. Problem definition studies on potential environmental pollutants. II. Physical, chemical, toxicological, and biological properties of 16 substances. Fort Detrick, MD: U.S. Army Medical Bioengineering Research Development Laboratory. TR-7509.
*Rosenblatt DH, Small MJ, Kimmell TA, . 1996. Background chemistry for warfare agents and decontamination processes in support of delisting waste streams at the U.S. Army Dugway Proving Ground, Utah.
Rosenthal DS, Simbulan-Rosenthal CM, Liu WF, . 2001. PARP determines the mode of cell death in skin fibroblasts, but not keratinocytes, exposed to sulfur mustard. J Invest Dermatol 117:1566–1573.11886524
*Rosenthal DS, Simbulan-Rosenthal CMG, Spoonde SIA, . 1998. Sulfur mustard induces markers of terminal differentiation and apoptosis in keratinocytes via a Ca^2+^-calmodulin and capase-dependent pathway. J Invest Dermatol 111:64–71.9665388
*Rozmiarek H, Capizzi RL, Papirmeister B, . 1973. Mutagenic activity in somatic and germ cells following chronic inhalation of sulfur mustard. Mutat Res Sect Environ Mutag Relat Sub 21:13–14.
Ruhl CM, Park SJ, Danisa O, . 1994. A serious skin sulfur mustard burn from an artillery shell. J Emerg Med 12(2):159–166.8207150
Safaei A, Saluti R, Kumar PV. 2001. Conjunctival dysplasia in soldiers exposed to mustard gas during the Iraq-Iran war. Acta Cytol 45(6):909–913.11726116
Safarinejad MR. 2001. Testicular effect of mustard gas. Urology 58:90–94.11445486
Safarinejad MR, Moosavi SA, Montazeri B. 2001. Ocular injuries caused by mustard gas: diagnosis, treatment, and medical defense. Mil Med 166(1):67–70.
Sage GW, Howard PH. 1989. Environmental fate assessments of chemical agents: HD and VX. Chemical Hazard Assessment Division. Syracuse, NY: Syracuse Research Corporation.
*Sandelowsky I, Simon GA, Barak R, . 1992. N^1^-(2-hydroxyethylthioethyl)-4-methyl imidazole (4-met-1-imid-thiodiglycol) in plasma and urine: A novel metabolite following dermal exposure to sulphur mustard. Arch Toxicol 66:296–297.1514930
*Sass S, Steger RJ. 1982. Gas chromatographic differentiation and estimation of some sulfur and nitrogen mustards using a multidetector technique. J Chromatogr 238:121–132.
*Sass S, Stutz MH. 1981. Thin-layer chromatography of some sulfur and nitrogen mustards. J Chromatogr 213:173–176.
Sasser LB, Cushing JA, Dacre JC. 1990. Dominant lethal effect of sulfur mustard in rats. Toxicologist 10(1):225.
*Sasser LB, Cushing JA, Dacre JC. 1993. Dominant lethal study of sulfur mustard in male and female rats. J Appl Toxicol 13(5):359–368.8258633
*Sasser LB, Cushing JA, Dacre JC. 1996a. Two-generation reproduction study of sulfur mustard in rats. Reprod Toxicol 10(4):311–319.8829254
*Sasser LB, Miller RA, Kalkwarf DR, . 1996b. Subchronic toxicity evaluation of sulfur mustard in rats. J Appl Toxicol 16(1):5–13.8821670
*Sawyer TW. 1998. Characterization of the protective effects of L-nitroarginine methyl ester (L-NAME) against the toxicity of sulphur mustard in vitro. Toxicology 131:21–32.9881932
*Sawyer TW. 1999. Synergistic protective effects of selected arginine analogues against sulphur mustard toxicity in neuron culture. Toxicol Appl Pharmacol 155:169–176.10053171
Sawyer TW, Risk D. 2000. Effects of selected arginine analogues on sulphur mustard toxicity in human and hairless guinea pig skin keratinocytes. Toxicol Appl Pharmacol 163:75–85.10662607
*Sawyer TW, Hancock JR, D’Agostino PA. 1998. L-Thiocitrulline: A potent protective agent against the toxicity of sulphur mustard in vitro. Toxicol Appl Pharmacol 151:340–346.9707510
*Sawyer TW, Lundy PM, Weiss MT. 1996. Protective effect of an inhibitor of nitric oxide synthase on sulphur mustard toxicity in vitro. Toxicol Appl Pharmacol 141:138–144.8917686
*Sax IN, Lewis RJ. 1989. Dangerous properties of industrial materials. Volume II. 7 ^th^ ed. New York: Van Nostrand Reinhold, 477.
*SBCCOM. 1999. Distilled mustard (HD). Material safety data sheet. U.S. Army Soldier and Biological Chemical Command. http://in1.apgea.army.mil/RDA/msds/hd.htm. July 12, 2001.
*SBCCOM. 2001. M291 Skin decontamination kit. U.S. Army Soldier and Biological Chemical Command. http://www.sbccom.apgea.army.mil/products/m291.htm. March 14, 2001.
*SBCCOM. 2002. Biological and chemical agent quick reference tables. U.S. Army Soldier and Biological Chemical Command. http://www.sbccom.apgea.army.mil/products/m291.htm. March 12, 2002.
Schlager JJ, Hart BW. 2000. Stress gene activity in HepG2 cells after sulfur mustard exposure. J Appl Toxicol 20:395–405.11139170
*Scholz RO. 1945. Clinical and pathological studies of ocular mustard gas burns. Fasciculus on Chemical Warfare Medicine. Volume I, Eye. Washington, DC: National Research Council, Division of Medical Sciences, Committee on Treatment of Gas Casualties, 155–191.
*Scholz RO, Woods AC. 1945. Relapsing and chronic mustard gas lesions of the eyes. Fasciculus on Chemical Warfare Medicine. Volume I, Eye. Washington, DC: National Research Council, Division of Medical Sciences, Committee on Treatment of Gas Casualties, 260–278.
Scott D, Marshall RR. 1977. Relationships between DNA repair chromosome aberrations and survival in mammalian cells. Mutat Res 46:154–155.
*Scott D, Fox M, Fox BW. 1974. The relationship between chromosomal aberrations, survival, and DNA repair in tumor cell lines of differential sensitivity to x-rays and sulphur mustard. Mutat Res 22:207–221.4366909
*Seidell A. 1941. Solubilities of organic compounds. A compilation of quantitative solubility data from the periodical literature. Vol. 11, 3^rd^ Edition. New York: D. Van Nostrand Company, Inc. 241–242.
*Setchell BP, Waites GMH. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington DC: American Physiological Society.
Shahin S, Cullinane C, Gray PJ. 2001. Mitochondrial and nuclear DNA damage induced by sulphur mustard in keratinocytes. Chem Biol Interact 138:231–245.11714481
Shakil FA, Kuramoto A, Yamakido M, . 1993. Cytogenetic abnormalities of hematopoietic tissue in retired workers of the Ohkunojima poison gas factory. Hiroshima J Med Sci 42(4):159–165.8014068
Sherer RA, Price PS. 1993. The effect of cooking processes on PCB levels in edible fish tissue. Qual Assur Good Prac Reg Law 2(4):396–407.
Shih ML, Korte WD, Smith JR, . 1999a. Analysis and stability of the candidate sulfur mustard decontaminant S-330. J Appl Toxicol 19:S89–S95.10594907
Shih ML, Korte WD, Smith JR, . 1999b. Reactions of sulfides with S-330, a potential decontaminant of sulfur mustard in formulations. J Appl Toxicol 19:S83–S88.10594906
Shimkin MB, McClelland JN. 1949. Induced pulmonary tumors in mice. IV. Analysis of dose response data with methyl-cholanthrene. J Natl Cancer Inst 10:597–603.15403013
Sidell FR, Hurst CG. 1992. Clinical considerations in mustard poisoning. In: Somani AM ed. Chemical warfare agents. New York: Academic Press, 51–67.
*Sinclair DC. 1948. The clinical features of mustard-gas poisoning in man. Br Med J 290–294.
*Sinclair DC. 1950. Disability produced by exposure of skin to mustard-gas vapor. Br Med J 346–348.
SIPRI. 1975. Delayed toxic effects of chemical warfare agents: A SIPRI monograph. Stockholm: Stockholm International Peace Research Institute.
*SIPRI. 1971. The Problem of chemical and biological warfare: A study of the historical, technical, military, legal, and political aspects of CBW, and possible disarmament measures. Stockholm International Peace Research Institute. Stockholm, Sweden: Almqvist & Wiksell, 125–305.
Sklyar VI, Mosolova TP, Kuchernko IA, . 1999. Anaerobic toxicity and biodegradability of hydrolysis products of chemical warfare agents. Appl Biochem Biotech 81:107–117.
*Small MJ. 1984. Compounds formed from the chemical decontamination of HD, GB, and VX and their environmental fate. U.S. Army Research and Development Command. Frederick, Maryland.
Smith CN, Lindsay CD. 2001a. Kojic acid reduces the cytotoxic effects of sulfur mustard on cultures containing human melanoma cells in vitro. J Appl Toxicol 21:435–440.11746188
Smith CN, Lindsay CD. 2001b. Stimulation of C32 and G361 melanoma cells using oleoyl acetyl glycerol and its effect on sulphur mustard cytotoxicity. Hum Exp Toxicol 20:418–425.11727793
*Smith JE, Fowler WK. 1985. Analytical methods development. Final report. Contract DAAK 11-82-C-0162.
*Smith JR, Shih ML. 2001. Analysis of the degradation compounds of chemical warfare agents using liquid chromatography/mass spectrometry. J Appl Toxicol 21:S27–S34.11920917
Smith WJ, Dunn MA. 1991. Medical defense against blistering chemical warfare agents. Arch Dermatol 127:1207–1213.1863081
Smith WJ, Gross CL. 2002. Sulfur mustard medical countermeasures in a nuclear environment. Mil Med 167:101–102.11873485
Smith C, Lindsay C, Upshall D. 1997. Presence of methenamine/glutathione mixtures reduces the cytotoxic effect of sulfur mustard on cultured SVK-14 human keratinocytes in vitro. Hum Exp Toxicol 16:247–253.9192202
Smith CN, Lindsay CD, Hambrook JL. 2001. An in vitro comparison of the cytotoxicity of sulphur mustard in melanoma and keratinocyte cell lines. Hum Exp Toxicol 20:483–490.11776411
*Smith HW, Clowes GHA, Marshall JV. 1919. On dichloroethylsulfide (mustard gas). IV. The mechanism of absorption by the skin. J Pharmacol Exp Ther 13:1–30.
*Smith JE, Boyd WB, Mason DW. 1982. Depot Area Air Monitoring System and VX Study. Final Report. Contract DAAK 11-77-c-0087. Task orders 6 and 7. Report # ARCS-CR-82052.
*Smith KJ, Graham JS, Hamilton TA, . 1997a. Immunohistochemical studies of basement membrane proteins and proliferation and apoptosis markers in sulfur mustard induced cutaneous lesions in weanling pigs. J Dermatol Sci 15:173–182.9302645
Smith KJ, Hamilton T, Smith WJ, . 1996. Immunohistochemical staining of basement membrane proteins after topical exposure of human skin to nitrogen and sulfur mustard. In: 1996 Medical defense bioscience review: Proceedings. Vol. II. 12–16 May. Aberdeen, MD; N: U.S. Army Medical Research Institute of Chemical Defense; 1093–1103.
Smith KJ, Hurst CG, Moeller RB, . 1995. Sulfur mustard: Its continuing threat as a chemical warfare agent, the cutaneous lesions induced, progress in understanding its mechanism of action, its longterm health effects, and new developments for protection and therapy. J Am Acad Dermatol 32:765–778.7722023
*Smith KJ, Skelton HG, Martin JL, . 1997b. CO_2_ laser debridement of sulphur mustard (bis-2-chloroethyl sulphide) induced cutaneous lesions accelerates production of a normal epidermis with elimination of cytological atypia. Br J Dermatol 137:590–594.9390337
*Smith PH, Nadkarni MV, Trams EG, . 1958. Distribution and fate of alkylating agents. Ann NY Acad Sci 68:834–852.13627736
*Smith WJ, Baskin SI, Filbert MG, . 2000. Editorial. Introduction to vesicant supplement of Journal of Applied Toxicology. J Appl Toxicol 20(Suppl 1):661.
Smith WJ, Gross CL, Chan P, . 1990a. The use of human epidermal keratinocytes in culture as a model for studying the biochemical mechanisms of sulfur mustard toxicity. Cell Biol Toxicol 6(3):285–291.2147571
Smith WJ, Gross CL, Chan P, . 1990b. Use of human epidermal keratinocytes in culture as a model for studying the biochemical mechanisms of sulfur mustard toxicity. Govt Reports Announcements & Index. NTIS/AD-A230 926/8.
*Smith WJ, Martens ME, Gross CL, . 1998. Biochemical and flow cytometric studies of the mechanism of action of sulfur mustard using human cells in culture. In: Salem H, Katz SA, eds. Advances in animal alternatives for safety and efficacy testing. Washington DC: Taylor and Francis 99–101.
*Smith WJ, Sanders KM, Ruddle SE, . 1993a. Cytometric analysis of DNA changes induced by sulfur mustard. J Toxicol Cutaneous Ocul Toxicol 12(4):337–347.
Smith WJ, Sanders KM, Ruddle SE, . 1993b. Cytometric analysis of DNA changes induced by sulfur mustard. In: Proceedings of the medical defense bioscience review (1993) held in Baltimore, Maryland on 10-13 May 1993. Vol. 1. Springfield, VA: US Department of Commerce, 189–198.
Snider TH, Blank JA, Reid FM, . 1996. Evaluation of the weanling pig as a model for sulfur mustard induced microvesication. In: 1996 Medical defense bioscience review: Proceedings. Vol. II. 12–16 May. Columbus, OH: Medical Research and Evaluation Facility, 1121–1128.
Snyder RE, Schulte BE, Mangoba L, . 1983. Research and development of hazardous/toxic waste analytical screening procedures: Available field methods for rapid screening of hazardous waste materials at waste sites. Final report. Fort Detrick, Frederick, MD: U.S. Army Medical Research and Development Command. DAMD17-78-C-8075.
Sokal JE, Lessman EM. 1960. Effects of cancer chemotherapeutic agents on the human fetus. J Am Med Assoc 172:1765–1771.13832514
*Solberg Y, Alcalay M, Belkin M. 1997. Ocular injury by mustard gas. Surv Ophthalmol 41(6):461–466.9220568
*Somani SM. 1992. Toxicokinetics and toxicodynamics of mustard. In: Chemical warfare agents. San Diego, CA: Academic Press Inc., 13–50.
*Somani SM, Babu SR. 1989. Toxicodynamics of sulfur mustard. Int J Clin Pharmacol Ther Toxicol 27:419–435.2681003
*Sonbati EM, Auerbach C. 1960. The brood pattern for intragenic and intergenic changes after mustard gas treatment of Drosophila males. Zeitschrift fur Vererbungslehre 91:253–258.
Spencer PS, Daniels J, Kisby G. 2000. Mustard warfare agents and related substances. In: Spencer PS, Schaumburg HH, Ludolph AC, eds. Experimental and clinical neurotoxicology. 2^nd^ Ed. New York NY: Oxford University Press, 837–848.
Spoo JW, Monteiro-Riviere NA, Riviere JE. 1995. Detection of sulfur mustard bis (2-chloroethyl) sulfide and metabolites after topical application in the isolated perfused porcine flap. Life Sci 56(17):1385–1394.8847949
*Stein WH. 1946. Chemical reactions of sulfur and nitrogen mustards. Chemical warfare agents and related chemical problems. Parts III-IV. Summary technical report of Division 9, NRDC, 389–414.
Stein WH, Moore S, Bergmann M. 1946. Chemical reactions of mustard gas and related compounds. J Org Chem 11:664–674.
*Sterri SH. 1993. Effect of s-mustard on stress response. In: Proceedings of the medical defense bioscience review (1993) held in Baltimore, Maryland on 10-13 May 1993. Vol. 1. Springfield, MA: US Department of Commerce, 285–292.
Stewart DL, Sass EJ, Fritz LK, . 1989. Toxicology studies on lewisite and sulfur mustard agents: Mutagenicity of sulfur mustard in the Salmonella histidine reversion assay. Final Report, PNL-6873. Pacific Northwest Laboratories, Richland, WA. ADA213102.
*Stutz MH, Sass S. 1969. Qualitative thin-layer chromatography of some mustards (HD, Q, HN-1, HN-2, HN-3, and T). Edgewood Arsenal technical report. Edgewood Arsenal, Maryland: Department of the Army, Edgewood Arsenal, Research Laboratories, Chemical Research Laboratories. EATR 4283.
*Sugendran K, Jeevaratnam K, Vijayaraghavan R, . 1994. Therapeutic efficacy of saline and glucose-saline against dermally applied sulphur mustard intoxication in mice. Def Sci J 44(1):21–23.
Sulzberger MB, Baer RL, Kanof A, . 1945. Skin sensitization to vesicant agents of chemical warfare. Fasciculus on chemical warfare medicine. Ithaca NY: Cornell University, 16–66.
*Sulzberger MB, Baer RL, Kanof A, . 1947. Skin sensitization to vesicant agents of chemical warfare. J Invest Dermatol 8:365–393.20257267
Suryanarayana MVS, Shrivastava RK, Pandey D, . 2001. Simple time weighted average level air-monitoring method for sulfur mustard in work places. J Chromatogr A 907:229–234.11217030
SwRI. 2001. Ensuring environmental safety. Southwest Research Institute. http://www.swri.com/3pubs/ttoday/summer98/safe.htm. March 17, 2001.
Taher AA. 1992. Cleft lip and palate in Tehran. Cleft Palate Craniofac J 29:15–16.1547245
Takeshima Y, Inai K, Bennett WP, . 1994. Accelerated paper, p53 mutations in lung cancers from Japanese mustard gas workers. Carcinogenesis 15(10):2075–2079.7955036
ten Berge WF, Zwart A, Appelman LM. 1986. Concentration-time mortality response relationship of irritant and systematically acting vapours and gases. J Hazard Mater 13(3):301–309.
*Thomsen AB, Eriksen J, Smidt-Nielsen K. 1998. Chronic neuropathic symptoms after exposure to mustard gas: A long-term investigation. J Am Acad Dermatol 39:187–190.9704826
*Tokuoka S, Hayashi Y, Inai K, . 1986. Early cancer and related lesions in the bronchial epithelium in former worker of mustard gas factory. Acta Pathologica Japonica 36:533–542.3014812
TRI00. 2003. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. http://www.epa.gov/triexplorer/chemical.htm. August, 2003.
*Uhde G, Dunphy EB. 1946. The effect of oily drops on eyes exposed to mustard vapor. Intelligence Division Report No. 2981. Great Britain.
*Uhrig HT. 1962. Some medical aspects of chemical agents. J M A Alabama 32:144–150.
United States Army Chemical Activity WESTCOM. 1989. Environmental Laboratory Section Operations. SOP No ELS-3.
*USACHPPM. 1999. Derivation of health-based environmental screening levels for chemical warfare agents. A technical evaluation. U.S. Army Center for Health Promotion and Preventive Medicine.
*USACHPPM. 2000a. Evaluation of airborne exposure limits for sulfur mustard: occupational and general population exposure criteria. U.S. Army Center for Health Promotion and Preventive Medicine. Technical Report 47-EM-3767-01.
*USACHPPM. 2000b. Recommendations regarding chronic toxicological criteria for chemical warfare compounds. Memo for Office of the Surgeon General.
*USACHPPM. 2003. Chemical Warfare Agent Standards Derivation. Environmental Medicine Program. U.S. Army Center for Health Promotion and Preventive Medicine. http://chppm-www.apgea.army.mil/doem/EMP.asp.
U.S. Army. 1973. Medical aid for toxic adent victims. Washington, DC: Foreign Science and Technology Center, U.S. Army. FSTC-HT-23-1074-73.
*U.S. Army. 1995. Treatment of chemical agent casualties and conventional military chemical injuries. Washington, DC: Department of the Army, FM 8-285. http://www.adtdl.army.mil/cgi-bin/atdl.dll/query/info/FM+8-285. March 22, 2001.
*U.S. Army Dugway Proving Ground. 1985. Technical report: Toxic chemicals in the soil environment: Volume 2. Interactions of some toxic chemicals/chemical warfare agents and soils. Technical Analysis and Information Office, Dugway, Utah. 2-CO-210-049-041. ADA158215.
*USCWCR. 1999. Chemical weapons convention regulations. U.S. Chemical Weapons Convention Regulations. Department of Commerce, Bureau of Export Administration. Federal Register:64:250. 15 CFR Parts 710 through 722. December 30, 1999.
*VA. 2001. Claims based on chronic effects of exposure. Veterans Affairs. Code of Federal Regulations. 38 CFR 3.316. http://www.acess.gpo.gov/nara/cfr/cfr-table-search.html. June 3, 2001.
van Delft JHM, van Weert EJM, Schellekens MM, . 1991. The isolation of monoclonal antibodies selected for the detection of imidazole ring-opened N7-ethylguanine in purified DNA and in cells in situ. Cross reaction with methyl, 2-hydroxyethyl and sulphur mustard adducts. Carcinogenesis 12(6):1041–1049.2044182
van der Schans GP, Noort D, Mars-Groenendijk RH, . 2002. Immunochemical detection of sulfur mustard adducts with keratins in the stratum corneum of human skin. Chem Res Toxicol 15:21–25.11800593
*van der Schans GP, Scheffer AG, Mars-Groenendijk RH, . 1994. Immunochemical detection of adducts of sulfur mustard to DNA of calf thymus and human white blood cells. Chem Res Toxicol 7:408–413.8075373
*Venitt S. 1968. Inter strand cross link in the DNA of Escherichia coli B-R and B-S-1 and their removal by the resistant strain mustard gas mutagen. Biochem Biophys Res Commun 31:355–360.4871327
*Venkateswaran KS, Malhotra RC, Venkateswaran KS. 1994b. Degradation of bacteriophage λ deoxyribonucleic acid in vitro by sulfur. Biochem Mol Biol Int 34(3):429–435.7833820
*Venkateswaran KS, Neeraja V, Sugendran K, . 1994a. Dose dependent effects on lymphoid organs following a single dermal application of sulphur mustard in mice. Hum Exp Toxicol 13:247–251.8204309
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
VIEW Database. 1989. Agency for Toxic Substances and Disease Registry (ATSDR), Office of External Affairs, Exposure and Disease Registry Branch, Atlanta, GA. September 1989.
*Vijaayaraghavan R. 1997. Modifications of breathing pattern induced by inhaled sulphur mustard in mice. Arch Toxicol 71:157–164.9049052
*Vijayaraghavan R, Kumar P, Joshi U, . 2001. Prophylactic efficacy of amifostine and its analogues against sulphur mustard toxicity. Toxicology 163:83–91.11516517
*Vijayaraghavan R, Sugendran K, Pant SC, . 1991. Dermal intoxication of mice with bis(2-chloroethyl)sulphide and the protective effect of flavonoids. Toxicology 69:35–42.1926154
*Vogt RF Jr, Dannenberg AM Jr, Schofield BH. 1984. Pathogenesis of skin lesions caused by sulfur mustard. Fundam Appl Toxicol 4:71–83.
*Vojvodic V, Milosavljevic Z, Boskovic B, . 1985. The protective effect of different drugs in rats poisoned by sulfur and nitrogen mustards. Toxicol 5:S160–S168.
*Vycudilik W. 1985. Detection of mustard gas bis(2-chloroethyl) sulfide in urine. Forensic Sci Int 28:131–136.4043896
*Vycudilik W. 1987. Detection of bis(2-chloroethyl) sulfide (yperite) in urine by high resolution gas chromatography-mass spectrometry. Forensic Sci Int 35:67–71.3679039
Wada S, Nishimoto Y, Miyanish M, . 1962. Malignant respiratory tract neoplasms related to poison gas exposure. Hiroshima J Med Sci 11:81–91.
*Wada S, Nishimoto Y, Niyanishi M, . 1968. Mustard gas as a cause of respiratory neoplasia in man. Lancet 1:1161–1163.4172287
*Walker IG, Thatcher CJ. 1968. Lethal effects of sulfur mustard on dividing mammalian cells. Radiat Res 34:110–127.5644004
Walker JE, Kaplan DL. 1992. Biological degradation of explosives and chemical agents. Biodegradation 3:369–385.
*Wariishi H, Itoh N, Yoshida M, . 2002. Complete degradation of yperite, a chemical warfare agent, by basidiomycetes. Biotechnol Lett 24:501–505.
*Warthin AS, Weller CV. 1919. The medical aspects of mustard gas poisoning. St. Louis: C.V. Mosby.
Waters MD, Garrett NE, Covone-de Serres CM, . 1983. Genetic toxicology of some known or suspected human carcinogens. In: de Serres FJ, ed. Chemical mutagens, principles and methods for their detection. New York: Plenum Press, 261–341.
*Watson AP, Griffin GD. 1992. Toxicity of vesicant agents scheduled for destruction by the chemical stockpile disposal program. Environ Health Perspect 98:259–280.1486858
Watson AP, Jones TD, Griffin GD. 1989. Sulfur mustard as a carcinogen application of relative potency analysis to the chemical warfare agents H, HD, and HT. Regul Toxicol Pharmacol 10:1–25.2672125
*Weiss A, Weiss B. 1975. [Carcinogenesis due to mustard gas exposure in man.] Deutsche Medizinsche Wonchenschrift 100:919–923. (German)
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
*Whitfield D. 1987. A literature review upon the toxicology, mechanism of action and treatment of sulphur and nitrogen mustard poisoning. Chemical Defence Establishment, Porton, Wilts, U.K., CDE Technical Note No. 840.
Whitten B, ed. 1963. Kirk-Othmer encyclopedia of chemical technology. Gas warfare agents, nitrogen mustards. Vol. 7, 1^st^ ed. New York, NY: The Interscience Encyclopedia, 127–130, 144–145.
*Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York: Academic Press.
Wilde PE, Upshall DG. 1994. Cysteine esters protect cultured rodent lung slices from sulphur mustard. Hum Exp Toxicol 13:743–748.7857693
*Willems JL. 1989. Clinical management of mustard gas casualties. Annales Medicinae Militaris Belgicae, 1989, Vol 3 Supp. Heymans Institute of Pharmacology, University of Ghent Medical School and Royal School of the Medical Services, Leopoldskazerne, B-900 Ghent, Belgium.
Wils ERJ. 1987. Analysis of thiodiglycol in urine of victims of an alleged attack with mustard gas. Part II. Prins Maurits Laboratorium, Institute for Chemical and Technological Research, The Netherlands. PML 1987–31.
Wils ERJ, Hulst AJ. 1992. The use of thermospray-liquid chromatography/mass spectrometry for the verification of chemical warfare agents. Fresenius J Anal Chem 342:749–758.
*Wils ERJ, Hulst AG, De Jong AL, . 1985. Analysis of thiodiglycol in urine of victims of an alleged attack with mustard gas. J Anal Toxicol 9:254–277.4079337
*Wils ERJ, Hulst AG, de Jong AL. 1992. Determination of mustard gas and related vesicants in rubber and paint by gas chromatography-mass spectrometry. J Chromatogr 625:382–386.
*Wils ERJ, Hulst AG, van Laar J. 1988. Analysis of thiodiglycol in urine of victims of an alleged attack with mustard gas part II. J Anal Toxicol 12:15–19.3352237
*Winternitz MC, Finney WP Jr. 1920. The pathology of mustard poisoning. In: Winternitz MC, ed. Pathology of war gas poisoning. New Haven, CT: Yale University Press, 101–111.
Woessner JF, Dannenberg AM, Pula PJ, . 1990. Extracellular collagenase, proteoglycanase and products of their activity, released in organ culture by intact dermal inflammatory lesions produced by sulfur mustard. J Invest Dermatol 95:717–726.2174450
*Wormser U, Brodsky B, Green BS, . 1997. Protective effect of povidone-iodine ointment against skin lesions induced by sulphur and nitrogen mustards and by non-mustard vesicants. Arch Toxicol 71:165–170.9049053
Wormser U, Brodsky B, Reich R. 2002. Topical treatment with povidone iodine reduces nitrogen mustard-induced skin collagenolytic activity. Arch Toxicol 76:119–121.11914782
*Wulf HC, Aasted A, Darre E, . 1985. Sister chromatid exchanges in fishermen exposed to leaking mustard gas shells. Lancet 1:690–691.
*Yamada A. 1963. On the late injuries following occupational inhalation of mustard gas, with special references to carcinoma of the respiratory tract. Acta Pathol Jpn 13(3):131–155.14196541
*Yamada A. 1974. Patho-anatomical studies on occupational poisoning. Tr Soc Path Jap 63:17–61.
Yamada A, Hirose F, Miyanishi M. 1953. An autopsy of bronchial carcinoma found in a patient succumbed to occupational mustard gas poisoning. Gann 44:216–219.13128117
Yamada A, Hirose F, Nagai M, . 1957. Five cases of cancer of the larynx found in persons who suffered from occupational mustard gas poisoning. Gann 48:366–368.13524406
*Yamakido M, Ishioka S, Hiyama K, . 1996. Former poison gas workers and cancer: Incidence and inhibition of tumor formation by treatment with biological response modifier N-CWS. Environ Health Perspect 104(Suppl. 3):485–488.8781369
Yamakido M, Ishioka S, Hozawa S, . 1992. Effect of nocardia ruba cell-wall skeleton on cancer prevention in humans. Cancer Immunol Immunother 34:389–392.1563016
*Yamakido M, Nishimoto Y, Shigenobu T, . 1985. Study of genetic effects of sulfur mustard gas on former workers of Ohkunojim poison gas factory and their offspring. Hiroshima J Med Sci 34:311–322.4066398
Yamakido M, Yanagida J, Ishioka S, . 1986. Immune functions of former poison gas workers. I. Mitogenic response of lymphocytes and serum factors. Hiroshima J Med Sci 35(2):117–126.3771270
Yanagida J, Hozawa S, Ishioka S, . 1988. Somatic mutation in peripheral lymphocytes of former workers at the Okunojima poison gas factory. Jpn J Cancer Res 79:1276–1283.3148597
*Yang YC, Baker JA, Ward JR. 1992. Decontamination of chemical warfare agents. Chem Rev 92:1729–1743.
*Young L. 1947. Observations on the effects of mustard gas on the rat. Canadian Journal of Research; Section E: Medical Sciences, 25:141–151.
*Yourick JJ, Clark CR, Mitcheltree LW. 1991. Niacinamide pretreatment reduces microvesicle formation in hairless guinea pigs cutaneously exposed to sulfur mustard. Fundam Appl Toxicol 17:533–542.1838996
*Yourick JJ, Dawson JS, Benton CD, . 1993. Pathogeneses of 2,2’-dichlorodiethyl sulfide in hairless guinea pigs. In: Proceedings of the medical defense bioscience review (1993) held in Baltimore Maryland on 10-13, May 1993. Vol. 1. Springfield, VA: US Department of Commerce, 21–30.
Yourick JJ, Dawson JS, Mitcheltree LW. 1992. Sulfur mustard-induced microvesication in hairless guinea pigs: Effect of short-term niacinamide administration. Toxicol Appl Pharmacol 117:104–109.1440603
Yourick JJ, Dawson JS, Mitcheltree LW. 1995. Reduction of erythema in hairless guinea pigs after cutaneous sulfur mustard vapor exposure by pretreatment with niacinamide, promethazine and indomethacin. J Appl Toxicol 15:133–138.7782559
*Zackerinia M, Namdar M, Alavi S, . 1998. Development of hematologic malignancies and aplastic anemia following exposure to mustard gas. Irn J Med Sci 23(1&2):5.
*Zhang B-Z, Wu Y. 1987. Toxicokinetics of sulfur mustard. Chinese J Pharm and Toxicol 1:188–194.
Zhang P, Ng P, Caridha D, . 2002. Gene expressions in Jurkat cells poisoned by a sulphur mustard vesicant and the induction of apoptosis. Br J Pharmacol 137:245–252.12208782
*Zhang Z, Fine JD, Monteiro-Riviere NA. 1998. Uncein may be a potential target for sulfur mustard alkylation. Toxicol Meth 8:27–36.
*Zhang Z, Riviere JE, Monteiro-Riviere A. 1995. Evaluation of protective effects of sodium thiosulfate, cysteine, niacinamide and indomethacin on sulfur mustard-treated isolated perfused porcine skin. Chem Biol Int 96:249–262.
*Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372