# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of sulfur mustard is located in Table 4-1. Sulfur mustard has several synonyms; the most common are “mustard gas”, “H”, and “HD”. The term “mustard gas” may be used interchangeably to identify “sulfur mustard.” “H” refers to undistilled or raw sulfur mustard, which contains a large fraction of impurities (see Table 4-2). “HD” refers to a distilled or purified form of sulfur mustard (see Table 4-3). “HT” is often called sulfur mustard even though it is a mixture of 60% “HD”, <40% Agent T (bis[2-(2-chloroethylthio)ethyl]ether, CAS# 63918-89-8), and a variety of sulfur contaminants and impurities. Most studies on sulfur mustard are based on its distilled or purified form, “HD” (Munro et al. 1999). Other mustard agents, such as “HN” or nitrogen mustard (i.e., bis(2-chloroethyl)methylamine hydrochloride; CAS No. 55-86-7) and lewisite (i.e., 2-chlorovinyldichloroarsine; CAS No. 541-25-3) are related to sulfur mustard. Information about “HN”, “HT”, and lewisite are not included in this document.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of sulfur mustard (HD) is located in Table 4-4. Weapons-grade sulfur mustard can contain stabilizers, starting materials, or by-products formed during manufacturing, and products formed from slow reactions during storage (Munro et al. 1999). The typical compositions of HD and H are illustrated in Tables 4-3 and 4-4, respectively (NRC 1999; Rosenblatt et al. 1996). In general, a residual “heel” (i.e., a gel that will not flow) forms with the ageing of sulfur mustard. The heel can amount to more than 10% of the agent and usually contains 14–53% sulfur mustard, 42–86% cyclic sulfonium ions, and metals, such as iron sulfide (NRC 1999).

Table 4-1 Chemical Identity of Sulfur Mustard

Characteristic | Information | Reference
Chemical name | Bis(2-chloroethyl) sulfide | HSDB 2002
Synonym(s) | β,β’-Dichloroethyl sulfide; β,β’-Dichloroethyl sulphide; 1-Chloro-2-(β-chloroethylthio)ethane; 1,1 ’-Thiobis-(2-chloroethane); 2,2’-Dichlorodiethyl sulfide; 2,2’-Dichlorodiethyl sulphide; 2,2’-Dichloroethyl sulphide; 2,2’-Dichloroethyl sulfide; Bis(β-chloroethyl)sulfide; Bis-(β-chloroethyl)sulphide; Bis(2-chloroethyl)sulphide; Di-2-chloroethyl sulfide; Di-2-chloroethyl sulphide; Dichloro-diethyl-sulphide; Dichlorodiethyl sulfide; Dichloroethyl sulfide; Diethyl sulfide, 2,2’-dichloro; Distilled mustard; Ethane, 1,1 ’-thiobis(2-chloro-; Gelbkreuz; H; HD; Kampstoff “Lost” Lost; Mustard, sulfur; Mustard vapor; Mustard gas; Mustard HD; S mustard; S-lost; S-Lost; S-yperite; Schwefel-Lost; Senfgas; Sulfide, bis(2-chloroethyl); Sulfur mustard gas; Sulfur mustard; Yellow Cross Liquid; Yellow Cross Gas | HSDB 2002
Registered trade name(s) | No data
Chemical formula | C4H8Cl2S | Budavari et al. 1996
Chemical structure | [image] | Budavari et al. 1996; IARC 1975
Identification numbers:
CAS registry | 505-60-2 | HSDB 2002
NIOSH RTECS | WQ0900000 | HSDB 2002
EPA hazardous waste | No data
OHM/TADS | No data
DOT/UN/NA/IMCO shipping | UN 2810 | DOT 2002
HSDB | 336 | HSDB 2002
NCI | No data

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency;HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Material/Technical Assistance Data system; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Typical Composition of Sulfur Mustard (H) from an Old Chemical Munition

Compound | CAS No. | GC/MS peak area percent
Sulfur mustard | 505-60-2 | 62.2
Bis(2-chloroethyl) disulfide | 1002-41-1 | 10.9
1,4-Dithiane | 505-29-3 | 3.2
Bis(2-chloroethyl) trisulfide | 19149-77-0 | 9.6
1,2-Bis(2-chloroethylthio)ethane | 3563-36-8 | 2.6
1,2,3-Trithiolane | — | 2.4
1,4-Thioxane | 15980-15-1 | 0.1
1,2,5-Trithiepane | 6576-93-8 | 0.9
1,2,3,4-Tetrathiane | — | 1.4
1,2-Dichloroethane | 107-06-2 | 3.2
HD tetrasulfide | — | 0.6
Tetrachloroethene | 127-18-4 | 0.3
Sulfur | 7704-34-9 | 0.5
Other | — | 1.3

GC/MS = gas chromatography/mass spectrometry

Source: Rosenblatt et al. 1996

Table 4-3 Typical Composition of Sulfur Mustard (HD) in 1-Ton Storage Containers (Aberdeen, Maryland)

Compound | CAS No. | Mole percent
Sulfur mustard | 505-60-2 | 91.38
Q sulfonium | 30843-67-5 | 6.08
2-Chloroethyl 4-chlorobutyl sulfide | 114811-35-7 | 0.86
1,4-Dithiane | 505-29-3 | 0.81
1,2-Dichloroethane | 107-06-2 | 0.35
Bis-3-chloropropyl sulfide | 22535-54-2 | 0.18
2-Chloropropyl 3′-chloropropyl sulfide | — | 0.18
2-Chloroethyl 3-chloropropyl sulfide | 71784-01-5 | 0.14
1-Chloropropyl 2-chloroethyl sulfide | — | 0.02
1,4-Thioxane | 15980-15-1 | <0.01

Source: NRC 1999

Table 4-4 Physical and Chemical Properties of Sulfur Mustard

Property | Information | Reference
Molecular weight | 159.08 | Budavari et al. 1996
Color | Clear | Budavari et al. 1996
Color | Pale yellow, black if impure | Munro et al. 1999
Physical state | Oily liquid | Budavari et al. 1996
Melting point | 13-14 °C | Budavari et al. 1996
Boiling point | 217.5 °C | Budavari et al. 1996
Density:
Density: | 1.338 at 13 °C | Budavari et al. 1996
Density: | 1.2685 at 25 °C | Rosenblatt et al. 1996
Odor | Weak, sweet, agreeable odor | Budavari et al. 1996
Odor threshold:
Water | No data
Air | 0.6 mg/m^3^ | Bowden 1943
Solubility:
Water | 920 mg/L at 22 °C | Rosenblatt et al. 1996
Water | 684 mg/L at 25 °C | Seidell 1941
Organic solvent(s) | Soluble in alcohol, ether, acetone, and benzene; miscible with petroleum ether | HSDB 2002
Organic solvent(s) | Soluble in fat solvents and other common organic solvents | IARC 1975
Partition coefficients:
Log K_ow_ | 2.41 | HSDB 2002
Log K_ow_ | 1.37 | Rosenblatt et al. 1996
Log K_oc_ | 2.43 | HSDB 2002
Vapor pressure:
at 22 °C | 0.082 mmHg | Rosenblatt et al. 1996
at 25 EC | 0.1059 mmHg | Rosenblatt et al. 1996
Henry’s law constant
Henry’s law constant | 2.4×10^−5^ atm-m^3^/mol | Opresko et al. 1998
Henry’s law constant | 1.87×10^−5^ atm-m^3^/mol | Rosenblatt et al. 1996
Autoignition temperature | No data
Flashpoint | 221 EF | Sax 1989
Conversion factors: | No data
Explosive limits | No data