# APPENDIX D ACUTE EXPOSURE GUIDELINE LEVELS (AEGLS) FOR SULFUR MUSTARD

The National Advisory Committee for the Acute Exposure Guideline Levels for Hazardous Substances has developed acute exposure guideline levels (AEGLs) for sulfur mustard (NAC/AEGL 2001). The AEGLs are threshold exposure limit values for the general public applicable to emergency exposure periods ranging from 10 minutes to 8 hours. For each chemical, three levels of AEGLs, distinguished by varying degrees of severity of toxic effects, are developed: at exposure levels above the AEGL-1, the general population could experience notable discomfort, irritation, or asymptomatic, nonsensory effects; above AEGL-2, the general population could experience irreversible or other serious, long lasting health effects or impaired ability to escape; and above AEGL-3, the general population could experience life-threatening health effects or death. At each AEGL level, values are developed for five exposure periods: 10 minutes, 30 minutes, 1 hour, 4 hours, and 8 hours.

The derivation of the AEGLs for sulfur mustard presented below was excerpted from NRC (2003).

## 5 DATA ANALYSIS FOR AEGL-l

### 5.1 Summary of Human Data Relevant to AEGL-l

Walker et al. (1928) reported that four of seven men exposed to sulfur mustard at 0.001 mg/L (1 mg/m^3^) for 5-45 min exhibited conjunctivitis, and two exhibited skin burns. It was also reported that, of 17 men exposed at 0.0005 mg/L (0.5 mg/m^3^) for 10-45 min (5-22.5 mg^.^min/m^3^), six exhibited conjunctivitis, and one had a skin burn. Three of 13 men exposed for 10-30 min at 0.0001 mg/L (0.1 mg/m^3^; Ct of 1-3 mg^.^min/m^3^) showed slight but distinct conjunctivitis. Although not of a severity consistent with an AEGL-2 level, those effects are of greater severity than would be acceptable for AEGL-l development. Guild et al. (1941) also conducted experiments using humans and reported that (1) exposure to Ct values <70 mg^.^min/m^3^ would result in mild conjunctival responses that would not be indicative of a casualty (temporary loss of vision); (2) Ct values of 70-100 mg^.^min/m^3^ would produce some casualties and; (3) Ct values >l00 mg^.^min/m^3^ would be expected to produce disabling ocular effects of several days’ duration. Because the subjects wore respiratory protection, effects on the respiratory tract could not be determined.

In experiments with human volunteers exposed to varying concentration-time regimens, Anderson (1942) found that an exposure concentration-time product of 12 mg^.^min/m^3^ was without effects and 30 mg^.^min/m^3^ represented the upper range for mild effects (conjunctival injection and minor discomfort with no functional decrement). Ct products slightly higher than that (e.g., 34-38.1 mg^.^min/m^3^) were, however, also without appreciable effects, thereby indicating that the response to 30 mg^.^min/m^3^ is consistent with AEGL-l effects.

Odor thresholds of 1 mg^.^min/m^3^ (Bloom 1944), 0.15 mg/m^3^ (Ruth 1986) and 0.6 mg/m^3^ (Dudley and Wells 1938; Bowden 1943; Fuhr and Krakow 1945) have been reported.

Analysis of the exposure-effect values from the human studies indicated that the 12-mg^.^min/m^3^ value represented a defensible estimate of the threshold for effects consistent with the AEGL-l definition. The 12-mg^.^min/m^3^ exposure was without a symptomatic effect and, therefore, provides the basis for protective AEGL-l values consistent with the AEGL- 1 definition.

### 5.2 Summary of Animal Data Relevant to AEGL-l

The effects described in the animal studies tend to be of a greater severity than those associated with AEGL-l (i.e., signs of severe ocular irritation, body weight loss, respiratory depression, evidence, evidence of respiratory tract histopathology, etc.). There were no definitive exposure-response data in animals that were considered appropriate for the development of AEGL-l values.

### 5.3 Derivation of AEGL-l

The most tenable AEGL-l values were developed using data reported by Anderson (1942) in which three to four human volunteers were exposed to agent HD at varying concentration-time regimens. In an analysis of those data, Anderson found that an exposure concentration-time product of 30 mg^.^min/m^3^ represented the upper range for mild effects (conjunctival injection and minor discomfort with no functional decrement) and that 12 mg^.^min/m^3^ represented a threshold for such effects. The 12 mg^.^min/m^3^ represents a defensible estimate of the threshold for AEGL-1 effects. The 12-mg^.^min/m^3^ exposure resulted in only minor conjunctival injection and no sensation of irritation. Ocular effects appear to be the most sensitive indicator of sulfur mustard exposure and toxicity, thereby justifying ocular irritation as an appropriate end point for development of AEGL values. All of the data considered were from human subjects, and, therefore, the uncertainty factor (UF) application to the 12-mg^.^min/m^3^ value was limited to 3 for protection of sensitive individuals. The adjustment is considered appropriate for acute exposures to chemicals whose mechanism of action primarily involves surface contact irritation of ocular and/or respiratory tract rather than systemic activity that involves absorption and distribution of the parent chemical or a biotransformation product to a target tissue. In addition, Anderson (1942) noted that there was little variability in the ocular responses among the individuals participating in the study. That the AEGL-1 values are based on a sensitive end point is also reflected in that they are below reported odor thresholds (0.6 mg/m^3^ and 1 mg^.^min/m^3^).

Because exposure-response data were unavailable for all of the AEGL- specific exposure durations, temporal extrapolation was used in the development of AEGL-1 values for the AEGL-specific time periods. The concentration-exposure time relationship for many irritant and systemically acting vapors and gases can be described by C^n^ x t = k, where the exponent n ranges from 0.8 to 3.5 (ten Berge et al. 1986). Analyses of available data regarding AEGL-1 type effects reported by Reed (1918), Reed et al. (1918), Guild et al. (1941), and Anderson (1942) indicate that for the exposure periods up to several hours, the concentrationexposure time relationship is a near-linear function (i.e., Haber’s law where n = 1 for C^n^ x t = k) as shown by n values of 1.11 and 0.96 for various data sets consistent with AEGL-l effects (Appendix B). Therefore, an empirically derived, chemical-specific estimate of n = 1 was used, rather than a default value, based on the ten Berge (1986) analyses. The derivation of the exponent (n) utilized human response data where 75-100% of the responders showed a mild response that would be consistent with the definition of AEGL-l effects. In addition, the data provided by Anderson (1942) were indicative of a linear concentration-time relationship. The AEGL-l values developed using the 12-mg^.^min/m^3^ exposure value reported by Anderson (1942) are shown in Table 2-9. The AEGL-l values are below the odor threshold for sulfur mustard (0.6 mg/m^3^ and 1 mg^.^min/m^3^).

## 6 DATA ANALYSIS FOR AEGL-2

### 6.1 Summary of Human Data Relevant to AEGL-2

Quantitative data regarding the human experience and AEGL-2 level effects are limited to responses ranging from signs of mild ocular irritation to ocular irritation that impairs normal visual function. Reed (1918) reported that 20-45 min exposure of himself and a volunteer at 1.2 mg/m^3^ resulted in severe ocular irritation and dermal lesions. In a report of a subsequent experiment, Reed et al. (1918) noted that exposure of human volunteers at 0.1- 4.3 mg/m^3^ for 5-45 min produced ocular irritation and skin burns (0.5 mg/m^3^ for 30 min) and very severe conjunctivitis, photophobia, skin bums, and nasopharyngeal exfoliation (1.0 mg/m^3^ for 45 min). The analytical techniques used in these experiments were suspect; actual exposures were likely 30-40% higher. The report by Guild et al. (1941) of human exposure experiments did not provide findings of effects consistent with the AEGL-2 definition. Anderson (1942) reported on a series of human exposures resulting in varying degrees of ocular responses ranging from nonsymptomatic ocular injection to ocular irritation that required medical treatments and was considered severe enough to impair normal function.

### 6.2 Summary of Animal Data Relevant to AEGL-2

With the exception of a study reported by Warthin and Weller (1919) regarding the effects in rabbits following acute exposure, there is little exposure-response data for animals consistent with AEGL-2-severity effects. Weller and Warthin reported severe ocular effects and dermal burns in rabbits exposed for 12 h to sulfur mustard at 130 mg/m^3^. That study, however, was compromised by the use of single animals and lacks detail. Kumar and Vijayaraghavan (1998) reported alterations in purine catabolism exposed for 1 h to sulfur mustard at 21.2- 84.6 mg/m^3^ but those exposures also represented 0.5, 1.0, and 2.0 LC^50^ responses. Statistically significant reductions in body weights were also observed for the mice at 14 d following a 1-h exposure to concentrations at 16.9- 42.3 mg/m^3^; however at least some of the exposures were also associated with lethality. Dogs, rats, mice, and guinea pigs exposed continuously to sulfur mustard at 0.001 mg/m^3^ or discontinuously (6.5 h/d, 5 d/wk) at 0.1 mg/m^3^ for up to 52 wk did not exhibit effects consistent with the AEGL-2 definition (McNamara et al. 1975).

Table 2-9 AEGL-l Values for Sulfur Mustard (ppm [mg/m^3^])^a^

10-min | 30-min | 1-h | 4-h | 8-h
0.06 (0.40) | 0.02 (0.13) | 0.01 (0.067) | 0.003 (0.017) | 0.001 (0.008)

a The AEGL-1 values are at or below the odor threshold for sulfur mustard.

### 6.3 Derivation of AEGL-2

The AEGL-2 values for sulfur mustard were developed using data from Anderson (1942). The study utilized three or four human volunteers’ exposed to varying concentrations of sulfur mustard (1. 7-15.6mg/m^3^) for time periods varying from 2 to 33 min. Anderson considered a Ct value of 60 mg^.^min/m^3^ as the lowest concentration-time product for which ocular effects could be characterized as military casualties and that personnel exposed might be ineffective for up to (but no more than) 7 d. Effects included irritation, soreness, and widespread conjunctivitis, frequently accompanied by chemosis and photophobia. The 60-mg^.^min/m^3^ exposure was used as the basis for developing the AEGL-2 values because it is representative of an acute exposure causing an effect severe enough to impair normal visual function and, although not irreversible, would certainly result in potential for additional injury. The ocular irritation and damage were also considered appropriate as a threshold estimate for AEGL-2 effects, because the eyes are generally considered the most sensitive indicator of sulfur mustard exposure, and irritation would likely occur in the absence of vesication effects and severe pulmonary effects. The fact that the AEGL-2 is based on human data precludes the use of an interspecies UF. A factor of 3 was applied for intraspecies variability (protection of sensitive populations). The factor was limited to 3 under the assumption that the primary mechanism of action of sulfur mustard involves a direct effect on the ocular surface and that the response will not vary greatly among individuals (as noted by Anderson [1942]). A modifying factor of 3 was applied to accommodate potential onset of long-term ocular or respiratory effects. It was justified by the absence of long-term follow-up in the subjects of the Anderson (1942) study to confirm or deny development of permanent ocular or respiratory tract damage. Because the factors of 3 each represent a logarithmic mean (3.16) of 10, their product is 3.16 x 3.16 = 10. Further reduction by the application of additional modifying factors was not warranted because of the use of a sensitive indicator representing an AEGL-2 effect of marginal severity. As is the case for AEGL-1 values, time scaling was conducted using an n of 1 for all time points (Appendix B). The resulting AEGL-2 values are shown in Table 2-10, and their derivation is presented in Appendix A. Similar to the AEGL-l values, all of the AEGL-2 values are at or below the reported odor thresholds (0.6 mg/m^3^ and 1 mg^.^min/m^3^).

Table 2-10 AEGL-2 Values for Sulfur Mustard (ppm [mg/m^3^])^a^

10-min | 30-min | 1-h | 4-h | 8-h
0.09 (0.60) | 0.03 (0.20) | 0.02 (0.10) | 0.004 (0.025) | 0.002 (0.013)

a The AEGL-2 values are at or below odor threshold for sulfur mustard.

## 7 DATA ANALYSIS FOR AEGL-3

### 7.1 Summary of Human Data Relevant to AEGL-3

Human lethality data are limited to an inhalation LCt_50_ estimate of 1,500 mg^.^min/m^3^ and percutaneous LCt^50^ estimate of 10,000 mg^.^min/m^3^ estimated from animal data (DA 1974). The NRC (1997) concluded that an estimated LCt^50^ for humans of 900 mg^.^min/m^3^ developed by the U. S. Army based on an average of animal LCt^50^ data was scientifically valid but was developed in reference to healthy male military personnel and does not apply to civilians.

### 7.2 Summary of Animal Data Relevant to AEGL-3

Various lethality values have been reported for laboratory species exposed to sulfur mustard. Vijayaraghavan (1997) reported a 1-h LC^50^ of 42.5 mg/m^3^ for mice (head-only exposure). In a follow-up study reported by Kumar and Vijayaraghavan (1998), 1-h exposure of mice at 21.2 mg/m^3^ did not result in lethality. Lethality estimates were based on deaths occurring up to 14 d after exposure. Langenberg et al. (1998) reported a 5-min LCt_50_ of 800 mg^.^min/m3 for rabbits (deaths determined up to 96 h after exposure). These studies utilized up-to-date exposure and analytical systems and provided lethality estimates based on adequate numbers of animals evaluated at post exposure time frames appropriate for the known latency in sulfur-mustard-induced lethality.

### 7.3 Derivation of AEGL-3

As noted in Section 3.1.4, the lethality data from earlier reports were not verifiable but are not inconsistent with those from later studies. The 1-h LC_50_ values for rats and mice derived from the 840 and 860 mg^.^min/m^3^ 60-min LCt5o values reported by Fuhr and Krakow (1945) are similar to the lower confidence limit of the mouse 1-h LC_50_ reported by Vijayaraghavan (1997) (i.e., 14.0, 14.3, and 13.5 mg/m^3^, respectively; the corresponding Ct values are 840,858, and 810 mg^.^min/m^3^). The values are also similar to a 1-h LC_50_ of 13.3 mg/m^3^ for guinea pigs extrapolated (assuming C^1^ x t = k) from the 5-min LCt_50_ of 800 mg^.^min/m^3^ reported by Langenberg et al. (1998). However, the values from the earlier studies are not verifiable. In the inhalation toxicity study by Vijayaraghavan (1997), mice were exposed head only) for 60 min to sulfur mustard at concentrations of 0.0, 8.5, 16.9, 21.3, 26.8, 42.3 or 84.7 mg/m^3^. The study investigator derived a 60-min LC_50_ of 42.5 mg/m^3^ based on lethality at 14 d post exposure (95% confidence interval: 13.5-133.4 mg/m^3^). In a follow-up study (Kumar and Vijayaraghavan 1998), there was no mortality in mice exposed at 0.5 LC_50_ mg/m^3^). Therefore, the 1-h exposure at 21.2 mg/m^3^ was selected as an estimate of the lethality threshold in mice.

When compared with the human exposure-effect data, the 21.2-mg/m^3^ concentration (Ct of 1,272 mg^.^min/m^3^ for a 60-min exposure) is not an exposure that has been associated with lethality in humans (see Section 2.1). An intraspecies UF of 3 was applied for protection of sensitive individuals. This adjustment was considered appropriate for acute exposures to chemicals whose mechanism of action primarily involves surface contact irritation of ocular and/or respiratory tract tissue rather than systemic activity that involves absorption and distribution of the parent chemical or a biotransformation product to a target tissue. An interspecies UP was limited to 3 because available data do not suggest that humans are notably more sensitive than animals regarding lethality from inhalation exposure to sulfur mustard. The mechanism of pulmonary injury leading to lethality appears to be a function of the direct contact of an alkylating agent with epithelial tissue. This mechanism is likely to be more similar than different across mammalian species. Furthermore, the AEGL-3 values resulting from the aforementioned complement of UFs (total UF adjustment was 10; see Section 6.3) are equivalent to exposures known to cause only mild ocular effects in humans. The modifying factor of 3 utilized in the development of AEGL-2 values to account for uncertainties regarding the latency and persistence of the irritant effects of low-level exposure to sulfur mustard was not applied for AEGL-3 because lethality of the mice was assessed at 14 d post exposure in the key studies by Vijayaraghavan (1997) and Kumar and Vijayaraghavan (1998).

For derivation of the AEGL-3 values, there was uncertainty regarding the validity of applying linear extrapolation based on ocular effects to concentration-time extrapolations for lethality. As reported by ten Berge et al. (1986), the concentration-time relationship for many irritant and systemically acting vapors and gases can be described by C^n^ x t = k, where the exponent n ranges from 0.8 to 3.5. Therefore, in the absence of chemical-specific lethality data, time scaling was performed using exponential extrapolation (n = 3) for shorter time periods and linear extrapolation (n = 1) for longer time periods, thereby providing a somewhat more conservative (i.e., protective) estimate of the AEGL-3 values than would be obtained using an n value based on ocular irritation. The AEGL-3 values were derived by scaling from the 1-h LC_50_ of 21.2 mg/m^3^ reported by Kumar and Vijayaraghavan (1998) using C^n^ x t = k where n = l or 3 (Appendix A). The concentration-time constant, k, was 1,272 mg^.^min/m^3^ where n = 1 and 571,687.68 mg^.^min/m^3^ where n = 3. The AEGL-3 values are shown In Table 2-11, and their derivation is presented in Appendix A. The 4-h and 8-h AEGL-3 values are at or below reported odor thresholds.

Table 2-11 AEGL-3 Values for Sulfur Mustard (ppm [mg/m^3^])

10 min | 30 min | 1 h | 4 h | 8 h
0.59 (3.9) | 0.41 (2.7) | 0.32 (2.1) | 0.08 (0.53) | 0.04 (0.27)

Note: The 4 –h and 8 – h AEGL-3 values are below the odor threshold for sulfur mustard.

When comparing the Ct values generated by the draft AEGL-3 numbers the human exposure data, any further reduction appears indefensible. The Ct values resulting from theAEGL-3 numbers (i.e., 39-130 mg^.^min/m^3^) are similar to cumulative exposures shown to cause only ocular irritation in humans (Guild et al. 1941; Anderson 1942) and are similar to the ECt_50_ of 100 mg^.^min/m^3^ for severe ocular effects (for soldiers) determined by Reutter and Wade (1994) and the NRC (1997). Furthermore, the AEGL-3 values are nearly similar to those developed using the human lethality estimate of 900 mg^.^min/m^3^ (Reutter and Wade 1994) that was derived from multiple-species animal data and reviewed by the NRC (1997). Assuming a 3-fold reduction for estimation of a lethality threshold ([900 mg^.^min/m^3^]/3 = 300 mg^.^min/m^3^) and another 3-fold reduction for consideration of sensitive populations ([300 mg^.^min/m^3^]/3 = 100 mg^.^min/m^3^), the resulting AEGL-3 values from the Reutter and Wade (1994) and NRC (1997) reports would be 4.8, 3.3, 1.7, 0.42, and 0.21 mg/m^3^ for 10 min, 30 min, and 1, 4, 8 h, respectively. These highly derivative estimates are comparable to, and supportive of, AEGL-3 estimates derived from the experimental data of Kumar and Vijayaraghavan (1998) (see Table 2-11).

## 8 SUMMARY OF AEGLs

### 8.1 AEGL Values and Toxicity End Points

Human data are available from several independent sources that define exposure-response for AEGL-l and AEGL-2 effects. Although a definitive demarcation of the exposure-response for sensitive populations was not provided by those data, the human data eliminated the uncertainties inherent in the use of data from animal studies. Both the AEGL-l and AEGL-2 values were based on effect end points consistent with the respective AEGL definitions (i.e., threshold for barely discernible ocular irritation [AEGL-l] and threshold for ocular irritation indicative of functional impairment [AEGL-2]). Areas of uncertainty were associated with the sensitive responders and the relationship between ocular effects and the onset of respiratory effects. Human data from which to develop AEGL-3 values were unavailable. The AEGL-3 was based on an estimated lethality threshold from studies in mice (Vijayaraghavan 1997; Kumar and Vijayaraghavan 1998). When compared with human exposure-response data and lethality estimates, the mouse lethality data were considered a defensible approach to AEGL-3 derivation. AEGL-3 values based on a human lethality estimate of 900 mg^.^min/m^3^ (Reutter and Wade 1994; NRC 1997) were very similar to those developed using the animal data of Vijayaraghavan (1997) and Kumar and Vijayaraghavan (1998). An estimate of theoretical excess cancer risk based upon a geometric mean of inhalation slope factors developed using various data sets and procedures revealed that exposure concentrations representing a theoretical 10^−4^ lifetime risk were similar to the AEGL-3 exposure concentration values. The exposures for theoretical excess lifetime cancer risk at 10^−5^ and 10^−6^ levels would be correspondingly reduced. The use of excess cancer risk estimates in setting AEGL values is precluded by the uncertainties involved in assessing excess cancer risk following a single acute exposure of 8-h or less duration, by the relatively small population exposed in an emergency release situation, and by the potential risks associated with evacuations.

The AEGL values for sulfur mustard are summarized in Table 2-12. Extrapolation to exposure durations of less than 10 min is not recommended in the absence of careful evaluation of existing data and comparison of any derivative values with those data.

### 8.2 Comparison with Other Standards and Guidelines

Comparison of the draft AEGL values with other existing standards and guidelines is shown in Table 2-13. No other standards or guidelines from other agencies or programs (e.g., NIOSH, ERPG, ACGIH, MAK, MAC, and OSHA) were available.

### 8.3 Data Adequacy and Research Needs

The AEGL-1 values are based on human data and are considered estimates for exposures that would cause no significant health effects or sensations of irritation beyond minimal conjunctivitis.

Table 2-12 Summary of AEGL Values for Sulfur Mustard^a^

AEGL Level | 10 min | 30 min | 1 h | 4 h | 8 h
AEGL-1^a^ (Nondisabling) | 0.06 ppm (0.40 mg/m^3^) | 0.02 ppm (0.13 mg/m^3^) | 0.01 ppm (0.067 mg/m^3^) | 0.003 ppm (0.017 mg/m^3^) | 0.001 ppm (0.008 mg/m^3^)
AEGL-2^a^ (Disabling) | 0.09 ppm (0.60 mg/m^3^) | 0.03 ppm (0.20 mg/m^3^) | 0.02 ppm (0.10 mg/m^3^) | 0.004 ppm (0.025 mg/m^3^) | 0.002 ppm (0.013 mg/m^3^)
AEGL-3^a^ | 0.59 ppm (3.9 mg/m^3^) | 0.41 ppm (2.7 mg/m^3^) | 0.32 ppm (2.1 mg/m^3^) | 0.08 ppm (0.53 mg/m^3^) | 0.04 ppm (0.27 mg/m^3^)

a A AEGL-1 and AEGL-2 values, and the 4- and 8-h AEGL-3 values are at or below the odor threshold for sulfur mustard.

The ocular irritation on which the AEGL-l and AEGL-2 values are based is the most sensitive response to sulfur mustard vapor. The AEGL-2 values provide Ct exposures that are well below those known to induce severe ocular effects in normal humans (i.e., 70-90 mg^.^min/m^3^). AEGL-3 values provide Ct values (39-130 mg^.^min/m^3^) that are at levels known to cause moderate to severe ocular irritation and possible respiratory tract irritation in human subjects Anderson 1942; Guild et al. 1941) but no life-threatening effects or death. Although the overall database for acute inhalation exposure to sulfur mustard is not extensive, the AEGL values are supported by the available data.

The absence of multiple-species lethality data for acute exposures limits a thorough understanding of variability. Data providing definitive demarcation of the threshold for serious and/or irreversible effects would provide a more complete picture of responses resulting from acute inhalation exposure to sulfur mustard. That is especially relevant to assessing the potential for serious respiratory tract damage or permanent ocular pathology following acute exposure. Although sulfur mustard is a genotoxic chemical capable of inducing tumors in animals and humans, the carcinogenic potential of acute inhalation exposures has not been defined.

Table 2-13 Comparison of AEGL Values for Sulfur Mustard with Other Extant Standards and Guidelines

Guideline | 10 min | 30 min | 1 h | 4 h | 8 h | Other
AEGL-1 | 0.40 mg/m^3^ (0.06 ppm) | 0.13 mg/m^3^ (0.02 ppm) | 0.067 mg/m^3^ 0.01 ppm) | 0.017 mg/m^3^ (0.003 ppm) | 0.008 mg/m^3^ 0.001 ppm)
AEGL-2 | 0.60 mg/m^3^ (0.09 ppm) | 0.20 mg/m^3^ (0.03 ppm) | 0.10 mg/m^3^ (0.02 ppm) | 0.025 mg/m^3^ (0.004 ppm) | 0.013 mg/m^3^ (0.002 ppm)
AEGL-3 | 3.9 mg/m^3^ (0.59 ppm) | 2.7 mg/m^3^ (0.41 ppm) | 2.1 mg/m^3^ (0.32 ppm) | 0.53 mg/m^3^ (0.08 ppm) | 0.27 mg/m^3^ (0.04 ppm)
Department of the Army/Civilian Occupational WPL^a^ | | | | | 0.003mg/m^3^ (0.0005 ppm)
Department of the Army/Civilian GPL^b^ | | | | | | 0.0001 mg/m^3^ (1.5 × 10^−5^ ppm)
CDC-CSEPP (Thacker, 1994)^c^ | | | | | | 2.0 mg^.^min/m^3^ (0.3 ppm)

a Worker Population Exposure Limit (DA 1991, 1997; DHHS 1988), 8-h TWA, 5 d/wk

b General Population Limit (no observable effects), 24-h TWA, 7 d/wk

c Recommended acute effects levels for determining emergency evacuation distances in the Chemical Stockpile Emergency Preparedness Program (CSEPP); no set exposure time.

## 9 REFERENCES

Anderson, J.S. 1942. The effect of mustard gas vapour on eyes under Indian hot weather conditions. CDRE Report No. 241. Chemical Defense Research Establishment (India).
Bloom et al. 1944. Informal monthly progress report on toxicity of chemical warfare agents. OSRD Informal Report 9-4-1-12. January 10, 1944. (As cited in DNA 1993.)
Bowden, E. 1943. Median detectable concentrations by odor of plant run mustard, plant run Lewisite and pilot plant ethyl nitrogen mustard. ADB 969801, TDMR 615 (April 1943).
Crump, K.S., and R.B. Howe. 1984. The multistage model with a time-dependent dose pattern: Applications to carcinogenic risk assessment. Risk Analysis 4:163–176.
DA (U.S. Department of the Army). 1974. Chemical agent data sheets. Vol. 1. Tech. Report E-SR-74001, Edgewood Arsenal Special Report, U.S. Department of the Army, Defense Technical Information Center, Alexandria, V A.
DA (U.S. Department of the Army). 1991. Occupational Health Guidelines for the Evaluation and Control of Occupational Exposure to Mustard Agents H, HD, and HT. Dept. of the Army, Pamphlet 40-173, Washington., DC.
DA (U.S. Department of the Army). 1997. The Army Chemical Agent Safety Program Army Regulation AR 385-61. Headquarters, Department of the Army, Washington, DC.
DHHS (U.S. Department of Health and Human Services). 1988. Final recommendations for protecting the health and safety against potential adverse effects of long-term exposure to low doses of agents: GA, GB, VX, mustard agent (H HD, HT), and lewisite (L). U.S. Department of Health and Human Services Centers for Disease Control. Fed. Reg. 53(50): 8504–8507.
Dudley, H.C., and W. J. H. B. Wells. 1938. The detection of HS by odor. ADB 959500, EATR 249 (March 1936). (As cited in personal communication from S.Reutter, U.S. Army Edgewood Research Development and Engineering Center, APG, MD, October 1995.)
Fuhr, I., and E.H. Krakow. 1945. Median lethal concentrations of H for mice and rats. For various exposure times. MDR 21, March 21. (As cited in McNarnara et al. 1975.)
Guild, W.J., K.P. Harrison, A. Fairly, and A.E. Childs. 1941. The effect of mustard gas vapour on the eyes. Porton Report No.2297, Serial No. 12, 8 November 1941.
Kumar O., and R. Vijayaraghavan. 1998. Effect of sulphur mustard inhalation exposure on some urinary variables in mice. J. Appl. Toxicol. 18:257–259.9719425
Langenberg J.P., G.P. van der Schans, H.E.T. Spruit, . 1998. Toxicokinetics of sulfur mustard and its DNA-adducts in the hairless guinea pig. Drug. Chem. Toxicol. 21(Suppl. 1):131–147.10028407
McNamara B.P., E.J. Owens, M.K. Christensen, F.J. Vocci, D.F. Ford, and H. Rozimarek. 1975. Toxicological basis for controlling levels of mustard in the environment. EASP EBSP 74030. Biomedical Laboratory, Department of the Army, Headquarters, Edgewood Arsenal, Aberdeen Proving Ground, MD.
NRC (National Research Council). 1985. Emergency and continuous exposure guidance levels for selected airborne contaminants, Vol. 5. Washington, DC: National Academy Press.
NRC (National Research Council). 1986. Criteria and methods for preparing emergency exposure guidance level (EEGL), short-term public emergency guidance level (SPEGL), and continuous exposure guidance level (CEGL) documents. Washington, DC: National Academy Press. Appendix F, pp. 25–27.
NRC (National Research Council). 1997. Review of acute human-toxicity estimates for selected chemical-warfare agents. Washington, DC: National Academy Press.
Reed, C.I. 1918. The minimum concentration of mustard gas effective for man. Preliminary Report. Report 318. War Department, Med. Div., C.W.S. Pharmacol. Res. Sec. Amer. Univ. Exp. Station, War Dept. October 26, 1918.
Reed C.I., E.F. Hopkins, and C.F. Weyand. 1918. The minimum concentration of mustard gas effective for man. Final Report. Report 329. War Department, Med. Div., C.W.S., Pharmacol. Res. Sec. Amer. Univ. Exp. Station, War Dept. December 2, 1918.
Reutter S.A., and J.V. Wade. 1994. “Table 1; Summary of Existing and Recommended Estimates (U),” unclassified summary table. In: Review of existing toxicity data and human estimates for selected chemical agents and recommended human toxicity estimates appropriate for defending the soldier. ERDEC-SP-O 18. U.S. Department of the Army, Edgewood Research Development and Engineering Center, Aberdeen Proving Ground, MD (secret report).
Ruth, J.H. 1986. Odor Thresholds and Irritation Levels of Several Chemical Substances: A review. Am. Ind. Hyg. Assoc. J. 47:A142–A151.3706135
ten Berge W.F., A. Zwart, and L.M. Appelman. 1986. Concentration-time mortality response relationship of irritant and systemically acting vapours and gases. J. Hazard Materials 13:301–309.
U.S. Army Center for Health Promotion and Preventive Medicine (USACHPPM). 2000. Evaluation of Airborne Exposure Limits for Sulfur Mustard: Occupational and General Population Exposure Criteria. Aberdeen Proving Ground, Maryland. Technical Report 47-EM-3767-00.
Vijayaraghavan, R. 1997. Modifications of breathing pattern induced by inhaled sulphur mustard in mice. Arch. Toxicol. 71:157–164.9049052
Walker H.W., B.F. Smith, and A. Blake. 1928. Summary and Discussion of Available Mustard Gas Data from Field Tests Conducted Prior to 1928. Report. No.462, Chemical Warfare Service, Edgewood, Arsenal, Edgewood, MD.
Warthin A.S., and C.V. Weller. 1919. The lesions of the respiratory and gastrointestinal tracts produced by mustard gas (dichloroethyl sulphide). J. Lab. Clin. Med. 4:229–264.
Watson A.P., and G.D. Griffin. 1992. Toxicity of vesicant agents scheduled for destruction by the chemical stockpile disposal program. Environ. Health Perspect. 98:259–280.1486858

## APPENDIX A Derivations of AEGL Values Derivation of AEGL-l

Key Study: | Anderson (1942)
Toxicity End point: | Exposure concentration-time product of 12 mg^.^min/m^3^ represented the threshold for ocular effects (conjunctival injection and minor discomfort with no functional decrement) for human volunteers exposed to agent HD at varying exposure regimens. The eye is generally considered to be the most sensitive organ/tissue relative to agent HD exposure.
Scaling: | The concentration-time relationship for many irritant and systemically acting vapors and gases can be described by C^n^ × t == k, where the exponent n ranges from 0.8 to 3.5 (ten Berge et al. 1986). Analysis of available data indicated n to be near unity (Appendix B), hence, C^1^ × t = k.
Uncertainty factors: | Total adjustment of 3. A factor of 3 was applied for intraspecies variability (protection of sensitive populations). This factor was limited to 3 under the assumption that the primary mechanism of action of agent HD involves a direct effect on the ocular surface and that the response will not vary greatly among individuals. In addition, subjects in the Anderson (1942) study exhibited little variability in ocular response.

Because the AEGL-l is based on human data, the interspecies UF is 1.

10-min AEGL-1: | C^1^ × 10 min = 12 mg^.^min/m^3^; C = 1.2 mg/m^3^; 10-min AEGL-1 = (1.2 mg/m^3^)/3 = 0.40 mg/m^3^; (0.06 ppm)
30-min AEGL-1: | C^1^ × 30 min= 12 mg^.^min/m^3^; C = 0.4 mg/m^3^; 30-min AEGL-1 = (0.4 mg/m^3^)/3 = 0.13 mg/m^3^; (0.02 ppm)
1-h AEGL-1: | C^1^ × 60 min = 12 mg^.^min/m^3^; C= 0.2 mg/m^3^; 1-h AEGL-1 = (0.2 mg/m^3^)/3 = 0.067 mg/m^3^; (0.01 ppm)
4-h AEGL-1: | C^1^ × 240 min = 12 mg^.^min/m^3^; C= 0.05 mg/m^3^; 4-h AEGL-1 = (0.05 mg/m^3^)/3 = 0.017 mg/m^3^; (0.003 ppm)
8-h AEGL-1: | C^1^ × 480 min = 12 mg^.^min/m^3^; C = 0.025 mg/m^3^; 8-h AEGL-1 = (0.025 mg/m^3^)/3 = 0.008 mg/m^3^; (0.001 ppm)

### Derivation of AEGL-2

Key study: | Anderson (1942)
Toxicity end point: | A concentration-time product of 60 mg^.^min/m^3^ was considered the lowest exposure causing ocular effects (we1lmarked, generalized conjunctivitis, edema, photophobia, and irritation) resulting in effective performance decrement and characterized as a military casualty requiring treatment for up to 1 wk.
Scaling: | The concentration-time relationship for many irritant and systemically acting vapors and gases may be described by C^n^ × t = k, where the exponent n ranges from 0.8 to 3.5 (ten Berge et al. 1986). Analysis of available data indicated n to be near unity (Appendix B), hence, C^1^ × t = k.
Uncertainty Factors: | Total adjustment of 10. A factor of 3 was applied for intraspecies variability (protection of sensitive populations). This factor was limited to 3 under the assumption that the primary mechanism of action of agent HD involves a direct effect on the ocular surface and that this response will not vary greatly among individuals. Because the AEGL-l is based on human data, the interspecies UF is 1. A modifying factor of 3 was applied to accommodate potential onset of long-term ocular or respiratory effects.; Because the factors of 3 each represent a logarithmic mean (3.16) of 10, their product is 3.16 x 3.16 = 10.

10-min AEGL-2: | C^1^ × 10 min = 60 mg^.^min/m^3^; C = 6 mg; 10-min AEGL-2 = (6 mg/m^3^)/10 = 0.60 mg/m^3^; (0.09 ppm)
30-min AEGL-2: | C^1^ × 30 min= 60 mg^.^min/m^3^; C = 2.00 mg; 30-min AEGL-2 = (2.00 mg/m^3^)/10 = 0.20 mg/m^3^; (0.03 ppm)
1-h AEGL-2: | C^1^ × 60 min = 60 mg^.^min/m^3^; C= 1.00 mg/m^3^; 1-h AEGL-2 = (1.00 mg/m^3^)/10 = 0.10 mg/m^3^; (0.02 ppm)
4-h AEGL-2: | C^1^ × 240 min = 60 mg^.^min/m^3^; C= 0.25 mg/m^3^; 4-h AEGL-2 = (0.25 mg/m^3^)/10 = 0.025 mg/m^3^; (0.004 ppm)
8-h AEGL-2: | C^1^ × 480 min = 60 mg^.^min/m^3^; C = 0.125 mg/m^3^; 8-h AEGL-2 = (0.125 mg/m^3^)/10 = 0.013 mg/m^3^; (0.002 ppm)

### Derivation of AEGL-3

Key study: | Kumar and Vijayaraghavan (1998)
Toxicity end point: | Estimated lethality threshold of 21.2 mg/m^3^ for 1 h based on no deaths in mice exposed to that concentration, which is 0.5 of the 1h LC_50_ in mice reported by Vijayaraghavan (1997).
Scaling: | The concentration-time relationship for many irritant and systemically acting vapors and gases may be described by C^n^ × t = k, where the exponent n ranges from 0.8 to 3.5 (ten Berge et al. 1986). Analysis of available data pertaining to ocular effects indicated n to be near unity (Appendix B). However, there was uncertainty regarding the validity of applying linear extrapolation based on ocular effects to concentration-time extrapolations for lethality. Therefore, in the absence of chemical-specific lethality data, time scaling was performed using exponential extrapolation (n = 3) for shorter time periods (<1 h) and linear extrapolation (n = 1) for longer time periods (> 1 h), thereby providing a somewhat more conservative (i.e., protective) estimate of the AEGL-3 values than would be obtained using an n value based on ocular irritation. The concentration-time constant, k, was 1272 mg^.^min/m^3^ where n = 1 and 571,687.68 mg^.^min/m^3^ where n = 3.
Uncertainty factors: | Total UF was 10. A UF for interspecies was limited to 3 because human data are available showing that exposures to the AEGL-3 values are more likely to produce only severe ocular irritation and possible minor or moderate irritation of the upper respiratory tract. Intraspecies variability was limited to 3 because lethality appears to be a function of extreme pulmonary damage resulting from direct contact of the agent with epithelial surfaces. No modifying factor was applied because the basis of lethality estimate was from studies utilizing a 14-d observation period to assess the lethal response from a 1-h exposure.; Because the factors of 3 each represent a logarithmic mean (3.16) of 10, their product is 3.16 × 3.16 = 10.

10-min AEGL-3: | C^3^ × 10 min = 571,687.68 mg^.^min/m^3^; C^3^ = 57,168.76 mg^.^min/m^3^; C = 38.52 mg/m^3^; 10-min AEGL-3 = (38.52 mg/m^3^)/10 = 3.9 mg/m^3^; (0.59 ppm)
30-min AEGL-3: | C^3^ × 30 min = 571,687.68 mg^.^min/m^3^; C^3^ = 19,056.26 mg^.^min/m^3^; C= 26.7 mg/m^3^; 30-min AEGL-3 = (26.7 mg/m^3^)/10 = 2.7 mg/m^3^; (0.41 ppm)
1-h AEGL-3: | C1 × 60 min = 1,272 mg^.^min/m^3^; C= 21.2 mg/m^3^; 1-h AEGL-3 = (21.2 mg/m^3^)/10 = 2.1 mg/m^3^; (0.32 ppm)
4-h AEGL-3: | C1 × 240 min = 1,272 mg^.^min/m^3^; C = 5.3 mg/m^3^; 4-h AEGL-3 = (5.3 mg/m^3^)/10= 0.53 mg/m^3^; (0.08 ppm)
8-h AEGL-3: | C1 × 480 min = 1,272 mg^.^min/m^3^; C = 2.65 mg/m^3^; 8-h AEGL-3 = (2.65 mg/m^3^)/10 = 0.27 mg/m^3^; (0.04 ppm)

## APPENDIX B Determination of Temporal Scaling Factor (n) for AEGL Derivations

Derivation of n for C^n^ x t = k; data points indicative of a 100% response for mild ocular irritation following exposure to sulfur mustard agent HD) at various concentrations and times (Reed 1918; Reed et al., 1918; Guild et a1. 1941; Anderson 1942)

Time | Concentration | Log Time | Log Concentration
1 | 72 | 0.0000 | 1.8573
30 | 1.4 | 1.4771 | 0.1461
30 | 0.06 | 1.4771 | −1.2218
45 | 1.4 | 1.6532 | 0.6198
210 | 0.24 | 2.3222 | −0.6198
480 | 0.1 | 2.6812 | −1.0000
600 | 0.1 | 2.7782 | −1.0000
1,440 | 0.06 | 3.1584 | −1.2218

Regression output:
Intercept | 1.3852
Slope | −0.9002
squared | 0.7434
Correlation | −0.8622
Degrees of Freedom | 6
Observations | 8

n = 1.11

k = 34.58

Derivation of n for C^n^ x t = k; data points indicative of a 75-100% response for mild ocular irritation following exposure to sulfur mustard (agent HD) at various concentrations and times (Reed 1918; Reed et al. 1918; Guild et al. 1941; Anderson 1942)

Time | Concentration | Log Time | Log Concentration
1 | 72 | 0.0000 | 1.8573
30 | 1.4 | 1.4771 | 0.1461
30 | 0.06 | 1.477 | −1.2218
45 | 1.4 | 1.6532 | 0.1461
210 | 0.24 | 2.3222 | −0.6198
480 | 0.1 | 2.6812 | −1.0000
600 | 0.1 | 2.7782 | −1.0000
1,440 | 0.06 | 3.1584 | −1.2218
33 | 1.7 | 1.5185 | 0.2304
3 | 12.7 | 0.4771 | 1.1038
3 | 30 | 0.4771 | 1.4771
2.5 | 30 | 0.3979 | 1.4771
2 | 30 | 0.3010 | 1.4771
0.25 | 320 | −0.6021 | 2.5051

Regression Output:
Intercept | 1.7240
Slope | −1.0356
R squared | 0.8891
Correlation | −0.9429
Degrees of freedom | 12
Observations | 14

n = 0.96

k = 46.05

## APPENDIX C Carcinogenicity Assessment for Acute Exposure to Sulfur Mustard (Agent HD)

The cancer assessment for acute inhalation exposure to sulfur mustard was conducted following the NRC methodology for EEGLs, SPEGLs, and CEGLs (NRC 1986). The virtually safe dose (VSD) was determined from an inhalation slope factor of 14 (mg/kg/d)^−l^ for the general population (USACHPPM 2000). The slope factor was a geometric mean of slope factors developed using various data sets and procedures and was considered the most tenable quantitative assessment for potential cancer risk from inhalation exposure to sulfur mustard. The corresponding Inhalation Unit Risk was 0.0041 (μg/m^3^)^−1^ or 4.1 (mg/m^3^)^−1^ (USACHPPM 2000). The VSD was calculated as follows:

VSD = (1 × 10^− 4^ risk = 2.5 × 10^− 5^ mg / m^3^)/((4.1 mg / m^3^)^− 1^)

Assuming the carcinogenic effect to be a linear function of cumulative dose (d), a single-day exposure is equivalent to d x 25,600 d (average lifetime).

24 − h exposure = VSD × 25,600 = (2.5 × 10^− 5^ mg / m^3^) × 25,600 = 0.64 mg / m^3^

Adjustment to allow for uncertainties in assessing potential cancer risks under short term exposures under the multistage model (Crump and Howe 1984).

(24 − hr exp)/(6) = (0.64 mg / m^3^)/(6) = 0.1 mg / m^3^

If the exposure is limited to a fraction (f) of a 24-h period, the fractional exposure becomes l/f x 24 h (NRC 1985). For a 1 × 10^−4^, 1 × 10^−5^, and 1 × 10^−6^ risk, the fractional exposures are shown below.

Exposure Duration | 10^−4^ | 10^−5^ | 10^−6^
24-h | 0.1 mg/m^3^ (0.02 ppm) | 0.01 mg/m^3^ (0.002 ppm) | 0.001 mg/m^3^ (0.002 ppm)
8-h | 0.3 mg/m^3^ (0.05 ppm) | 0.03 mg/m^3^ (0.005 ppm) | 0.003 mg/m^3^ (0.0005 ppm)
4-h | 0.6 mg/m^3^ (0.09 ppm) | 0.06 mg/m^3^ (0.009 ppm) | 0.006 mg/m^3^ (0.0009 ppm)
1-h | 2.4 mg/m^3^ (0.36 ppm) | 0.24 mg/m^3^ (0.036 ppm) | 0.024 mg/m^3^ (0.0036 ppm)
30-min | 4.8 mg/m^3^ (0.72 ppm) | 0.48 mg/m^3^ (0.072 ppm) | 0.048 mg/m^3^ (0.0072 ppm)
10-min | 14.1 mg/m^3^ (2.16 ppm) | 1.41 mg/m^3^ (0.22 ppm) | 0.141 mg/m^3^ (0.022 ppm)

Because the derivation of the cancer slope factor requires conversion of animal doses to human equivalent doses, no reduction of exposure levels is applied to account for interspecies variability. With the exception of the 10-min, 30-min, and 1-h values for 10^−4^ risk and the 10- min 10^−5^ risk, these exposures are at or below the odor threshold for sulfur mustard. A cancer risk assessment based on a geometric mean of inhalation slope factors developed using various data sets and procedures indicated an excess cancer risk of 1 in 10,000 (10^−4^) may be associated with exposures similar to the AEGL-3 values. The use of excess cancer risk estimates in setting AEGL values is precluded by the uncertainties involved in assessing excess cancer risk following a single acute exposure of 8-h or less duration, by the relatively small population exposed in an emergency release situation, and by the potential risks associated with evacuations.

## APPENDIX D DERIVATION SUMMARY FOR ACUTE EXPOSURE GUIDELINES LEVELS

Sulfur Mustard (CAS NO.505-60-2)

AEGL-1
10 min | 30 min | 1 h | 4 h | 8 h
0.40 mg/m^3^ (0.06 ppm) | 0.13 mg/m^3^ (0.02 ppm) | 0.067 mg/m^3^ (0.01 ppm) | 0.017 mg/m^3^ (0.003 ppm) | 0.008 mg/m^3^ (0.001 ppm)
Key Reference: Anderson, J.S. 1942. The effect of mustard gas vapour on eyes under Indian hot weather conditions. CDRE Report No. 241. Chemical Defense Research Establishment (India)
Test species/strain/gender/number: 3-4 human volunteers
Exposure route/concentrations/durations: Vapor exposure to varying concentrations (1.7 – 15.6 mg/m^3^) for varying durations (2-33 min)
Effects: Mild ocular effects (mild injection to notable conjunctivitis)
End point/concentration/rationale: Concentration-time threshold of 12 mg^.^min/m^3^for ocular effects (conjunctival injection with minor discomfort and no functional decrement.
Uncertainty factors/rationale:; - Interspecies: 1 (human subjects); - Intraspecies: A factor of 3 was applies for intraspecies variability (protection of sensitive populations). This factor was limited to 3 under the assumption that the primary mechanism of action of agent HD involves a direct effect on the ocular surface and that the response will not vary greatly among individuals. Furthermore, little variability was observed in the tested subjects regarding ocular responses.
Modifying factor: None applied
Animal to human dosimetric adjustment: Not applicable
Time scaling: C^n^ × t = k, where n = 1 based on analysis of available human exposure data for ocular effects.
Data adequacy: The key study was conducted using human volunteers thus avoiding uncertainties associated with animal studies. Ocular irritation is considered the most sensitive end point for assessing the effects of acute exposure to sulfur mustard and the available data were sufficient for developing AEGL-1 values.
AEGL-2
10 min | 30 min | 1 h | 4 h | 8 h
0.60 mg/m^3^ (0.09 ppm) | 0.20 mg/m^3^ (0.03 ppm) | 0.10 mg/m^3^ (0.02 ppm) | 0.025 mg/m^3^ (0.004 ppm) | 0.013 mg/m^3^ (0.002 ppm)
Key Reference: Anderson, J.S. 1942. The effect of mustard gas vapour on eyes under Indian hot weather conditions. CDRE Report No. 241. Chemical Defense Research Establishment (India)
Test species/strain/gender/number: 3-4 human volunteers
Exposure route/concentrations/durations: Vapor exposure to varying concentrations (1.7 – 15.6 mg/m^3^) for varying durations (2-33 min)
Effects: Ocular effects ranging from mild injection to notable conjunctivitis, photophobia, lacrimation, blepharospasm
End point/concentration/rationale: Exposure-concentration time product of 60 mg^.^min/m^3^representing exposure at which ocular irritation (Well marked, generalized conjunctivitis, edema, photophobia, and irritation) will occur resulting in performance decrement and necessitating medical treatment.
Uncertainty factors/rationale:; - Interspecies: 1 (human subjects); - Intraspecies: A factor of 3 was applies for intraspecies variability (protection of sensitive populations). This factor was limited to 3 under the assumption that the primary mechanism of action of agent HD involves a direct effect on the ocular surface and that the response will not vary greatly among individuals. Furthermore, little variability was observed in the tested subjects regarding ocular responses.
Modifying factor: A modifying factor of 3 was applied to accommodate uncertainties regarding the onset of potential long-term ocular effects of respiratory effects.
Animal to human dosimetric adjustment: Not applicable
Time scaling: C^n^ × t = k, where n = 1 based on analysis of available human exposure data for ocular effects.
Data adequacy: The key study was conducted using human volunteers thus avoiding uncertainties associated with animal studies. The AEGL-2 values are based on ocular effects that may be considered severe enough to impair vision. The data were considered sufficient for developing AEGL-2 values.
AEGL-3
10 min | 30 min | 1 h | 4 h | 8 h
3.9 mg/m^3^ (0.59 ppm) | 2.7 mg/m^3^ (0.41 ppm) | 2.1 mg/m^3^ (0.32 ppm) | 0.053 mg/m^3^ (0.08 ppm) | 0.27 mg/m^3^ (0.04 ppm)
Key Reference: Kumar, O., and R. Vijayaraghavan. 1998. Effect of sulfur mustard inhalation exposure on some urinary variables in mice. J. Appl. Toxicol. 18:257-259.
Test species/strain/gender/number: Swiss mice/femal/4 per exposure group.
Exposure route/concentrations/durations: Head-only inhalation exposure for 1 h to sulfur mustard (>99% purity) at 21.2, 42.3, or 84.6 mg/m^3^(equivalent to 0.5, 1.0, and 2.0LC_50_). Subjects were sacrificed at 6, 24, or 48 h or 7 d after exposure. Three groups of 10 mice were exposed at each concentration and observed for up to 14 d.
Effects: Lethality assessed up to 14 d post exposure
End point/concentration/rationale: No mortality in mice at 14 d following 10h exposure at 21.2 mg/m^3^. The exposure was considered an estimate of the lethality threshold in mice.
Uncertainty factors/rationale:; - Total uncertainty factor: 10; - Interspecies: A factor of 3 was applied to account for possible interspecies variability in the lethal response to sulfur mustard. Application of any additional uncertainty factors or modifying factors was not warranted because the AEGL-3 values are equivalent to exposures in humans that are known to produce only ocular and respiratory tract irritation.; - Intraspecies: Intraspecies variability was limited to 3 because lethality appears to be a function of extreme pulmonary damage resulting from direct contact of the agent with epithelial surfaces.
Modifying factor: No modifying factor was applied because the basis of lethality estimate was from a study utilizing a 14-d observation period to assess the lethal response from a 1-h exposure.
Animal to human dosimetric adjustment: Insufficient data
Time scaling: C^n^ × t = k, where n = 1 or 3. The concentration-time relationship for many irritant and systemically acting vapors and gases can be described by C^n^ × t = k, where the exponent n ranges from 0.8 to 3.5 (ten Berge et al. 1986). In the absence of chemical-specific lethality data, time scaling was performed using exponential extrapolation (n = 3) for shorter time periods and linear extrapolation (n = 1) for longer time periods, thereby providing a somewhat more conservative (i.e., protective) estimate of the AEGL-3 values than would be obtained using an n value of 1 based on ocular irritation.
Data adequacy: Uncertainties exist regarding a definitive lethality threshold for single acute exposures to sulfur mustard. However, the key study appeared to be well-designed and properly conducted and is considered sufficient for developing AEGL-3 values.