# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as a hundredfold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agency wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change, as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop E-29, Atlanta, GA 30333.

## Sulfur mustard [bis(2-chlorethyl) sulfide] Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical name: | Sulfur mustard [bis(2-chlorethyl) sulfide]
CAS number(s): | 505-60-2
Date: | August 29, 2003
Profile status: | Third Draft
Route: | [X] Inhalation [ ] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Key to figure: | 2
Species: | Human

[underlined: Minimal Risk Level]: 0.0007 [ ] mg/kg/day [ ] ppm [X] mg/m^3^

[underlined: Reference]: Guild WJF, Harrison KP, Fairley A, . 1941. The effect of mustard gas vapor on the eyes. Chemical Board, Physiological Sub-Committee and Panel of Opthalmic Specialists. Porton Report 2297. Chemical Defense Experimental Station, Porton, UK.

[underlined: Experimental design]: Male soldiers wearing respirators (2–6 men/group) were exposed to sulfur mustard vapor concentrations, checked by continuous chemical sampling, ranging from 0.06 to 320 mg/m^3^. Continuous exposure durations ranged from 15 seconds to 10 hours, yielding concentration time (Ct) products in the range of 42–144 mg-minute/m^3^. Two repeated-exposure tests were also conducted; a group of four men was exposed to 0.22 mg/m^3^, 2.5 hours/day, for 2 days, and another group of four men was exposed to 0.06 mg/m^3^, 8 hours/day, for 3 days (intermittent Cts of 66 and 86 mg-minute/m^3^, respectively). Chamber temperatures for each experiment were not provided, but chamber temperatures were stated to range from 55 to 80 ºF during the testing. Soldiers were in good health and had no previous exposures to sulfur mustard. The subject’s eyes were examined for evidence of toxicity subsequent to exposure.

[underlined: Effects noted in study and corresponding doses]: No deaths occurred. For continuous exposures, ocular effects and severity depended on the concentration and duration, or Ct. At the lowest continuous Ct of 42 mg-minute/m^3^ (1.4 mg/m^3^ for 30 minutes), four of four soldiers showed a slight generalized conjunctival reaction. A slight or just discernable or slight conjunctival reaction was also reported at the lowest concentration of 0.1 mg/m^3^ for 8 and 10 hours exposures (Cts of 48 and 60 mg-minute/m^3^, respectively). Just discernable angular congestion of the bulbar conjunctiva was reported for Cts ranging from 48 to 75 mg-minute/m^3^. Slight to moderate degree of conjunctival congestion was reported for the Ct range of 80-90 mg-minute/m^3^. The first casualties (two of two men) [casualty meaning any interference with vision or any lesion of the eyes sufficiently severe to render a soldier, for a time, incapable of carrying out his normal duties] were reported at a Ct of 99 mg-minute/m^3^ (16.5 mg/m^3^ for 6 minutes). Both subjects showed generalized established conjunctivitis with photophobia. At a Ct of 144 mg-minute/m^3^, six of six subjects showed marked generalized conjunctival congestion, with photophobia in one of six subjects. While specific results were not reported for the 2-day repeated exposure (0.22 mg/m^3^, 2.5 hours/day, for 2 days), the authors stated that there was no discernable difference in the degree of conjunctival reaction between subjects in this group and subjects exposed to the same concentration for 5 hours (Ct of 66 mg-minute/m^3^). A scarcely discernable generalized conjunctival reaction (incidence unspecified) was reported in subjects undergoing the 3-day repeated exposure (0.06 mg/m^3^, 8 hours/day, for 3 days; intermittent Cts of 86 mg-minute/m^3^). The severity of conjunctivitis for the 3-day intermittent exposure was described as far slighter than the moderate degree of conjunctivitis observed from continuous exposures with Cts ≥80 mg-minute/m^3^.

[underlined: Dose and end point used for MRL derivation]: The 3-day repeated exposure experiment is considered to best represent a potential acute exposure, and the time-weighted average concentration of 0.02 mg/m^3^ (0.06 mg/m^3^ x 8 hours/24 hours) is considered a minimal LOAEL for ocular effects.

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty factors (UF) and Modifying Factor (MF) used in MRL derivation]:

- [X] 3 for use of a minimal LOAEL
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? NA [underlined: Was a conversion used from intermittent to continuous exposure]? Yes

LOAEL_[ADJ]_ = 0.06 mg / m^3^ ⋅ (8 hours / 24 hours) = 0.02 mg / m^3^

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: NA

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Ocular effects were reported in other chamber tests reported by Reed (1919) and Anderson (1942); however, these studies did not include repeated exposures. Conjunctivitis with photophobia and blepharospasm were reported as the initial signs of exposure in two subjects who underwent chamber tests wearing no respirators and clad only in khaki uniform pants without shirts (Reed 1918). The two subjects were exposed to 1.2 mg/m^3^ of sulfur mustard vapor for 20 and 45 minutes (Cts of 24 and 54 mg-minute/m^3^), respectively. The variation in sensitivity to sulfur mustard was demonstrated by a latency of 3 hours for the subject exposed to the Ct of 24 mg-minute/m^3^, as compared to 6 hours for the subject exposed to the higher Ct. In subsequent chamber tests conducted by Reed (1918), no signs were reported in six subjects exposed to the lowest Ct of 1.0 mg-minute/m^3^ (0.1 mg/m^3^ for 10 minutes), whereas one of two subjects showed slight, but distinct, conjunctival injection at the next higher Ct of 1.5 mg-minute/m^3^ (0.1 mg/m^3^ for 15 minutes). In continuous flow tests with human subjects, with only the face and one eye exposed, conjunctivitis was observed at Cts as low as 7 mg-minute/m^3^ (0.7 mg/m^3^ for 10 minutes); Cts as low as 1.5 mg-minute/m^3^ (0.1 mg/m^3^ for 15 minutes) were tested (Reed 1918). However, it should be noted that methods for measuring low vapor concentrations of sulfur mustard were not yet validated at the time of these studies. In chamber tests conducted by Anderson (1942), using male soldier wearing respirators, a trace of angular conjunctivitis and “band of fine injection” across the exposed part bulbar conjunctiva were reported at the lowest Ct of 12.5 mg-minute/m^3^ (6.25 mg/m^3^ for 2 minutes). A “fine injection band” over the exposed sclera was reported at the lowest concentration of 1.7 mg/m^3^ (33 min; Ct=56.1 mg-minute/m^3^) (Anderson 1942). In addition to chamber testing, numerous reports exist of ocular lesions that occurred in soldiers exposed to sulfur mustard during World War I (Hughes 1942; Philips 1940). In a more recent study of Iranian fighters with a history of sulfur mustard poisoning, delayed ocular lesions from undetermined, presumably acute, exposures included chronic conjunctivitis in 75/85 (32%), keratoconjunctivitis in 7/85 (3%) and blindness in 2/85 (1%) (Balali-Mood 1986). A range of ocular effects, including conjunctivitis, chronic keratitis, and corneal ulcerations, have been reported in dogs and rabbits following acute exposure to sulfur mustard depending on the concentration and duration of exposures (Balali-Mood 1986; Gates and Moore 1946; Laughlin 1944a; Maumenee and Scholts 1948; Reed 1918; Warthin and Weller 1919).

[underlined: Agency Contact (Chemical Manager)]: Zemoria A. Rosemond

## Sulfur mustard [bis(2-chlorethyl) sulfide] Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical name: | Sulfur mustard [bis(2-chlorethyl) sulfide]
CAS number(s): | 505-60-2
Date: | August 29, 2003
Profile status: | Third Draft
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Key to figure: | 11
Species: | Dog

[underlined: Minimal Risk Level]: 0.00002 [ ] mg/kg/day [ ] ppm [X] mg/m^3^

[underlined: Reference]: McNamara BP, Owens EJ, Christensen MK, . 1975. Toxicological basis for controlling levels of mustard in the environment. Edgewood Arsenal Special Publication. Aberdeen Proving Ground, Maryland: Department of the Army. EB-SP-74030.

[underlined: Experimental design]: Male and female beagle dogs (6 initially and 4 added), rats (140), A/J mice (140), rabbits (12 initially and 6 added), and guinea pigs (30 initially and 12 added) were exposed to sulfur mustard vapor at a concentration of 0.001 mg/m^3^ for 24 hours/day, 5 days/week (time-weighted average concentration of 0.0007 mg/m^3^), for varying durations up to 1 year. The same number of animals of each species were exposed to 0.1 mg/m^3^ for 6.5 hours followed by exposure to 0.0025 mg/m^3^ for the remaining 17.5 hours of the day, 5 days/week, for durations up to a year. The latter exposure is equivalent to a time-weighted average concentration of 0.0206 mg/m^3^ [{0.1 mg/m^3^ x (6.5 hours/24 hours) + 0.0025 mg/m^3^ x (17.5 hours/24 hours)} x (5 days/7 days) = 0.0206 mg/m^3^]. Unexposed controls consisted of 10 dogs (6 initially and 4 added), 100 rats, 140 A/J mice (120 initially and 20 added), 22 rabbits (7 initially and 15 added), and 32 guinea pigs (20 initially and 12 added). The treatment protocol was unusual in that new animals were added to replace exposed animals that were sacrificed periodically. At about 7 months after the study was initiated, 100 ICR Swiss albino mice were added to the test chambers, and 50 A/J mice were added about 3 months later. At these same times, the same numbers of each strain were added to the study as additional controls. The animals were observed periodically for clinical signs of toxicity. Body weights were recorded. Red and white blood cell counts, hematocrit, and hemoglobin were measured in dogs and rabbits, but not other species. Clinical chemistry analyses including blood urea nitrogen (BUN), lactic dehydrogenase (LDH), alkaline phosphatase (ALP), and serum alanine aminotransferase (ALT) were conducted in dogs. Gross and microscopic examinations were performed.

[underlined: Effects noted in study and corresponding doses]: No dogs died during the study. Mortality was unrelated to concentration in rabbits and guinea pigs, and comparable to controls in exposed ICR Swiss mice. While no control rats died, death occurred in 3/140 and 16/140 at the low- and high-concentrations, respectively. In the first group of A/J mice, mortality incidence was concentration-related; 4/140, 14/140, and 24/140 in the control, low- and high-concentration groups, respectively. However, in the second group of A/J mice, 3/50 animals in the low-concentration group died, while there were no deaths in the control and high-concentration groups. Because of the lack of correlation between deaths and exposure in the ICR Swiss mice and the second group of A/J mice the authors concluded that deaths were more likely due to conditions of animal storage than treatment. Of 79 rats exposed to the lower concentration and necropsied, 5 developed chronic keratitis. This lesion was not observed in control or high-dose rats. No clinical signs of toxicity were observed in any of the other species exposed to the low concentration. At the high concentration, the only overt signs of toxicity were ocular effects, observed only in dogs. Ocular effects first appearing after 16 weeks of exposure, including corneal opacity, pannus, chronic keratitis, vascularization, pigmentation, and granulation were reported in 3 of 10 high-concentration dogs exposed for 7.5 or 12 months. The time-weighted average concentration of 0.0206 mg/m^3^ is considered a LOAEL for ocular effects in beagle dogs.

[underlined: Dose and end point used for MRL derivation]: The lowest concentration tested in dogs, 0.001 mg/m^3^, is a NOAEL for ocular effects (conjunctivitis and chronic keratitis).

[ X] NOAEL [ ] LOAEL

[underlined: Uncertainty factors (UF) and Modifying Factor (MF) used in MRL derivation]:

- [X] 10 for human variability
- [X] 3 for animal-to-human extrapolation

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? NA [underlined: Was a conversion used from intermittent to continuous exposure]? Yes

NOAEL_[ADJ]_ = 0.001 mg / m^3^ ⋅ (24 hours / 24 hours) ⋅ (5 days / 7 days) = 0.0007 mg / m^3^

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Gates and Moore (1946) reported that the human eye is about four times more sensitive to sulfur mustard than the rabbit eye based on the observation of corneal ulceration produced in rabbits and dogs at Cts of 4 and 2 times the value, respectively, at which this effect occurred in humans. This is consistent with the observation by McNamara et al. (1975) of ocular effects in dogs, but not in rabbits, at the high concentration. Thus, an uncertainty factor of 3 for extrapolation of data from dogs to humans is considered appropriate for derivation of the MRL.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: The intermediateduration inhalation MRL was based on the same critical endpoint as the acute-duration inhalation MRL. In addition to the supporting information for ocular lesions as provided for the acute-duration MRL, there are numerous reports of eye burns in workers accidentally exposed to large quantities of sulfur mustard vapor, as well as to slow leaks that were not detected by smell (Hughes 1945a; Pechura and Rall 1993; Uhde 1946).

[underlined: Agency Contact (Chemical Manager)]: Zemoria A. Rosemond

## Sulfur mustard [bis(2-chlorethyl) sulfide] Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical name: | Sulfur mustard [bis(2-chlorethyl) sulfide]
CAS number(s): | 505-60-2
Date: | August 29, 2003
Profile status: | Third Draft
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Key to figure: | 5, 6
Species: | Rat

[underlined: Minimal Risk Level]: 0.5 [X] μg/kg/day [ ] ppm [ ] mg/m^3^

[underlined: Reference]: DOA. 1987. Teratology studies on lewisite and sulfur mustard agents: Effects of sulfur mustard in rats and rabbits. Fort Detrick, MD: U.S. Army Medical Research and Development Command, U.S. Department of Army. ADA187495.

[underlined: Experimental design]: Sulfur mustard (95.9–96.1% purity) dissolved in sesame oil was administered by intragastric intubation to mated Sprague-Dawley female rats (10–11 weeks old) on gestation days 6 through 15 (10 days). The administered doses were 0, 0.5, 1.0, or 2.0 mg/kg/day and there were 25– 27 animals/dose group, of which 20–26/dose group were pregnant. All animals were observed for clinical signs of toxicity prior to and following administration of sulfur mustard. Treated rats were weighed on gestation days 0, 6–15 (exposure days), and on day 20. Necropsy was performed on all rats found dead or in moribund condition. Scheduled necropsy was performed on gestation day 20. Blood samples were collected from maternal animals for hematocrit measurement prior to sacrifice. The animals were examined for gross lesions of major organ systems. The numbers of corpora lutea, implantation sites, resorptions, and live and dead fetuses were determined. Uterine weights were recorded. Live fetuses were removed, weighed, sexed, and examined for gross, soft tissue, and skeletal anomalies.

[underlined: Effects noted in study and corresponding doses]: There were no treatment-related deaths. In rats, a significant dose-related decrease in maternal body weight was observed by gestation day 12 at 0.5 mg/kg/day (4.1–6.6%) and by gestation day 9 in the 1.0 (4.7–9.1%) and 2.0 (6.5–16.0%) mg/kg/day groups. Extragestation weight gain was significantly reduced at ≥0.5 mg/kg/day with dose-related reductions of 25, 38, and 57% at 0.5, 1.0, and 2.0 mg/kg/day, compared to controls. A significantly decreased (16%) gravid uteri weight was measured at the highest dose. Maternal hematocrit values were statistically significantly reduced by 5.4% at 1.0 and 2.0 mg/kg/day. Gastric mucosa inflammation was observed in 2/30 (6.7%) rats at 2.0 mg/kg/day, but not in any of the lower dose or control groups. A significantly increased incidence of inflamed mesenteric lymph nodes was found at ≥0.5 mg/kg/day; the incidences were 0/27 controls, and 11/25 (44%), 16/25 (64%), and 15/27 (56%) rats at 0.5, 1.0, and 2.0 mg/kg/day, respectively.

Fetal body weight was significantly decreased (6–7%) from controls in litters exposed to doses of ≥1.0 mg/kg/day; no clear dose-relation was evident. The sex ratio (percent males) was significantly lower than control at the highest dose (46.2 vs. 51.0%). Placental weight was also significantly reduced (8.4%) at the highest dose. Supernumerary ribs were found in 9/299 (3%) fetuses of one litter in the highest dose group, while this anomaly was not found in any of the fetuses in the lower dose or control groups. The incidence of reduced ossification of the vertebrae and/or sternebrae in all treated groups was significantly higher than controls when individual pup data were compared, but not with litter comparisons, 42/272 (15%) in controls, 51/229 (22%) at 0.5 mg/kg/day, 76/315 (24%) at 1.0 mg/kg/day, and 72/299 (24%) at 2.0 mg/kg/day. All fetal effects in rats occurred at doses that also produced maternal toxicity.

[underlined: Dose and end point used for MRL derivation]: The lowest dose tested in rats, 0.5 mg/kg/day is a LOAEL for inflamed mesenteric lymph nodes in the dams and reduced ossification in the fetuses.

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty factors (UF) and Modifying Factor (MF) used in MRL derivation]:

- [X] 10 for LOAEL-to-NOAEL extrapolation [X] 10 for human variability
- [X] 10 for animal-to-human extrapolation

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? NA [underlined: Was a conversion used from intermittent to continuous exposure]? NA [underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: NA

[underlined: Other additional studies or pertinent information that lend support to this MRL]: In support of the critical effect, there is some evidence in humans to indicate that sulfur mustard affects the lymph system. Discoloration of the lymph nodes in the axillary, inguinal, and mesenteric glands were noted in autopsies of victims of the World War II Bari Harbor incident, during which sulfur mustard was released in to the air and water (Alexander 1947). The spleen also demonstrated evidences of gross pathology in 33 of 53 (62%) autopsies (Alexander 1947). In the majority of cases, the spleen was described as shrunken in size with pale color. Microscopically, only 2 of 32 spleens examined showed degeneration or necrosis; pyknosis and karyorrhexis of lymphocytes in some corpuscles were observed in one and slight necrosis of the malpighian follicle, was observed in the other. Additional studies in animals also revealed sulfur mustard-induced damage to the lymph system. Cameron et al. (1946), after observing damage to the cervical lymph nodes and lymphoid tissue throughout the body in rabbits and monkeys that had undergone tracheal cannulation and had been exposed to chamber concentrations of sulfur mustard ranging from 30 to 350 mg/m^3^ (5–54 ppm), administered sulfur mustard to animal skin topically or by subcutaneous injection and observed identical changes to the lymph tissue, suggesting that lymphoid tissue damage may be due to systemic absorption. Sulfur mustard produced a significant dose-related decrease in the weight of peripheral lymph nodes (12–44%) when topically applied at single doses of 3.88, 7.75, or 15.5 mg/kg to the shaved backs of Balb/c mice (Venkateswaran et al. 1994a). A significant decrease in the weight of mesenteric lymph nodes (18%) was noted at the highest dose. Incidence and severity of histological changes in the thymus and spleen were also dose-related. Spleen histopathology included hypocellularity, atrophy of the lymphoid follicles, degeneration of germinal centers, and red pulp infiltrated with macrophages. The cortex and medulla regions of the thymus showed atrophy and hypocellularity. A significant dose-related decrease in the cellularity of the spleen (24–45%) was measured. A dose-related decrease in the cellularity of the thymus was also found, and was significant at the mid- and high doses (36–42%). A significant dose-related reduction in spleen cell number was measured in female mice 7 days after intraperitoneal injection with sulfur mustard (23% at 5 mg/kg and 49% at 10 mg/kg) (Coutelier et al. 1991).

The principal study (DOA 1987) identified the lowest LOAEL of 0.5 mg/kg/day for inflamed mesenteric lymph nodes in rats following acute administration of sulfur mustard. In range-finding experiments, conducted prior to the principal teratology study, in which rats were dosed with 0, 0.2, 0.4, 0.8, 1.6, 2.0, or 2.5 mg/kg/day (3–9 animals/dose group of which 2–7/dose group were pregnant) on gestation days 6–15, significant incidences of inflamed mesenteric lymph nodes occurred at ≥0.4 mg/kg/day (DOA 1987). Also in support of the critical dose, another lymphoretic effect, enlarged Peyer’s patches, was observed in rabbits at 0.5 g/kg/day in a range-finding study and at 0.4 g/kg/day in a teratology study (incidence data were not reported) (DOA 1987).

[underlined: Agency Contact (Chemical Manager)]: Zemoria A. Rosemond

## Sulfur mustard [bis(2-chlorethyl) sulfide] Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical name: | Sulfur mustard [bis(2-chlorethyl) sulfide]
CAS number(s): | 505-60-2
Date: | August 29, 2003
Profile status: | Third Draft
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Key to figure: | 9
Species: | Rat

[underlined: Minimal Risk Level]: 0.07 [X] μg/kg/day [ ] ppm [ ] mg/m^3^

[underlined: Reference]: Sasser LB, Cushing JA, Dacre JC. 1996a. Two-generation reproduction study of sulfur mustard in rats. Repro Toxicol 10(4):311–319.

[underlined: Experimental design]: Sulfur mustard (97.3% purity) dissolved in sesame oil was administered intragastrically by intubation to groups of 8-week-old Sprague-Dawley rats (27 females and 20 males/group/generation) at doses of 0, 0.03, 0.1, or 0.4 mg/kg/day. Male and female rats were dosed 5 days/week for 15 weeks that included 13 weeks before and 2 weeks during the mating period. Females were dosed daily (7 days/week) throughout the 21-day gestation period and 4–5 days/week during the 21-day lactation period. Males were dosed 5 days/week during the 21-day gestation period and sacrificed at the birth of their pups. Dams were sacrificed when their pups were weaned. Male and female F1 pups were treated with sulfur mustard until they were mated and the females became pregnant and gave birth. F1 males were sacrificed at the birth of their pups. The dosing of F1 dams continued until pup weaning, at which time, the study was terminated. Animals were weighed weekly. A complete gross necropsy was performed on all rats found dead or in moribund condition. Weights of the testis, prostate, epididymis, ovary, and uterus were recorded. Histopathological evaluations were performed on reproductive organs of the high dose group and control group of the F0 and F1 adults and on the forestomach of animals in all dose groups.

[underlined: Effects noted in study and corresponding doses]: There were no treatment-related deaths. The body weights of the F0 sulfur mustard-exposed rats were not significantly different from controls; however, the growth rate of the high-dose males tended to decline after about 7 weeks of exposure. Body weight gain was significantly lower (p<0.05) than control values in F1 rats of both sexes born to high-dose parents beginning 1 or 2 weeks after dosing was started (approximately 20% for males and 15–24% for females). No significant dose-response in body weight occurred at the lower doses. Breeding and reproductive performance in F0 and F1 animals was not affected by treatment. The only statistically significant birth parameter difference was an altered sex ratio (an increase in the fraction of males) of the high-dose F0 offspring. Although not significantly different, litter weights and number of pups per litter tended to decrease in both F1 and F2 animals at the highest exposure level. Except for a slight reduction in absolute ovary weight in high-dose F0 females, absolute and/or relative male and female reproductive organ weights were unaffected by treatment. Microscopic examination of the reproductive organs revealed no evidence of treatment-related effects. Dose-related incidence and severity of lesions of the squamous epithelium of the forestomach characterized by cellular disorganization of the basilar layer, an apparent increase in mitotic activity of the basilar epithelial cells and thickening of the epithelial layer, occurred in both sexes of each treatment group. The incidence of squamous acanthosis (combined F0 and F1 males and females; minimal to marked severity) was 0/94 controls, 69/94 (73%; 27 males/42 females) in the low-dose groups, 90/94 (96%; 39 males/51 females) in the mid-dose groups, and 94/94 in the high-dose groups. Benign neoplasms of the forestomach (squamous papilloma) occurred in 0/94 controls, 0/94 in the low-dose groups, 8/94 (9%) in the mid-dose groups, and 10/94 (11%) in the high-dose groups.

[underlined: Dose and end point used for MRL derivation]: The lowest dose tested, 0.03 mg/kg/day, is a LOAEL for gastric lesions (mild epithelial acanthosis of the forestomach). Although humans do not have forestomachs, the primary mechanism of toxicity of sulfur mustard is epithelial tissue damage from direct contact and, therefore, epithelial acanthosis is considered a suitable critical noncancer end point for deriving an oral MRL. Tissue damage would be expected to occur at the point of contact, even if it were another part of the gastrointestinal tract.

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty factors (UF) and Modifying Factor (MF) used in MRL derivation]:

- [X] 10 for LOAEL-to-NOAEL extrapolation
- [X] 10 for human variability
- [X] 3 for animal-to-human extrapolation*

*Because sulfur mustard is a highly corrosive agent, epithelial lesions at the point of entry into the stomach are likely to occur across species. For this reason, the typical default value of 10 for the uncertainty factor for extrapolation of data from animals to humans is considered to be too high and a lower value of 3 is applied.

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? NA

[underlined: Was a conversion used from intermittent to continuous exposure]? A time-weighted average (TWA) daily dose was calculated as follows. Females were dosed during the lactation period while males were not. Female rats were treated 5 days/week for 15 weeks (75 days), total dose=2.25 mg/kg (75 days x 0.03 mg/kg/day); daily for 3 gestation weeks (21 days), total dose=0.63 mg/kg; and 4 days/week for 3 lactation weeks (12 days), total dose=0.36 mg/kg. The cumulative dose for females over the 21-week period is 3.24 mg/kg (2.25+0.63+0.36 mg/kg). Dividing the cumulative dose of 3.24 by 147 days (21 weeks) yields a TWA dose of 0.02 mg/kg/day. For males, the same TWA daily dose results; however, different time weighting applies [0.03 mg/kg/day x (5 days/7 days)=0.02 mg/kg/day].

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: NA

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Injury to the gastric mucosa (mild epithelial acanthosis of the forestomach) is a portal-of-entry direct contact toxic effect that is consistent with the vesicant properties of sulfur mustard following oral exposure. In support of the critical effect, gastrointestinal effects have been reported in humans following combat exposure to sulfur mustard, in sulfur mustard testing volunteers, and in sulfur mustard factory workers. In all of these cases, exposure was likely by multiple routes including inhalation, oral, and dermal. In 19 of 53 (36%) victims of the World War II Bari Harbor incident autopsied, stomach irritation and inflammation were documented. The lesions varied from simple hyperemia to focal loss of epithelium, necrosis, and ulceration (Alexander 1947). In a review of the clinical manifestations of sulfur mustard exposure in the Iran-Iraq war victims, Pierard et al. (1990) reported that endoscopy frequently revealed acute gastritis. Incidences of gastrointestinal effects of nausea (64%), vomiting (43%), and bleeding (14%) were reported in a group of 14 children and teenagers following exposure to sulfur mustard from air bombs during the Iran-Iraq war (Momeni and Aminjavaheri 1994). Gastrointestinal neoplasms were reported in Japanese sulfur mustard factory workers who were involved with the production of chemical agents during World War II (Yamakido et al. 1985). Sulfur mustard testing volunteers who were wearing respirators and who were exposed to unspecified levels of sulfur mustard vapors and liquids had skin burns, but also complained of nausea, vomiting, anorexia, abdominal pain, diarrhea, headache, and lassitude (Sinclair 1948). These signs could have been primary effects of the sulfur mustard on the rapidly dividing cells of the gastrointestinal epithelium, secondary effects from the skin burns, or psychological effects not related to the sulfur mustard exposure at all.

In addition to the principal study, Sasser et al. (1996a), similar gastric effects, edema, hemorrhage or sloughing of the mucosa, and ulceration) have been identified in rabbits following 14-day exposures at ≥0.4 mg/kg/day (DOA 1987), in rats following 10-day exposures at ≥2.0 mg/kg/day (DOA 1987), and in rats following 13-week exposures at ≥0.1 mg/kg/day (Sasser et al. 1996b). Regarding the relevance of the toxic effects to humans lacking a forestomach, tissue damage at the point of contact would be expected by a vesicant and direct alkylating agent such as sulfur mustard, regardless of the location in the gastrointestinal tract.

[underlined: Agency Contact (Chemical Manager):] Zemoria A. Rosemond