# 7 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding sulfur dioxide in air, water, and other media are summarized in Table 7-1.

A NTP cancer classification has not been reported for sulfur dioxide. NTP has not conducted genetic toxicology or chronic toxicology and carcinogenicity bioassays on sulfur dioxide (ACGIH 1991).

A STEL for occupational exposure has been established at 5 ppm (10 mg/m^3^). World Health Organization (WHO) guidelines for exposure to sulfur dioxide are listed in Table 7-1.

EPA primary and secondary NAAQS are listed in Table 7-1. A 24 hour limit and an annual limit of exposure have been established. However, despite the effects induced in exercising asthmatics by brief exposure to sulfur dioxide (Utell and Frampton 1992), no short-term ambient sulfur dioxide standard has been established.

An acute-duration MRL of 0.01 ppm has been derived based on increased airway resistance in asthmatics (Sheppard et al. 1981).

TABLE 7-1 Regulations and Guidelines Applicable to Sulfur Dioxide

Agency | | Description | Information | References
[underlined: INTERNATIONAL]
IARC | | Carcinogenic classification | Group 3^a^ | IARC 1992a
WHO | | 10-minute exposure limit | 500 μg/m^3^ (0.2 ppm) | WHO 1987
| | 1-hour exposure limit | 350 μg/m^3^ (0.13 ppm) | WHO 1987
| | 24-hour exposure limit | 100-150 μg/m^3^ (0.04-0.06 ppm) | WHO 1979
| | Annual arithmetic mean | 40-60 μg/m^3^ (0.015-0.023 ppm) | WHO 1979
[underlined: NATIONAL]
Regulations:
a. | Air:
| EPA | NAAQS, national primary ambient air quality standard for sulfur oxides measured as sulfur dioxide | | EPA 1998a (40 FR 50.4)
| | 24-hour exposure limit^b^ | 365 μg/m^3^ (0.14 ppm)
| | Annual arithmetic mean | 80 μg/m^3^ (0.03 ppm)
| | NAAQS, national secondary ambient air quality standard for sulfur oxides measured as sulfur dioxide | | EPA 1998b (40 CFR 50.5)
| | 3-hour exposure limit^b^ | 1,300 μg/m^3^ (0.5 ppm)
| OSHA | PEL TWA (8 hours) | 13 mg/m^3^ (5 ppm) | OSHA 1998 (29 CFR 1910.1000)
b. | Water:
| EPA | Hazardous substance under the Clean Federal Water Pollution Control Act Section 311(b)(2)(A) | No | EPA 1998c (40 CFR 116.4)
c. | Food:
| EPA | Residues from the use of sulfur dioxide in liquid grain-fumigant formulations for market or fire-retardant purposes at levels not exceeding 5% by weight are exempted from the requirement of a tolerance in or on barley, buckwheat, corn, oats, popcorn, rice, rye, grain sorghum, (milo), and wheat | Yes | EPA 1998e (40 CFR 180.1013)
| | Residues of sulfur dioxide resulting from postharvest fungicial use are exempted from the requirement of tolerances in or on corn for feed us only (non-human consumption) | Yes | EPA 1998e (54 CFR 180.1013)
| | Tolerance for sulfite residues from the fungicide sulfur dioxide in or on the following raw agricultural commodity: grapes, postharvest | 10 ppm (26.2 mg/m^3^) | EPA 1998d (40 CFR 180.444)
| FDA | Recognized as safe when used in accordance with good manufacturing or feeding practices except meats and food sources of vitamin B1 | Yes | FDA 1995 (21 CFR 582.3862)
b. | Other:
| DOT | Forbidden for transport on passenger-carrying aircraft or railcars | Yes | DOT 1998a (49 CFR 172.101)
| | Domestic transportation labels, poison gas, corrosive | Yes | DOT 1998a
| EPA | CERCLA reportable quantity | 500 pounds | EPA 1998f (40 CFR 355 Appendix A)
| | Extremely hazardous substance, TPQ | 500 pounds | EPA 1998f (40 CFR 355 Appendix A)
| EPA-OSW | Designation of hazardous substance | No | EPA 1998c (40 CFR 116.4)
Guidelines:
a. | Air:
| ACGIH | TLV TWA | 5.2 mg/m^3^ (2 ppm) | ACGIH 1998
| NIOSH | REL TWA | 5 mg/m^3^ (2 ppm) | NIOSH 1997
| | STEL | 13 mg/m^3^ (5 ppm) | NIOSH 1997
[underlined: STATE] ^c^
Regulations and Guidelines:
a. | Air:
| | Acceptable ambient air concentation:
| California | 1-hour | 0.25 ppm | CA ARB 1998
| | 24-hour | 0.04 ppm
| Colorado | 1°: 24-hour | 260 μg/m^3^ (0.10 ppm) | CO DPHE 1998
| | Annual | 75 μg/m^3^ (0.03 ppm)
| | 2°: 24-hour | 60 μg/m^3^ (0.02 ppm)
| | Annual | 150 μg/m^3^ (0.06 ppm)
| Connecticut | 1°: 24-hour | 365 μg/m^3^ (0.14 ppm) | CO DPHE 1998
| | Annual | 80 μg/m^3^ (0.03 ppm)
| | 2°: 24-hour | 1300 μg/m^3^ (0.5 ppm)
| | Annual | 360 μg/m^3^ (0.1 ppm)
| Florida | 3-hour | 1300 μg/m^3^ (0.5 ppm) | FL DEP 1998
| | 24-hour | 260 μg/m^3^ (0.1 ppm)
| | Annual | 60 μg/m^3^ (0.02 ppm)
| Maine | 3-hour | 1150 μg/m^3^ (0.4 ppm) | ME DEP 1998
| | 24-hour | 230 μg/m^3^ (0.09 ppm)
| | Annual | 57 μg/m^3^ (0.02 ppm)
| Minnesota | 1°: 24-hour | 365 μg/m^3^ (0.14 ppm) | MN PCA 1998
| | Annual | 80 μg/m^3^ (0.03 ppm)
| | 2°: 24-hour | 365 μg/m^3^ (0.14 ppm)
| | Annual | 60 μg/m^3^ (0.02 ppm)
| Montana | 1-hour | 0.5 ppm | MT DHES 1998
| | 24-hour | 0.10 ppm
| | Annual | 0.02 ppm
| Nevada | 1°: 24-hour | 365 μg/m^3^ (0.14 ppm) | NV DCNR 1998
| | Annual | 80 μg/m^3^ (0.03 ppm)
| | 2°: 24-hour | 1300 μg/m^3^ (0.5 ppm)
| | Annual | 260 μg/m^3^ (0.1 ppm)
| New Mexico | 24-hour^e^ | 0.10 ppm | NM ED 1998
| | Annual^e^ | 0.02 ppm
| | 3-hour^f^ | 0.50 ppm
| | 24-hour^f^ | 0.14 ppm
| | Annual^f^ | 0.03 ppm
| New York | 3-hour | 0.25 ppm^g^; 0.50 ppm^h^ | NY DEC 1998
| | 24-hour | 0.10 ppm^g^; 0.14 ppm^h^
| | Annual | 0.03 ppm
| North Dakota | 1-hour | 715 μg/m^3^ (0.27 ppm) | ND SDHCL 1998
| | 24-hour | 260 μg/m^3^ (0.10 ppm)
| | Annual | 60 μg/m^3^ (0.02 ppm)
| Oregon | 3-hour | 0.02 ppm | OR DEQ 1998
| | 24-hour | 0.10 ppm
| | Annual | 0.50 ppm
| Washington | 1-hour^h^ | 0.4 ppm | WA DE 1998
| | 1-hour^i^ | 0.25 ppm
| | 24-hour | 0.1 ppm
| | Annual | 0.02 ppm
| Wyoming | 3-hour | 1300 μg/m^3^ (0.50 ppm) | WY DEQ 1998
| | 24-hour | 260 μg/m^3^ (0.10 ppm)
| | Annual | 60 μg/m^3^ (0.02 ppm)

a The Working Group on the Evaluation of Carcinogenic Risks to Humans concluded that this agent is not classifiable as to its carcinogenicity to humans. There is inadequate evidence in humans and limited evidence in animals.

b Not to be exceeded more than once per year.

c State regulations are not necessarily applied state-wide. For specific information as to the areas affected by the regulations, refer to the corresponding state’s code of regulations. All states not listed have adopted the federal ambient air standards without modification. When designated, 1° indicates primary standards and 2° indicates secondary (more stringent) standards.

d Not to be exceeded more than eighteen times in any twelve consecutive months.

e For the state except on area within 3.5 miles of Chino Mines Company smelter furnace stack at Hurley.

f For area within 3.5 miles of Chino Mines Company smelter furnace stack at Hurley.

g 99% of the 3 or 24-hour average concentrations shall not exceed this standard.

h Not to be exceeded more than once per year

i Not to be exceeded more than twice per week.

ACGIH = American Conference of Governmental Industrial Hygienists; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DOT = Department of Transportation; DOT-IMO = Department of Transportation/International Maritime Organization; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FR = Federal Register; IARC = International Agency for Research on Cancer; NAAQS = National Ambient Air Quality Standard; NIOSH = National Institute for Occupational Safety and Health; OSHA = Occupational Safety and Health Administration; OSW = Office of Solid Wastes; PEL = Permissible Exposure Limit; REL = Recommended Exposure Limit; STEL = Short Term Exposure Limit; TLV = Threshold Limit Value; TPQ = Threshold Planning Quantity; TWA = Time-Weighted Average; WHO = World Health Organization