# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Information regarding the chemical identity of sulfur dioxide is located in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of sulfur dioxide is located in Table 3-2.

Table 3-1 Chemical Identity of Sulfur Dioxide

Characteristic | Sulfur dioxide | Reference
Synonyms | Sulphur dioxide; sulfurous anhydride; sulfur oxide; sulfurous oxide; sulfurous acid anhydride | HSDB 1998
Registered trade name(s) | No data
Chemical formula | SO_2_ | HSDB 1998
Chemical structure | O=S=O | HSDB 1998
Identification numbers:
CAS registry | 7446-09-5 | HSDB 1998
NIOSH RTECS | WS4550000 | HSDB 1998
EPA hazardous waste | No data
OHM/TADS | 7216914 | OHM/TADS 1998
DOT/UN/NA/IMCO shipping | UN1079 | HSDB 1998
HSDB | 228 | HSDB 1998
NCI | No data

CAS = Chemical Abstracts Service; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 3-2 Physical and Chemical Properties of Sulfur Dioxide

Property | Sulfur Dioxide | Reference
Molecular weight | 64.06 | Lide 1993
Color | Colorless | Lide 1993
Physical state | Gas (or liquid) | Lide 1993
Melting point | −72.7°C | Lide 1993
Boiling point | −10°C | Lide 1993
Density | 2.927 g/L (gas); 1.434 (liquid) | Lide 1993
Odor | Strong odor, suffocating | Lide 1993
Odor threshold:
Water | No data | HSDB 1998
Air | Low: 1.175 mg/m^3^ (0.45 ppm); high: 12.5 mg/m^3^ (4.8 ppm); irritating: 5 mg/m^3^ (1.9 ppm)
Solubility:
Water at 0°C | 22.8 g/100 cc | HSDB 1998
Water at 20°C | 11.3 g/100 cc
Water at 90°C | 0.58 g/100 cc
Organic solvents | Acetic acid, alcohol, chloroform, ether, sulfuric acid
Partition coefficients:
Log K_ow_ | No data
Log K_oc_ | No data
Vapor Pressure | 3000 mm Hg at 20°C | HSDB 1998
Henry’s law constant | No data
Autoignition temperature | No data
Flashpoint | No data
Flammability limits | Nonflammable | HSDB 1998
Conversion factors | 2.62 mg/m^3^ = 1 ppm | IARC 1992
Explosive limits | No data

CAS = Chemical Abstracts Service; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; IARC = International Agency for Research on Cancer; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances