# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) 142 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 9994991, requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summaryI and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1-14 days), intermediate (15-364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MREs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as a hundredfold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agencywide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRL,s in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road, Mailstop E-29, Atlanta, Georgia 30333.

## Sulfur Dioxide Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Sulfur Dioxide
CAS Number: | 7446-09-5
Date: | November 1998
Profile Status: | Third Draft Post-Public
Route: | [x] Inhalation [ ] Oral
Duration: | [x] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 25
Species: | Human

[underlined: Minimal Risk Level]: [underlined: 0.01] [ ] mg/kg/day [x] ppm

[underlined: Reference]: Sheppard 1981. Exercise Increases Sulfur Dioxide-induced Bronchoconstriction in Asthmatic Subjects. Am Rev Respir Dis 123:486–491 7235370

[underlined: Experimental design]: (human study details or strain, number of animals per exposure/control groups, sex, dose administration details):

Two separate sets of studies on two separate groups of mild asthmatics were conducted. In the first set of studies, the effects of exercise on sulfur dioxide-induced bronchoconstriction was assessed in seven subjects (six men and one woman). The study design included an examination of the changes in specific airway resistance (SR_aw_) produced by moderate exercise (10 minute duration) alone, inhalation of 0.10, 0.25, and 0.50 ppm sulfur dioxide alone, and the combination of exercise and sulfur dioxide. Subjects breathed sulfur dioxide and/or air from a mouthpiece.

In the second set of studies, a comparison was made between the bronchoconstriction produced by breathing sulfur dioxide during exercise and that produced by eucapnic hyperventilation with sulfur dioxide in six subjects (four men and two women). In one experiment, subjects were exposed to 1.0 ppm sulfur dioxide from a mouthpiece while exercising for 5 minutes. In another experiment, subjects were exposed to 1.0 ppm sulfur dioxide and instructed to hyperventilate. The pattern of hyperventilation approximated the pattern of the breathing of subjects during exercise. In addition, the effect of increased tidal volumes on the measurements of SR_aw_ after sulfur dioxide-induced bronchoconstriction was assessed in one subject since deep breathing may modify bronchoconstriction, and because hyperpnea occurs after exercise.

[underlined: Effects noted in study and corresponding doses]:

In the seven subjects with mild asthma, inhalation of 0.25 ppm sulfur dioxide during the performance of moderate exercise significantly increased SR_aw_. Inhalation of 0.50 ppm during exercise significantly increased SR_aw_ in all seven subjects (p<0.05), and three developed wheezing and shortness of breath. During the corresponding period of exercise alone and during inhalation of 0.50 ppm at rest, SR_aw_ did not increase in any subject. After inhalation of 0.50 ppm of sulfur dioxide during exercise, ΔSR_aw_ (the difference between baseline specific airway resistance and specific airway resistance after inhalation of sulfur dioxide) was significantly greater than after exercise alone or inhalation of 0.50 ppm of sulfur dioxide at rest (p<0.05). Inhalation of 0.25 ppm sulfur dioxide during exercise significantly increased SR_aw_ in three of the seven subjects, and the increase in SR_aw_ for the group was significant (p<0.05). No subject developed wheezing or shortness of breath. During the corresponding period of exercise alone, SR_aw_ did not increase in any subject. In the two most responsive subjects, inhalation of 0.10 ppm significantly increased SR_aw_, and there was a dose-response relationship to 0.10, 0.25, and 0.50 ppm in the 2 subjects. ΔSR_aw_ at 0.10 ppm was slight and was approximately 2.5 L × cm H_2_0/L/s (units for ΔSR_aw_). At 0.25 ppm, ΔSR_aw_ was approximately 5 L × cm H_2_0/L/s. At 0.5 ppm, the ΔSR_aw_ exceeded 15 L × cm H_2_0/L/s.

In the second set of studies, in all six subjects, inhalation of 1 ppm of sulfur dioxide dramatically increased SR_aw_, both when it was delivered during exercise and during eucapnic hyperventilation (rapid, deep breathing to deplete arterial CO_2_). In every case, the increase in SR_aw_ was accompanied by dyspnea and audible wheezing. The magnitude of the increase in SR_aw_ was the same when subjects inhaled sulfur dioxide while they exercised or while they performed eucapnic hyperventilation at the same minute ventilation.

The study authors concluded that moderate exercise increases the bronchomotor effect of sulfur dioxide in subjects with asthma so the concentrations as low as 0.10 ppm can cause sigificant bronchoconstriction. However, the ΔSR_aw_ at 0.10 ppm was slight. In addition, the authors stated that the concentrations studied are sometimes equaled or exceeded in polluted urban air, and that their findings support the contention that sulfur dioxide is at least partially responsible for the observed association between air pollution and increased morbidity from asthma.

[underlined: Dose and endpoint used for MRL derivation]:

[]NOAEL [X] minimal LOAEL

0.1 ppm, bronchoconstriction in exercising asthmatics

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 3 for use of a minimal LOAEL
- [ ] 10 for extrapolation from animals to humans
- [X] 3 for human variability

The uncertainty factor for human variability addresses varying sensitivity among asthmatics and possible increased sensitivity in children. There is concern of increased sensitivity in children but there is not sufficient data to confirm it.

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose?]

If so, explain: No, the doses provided are author-provided.

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose]:

None

[underlined: Other additional studies or pertinent information which lend support to this MRL]:

Lung function changes in asthmatics exposed by inhalation to sulfur dioxide have been reported by other investigators. In a chamber study of moderately exercising asthmatics, the concentration of sulfur dioxide required to produce an increase in airway resistance 100% greater than the response to clean air [designated as PC(SO_2_)] has been determined (Horstman et al. 1986). Analysis of the cumulative percentage of subjects plotted as a function of PC(SO_2_) revealed that 25% of the subjects exhibited a PC(SO_2_) of 0.25 to 0.5 ppm sulfur dioxide. The study authors considered that the 25% of the mild asthmatics who were very sensitive to sulfur dioxide could possibly exhibit bronchoconstriction if they were to perform normal exercise routines in some highly industrialized areas of the United States. A dose-related increase in specific airway resistance was seen in asthmatics following a 3 minute exposure (via mouthpiece) to ≥0.25 ppm sulfur dioxide (Myers et al. 1986a; Myers et al. 1986b).

Increases in specific airway resistance were observed in moderately exercising asthmatics exposed oronasally to 0.25 ppm sulfur dioxide for 5 minutes (Bethel et al. 1985). This study could have also been used to develop an MRL. An uncertainty factor of 30 would have been required (10 for the use of a LOAEL and 3 for human variability). Dividing the LOAEL of 0.25 ppm by an uncertainty factor of 30 results in an MRL of 0.01 ppm, a value consistent with the MRL derived from the Sheppard et al. (1981) study. Some studies of asthmatics have reported a lack of significant lung function changes in asthmatics following exposures to 0.1-0.5 ppm (Jorres and Magnussen 1990; Koenig et al. 1990). Bronchoconstrictive responses to sulfur dioxide are highly variable among individual asthmatics (Horstman et al. 1986). In some studies asthmatics were preselected for sensitivity to sulfur dioxide and this may explain the range of sulfur dioxide-induced responses obtained by different investigators.

The dose level of 0.1 ppm sulfur dioxide can be considered a minimal LOAEL.

[underlined: Agency Contact (Chemical Manager)]: Hana Pohl

[underlined: Agency Review Date]: 1° review:_______

2° review:_______