# 8 REGULATIONS, ADVISORIES, AND GUIDELINES

MRLs are substance specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites.

ATSDR has derived an acute-duration inhalation MRL of 5 ppm for styrene. This MRL is based on a NOAEL of 49 ppm for alterations in tests of reaction time, memory, attention, color discrimination, and olfactory threshold in subjects exposed to styrene for 6 hours (Ska et al. 2003) and an uncertainty factor of 10 to account for human variability.

ATSDR has derived a chronic-duration inhalation MRL of 0.2 ppm for styrene. This MRL is based on a minimal LOAEL of 20 ppm estimated from a meta-analysis of data (Benignus et al. 2005) from occupational exposure studies demonstrating alterations in choice reaction time and color discrimination in styrene workers. The minimal LOAEL was adjusted for intermittent exposure (8 hours/day, 5 days/week) and divided by an uncertainty factor of 30 (3 for use of a minimal LOAEL and 10 for human variability).

EPA (IRIS 2009) has derived an inhalation reference concentration (RfC) of 1 mg/m^3^ (0.2 ppm) based on a NOAEL_HEC_ value of 34 mg/m^3^ in a cross-sectional study in workers finding central nervous system effects in workers exposed to >22 ppm (Mutti et al. 1984a) and an uncertainty factor of 30 (3 for the use less than chronic study, 3 for human variability, and 3 for database inadequacies).

ATSDR has derived an acute-duration oral MRL of 0.1 mg/kg/day for styrene. This MRL is based on a LOAEL of 100 mg/kg/day for impaired learning in rats exposed to styrene for 14 days (Husain et al. 1985) and an uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for extrapolation from rats to humans, and 10 for human variability).

EPA (IRIS 2009) has established an oral reference dose (RfD) of 0.2 mg/kg/day based on a NOAEL of 200 mg/kg/day from a subchronic oral toxicity study in beagle dogs in which red blood cell and liver effects was observed (Quast et al. 1979). The uncertainty factor used in this assessment was 1,000 (10 for interspecies extrapolation, 10 for human variability variation, and 10 for extrapolation of subchronic effects to chronic effects).

The international and national regulations, advisories, and guidelines regarding styrene in air, water, and other media are summarized in Table 8-1.

Table 8-1 Regulations, Advisories, and Guidelines Applicable to Styrene

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | Group 2B^a^ | IARC 2006
WHO | Air quality guidelines | | WHO 2000
WHO | TWA based on effects other than cancer or odor/annoyance using an averaging time of 1 week | 0.26 mg/m^3^ | WHO 2000
WHO | Based on sensory effects or annoyance reactions, using an averaging time of 30 minutes | | WHO 2000
WHO | Detection threshold | 0.07 mg/m^3^ | WHO 2000
WHO | Recognition threshold | 0.21-0.28 mg/m^3^ | WHO 2000
WHO | Guideline value | 0.07 mg/m^3^ | WHO 2000
WHO | Drinking water quality guidelines | 0.02 mg/L^b^ | WHO 2004
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV (8-hour TWA) | 85 mg/m^3^ | ACGIH 2008
ACGIH | STEL (15-minute TWA) | 170 mg/m^3^ | ACGIH 2008
AIHA | ERPG-1^c^ | 213 mg/m^3^ | AIHA 1995
AIHA | ERPG-2^c^ | 1,065 mg/m^3^ | AIHA 1995
AIHA | ERPG-3^c^ | 4,260 mg/m^3^ | AIHA 1995
EPA | AEGL-1^d^ | | EPA 2007a
EPA | 10 minutes | 85 mg/m^3^ | EPA 2007a
EPA | 30 minutes | 85 mg/m^3^ | EPA 2007a
EPA | 60 minutes | 85 mg/m^3^ | EPA 2007a
EPA | 4 hours | 85 mg/m^3^ | EPA 2007a
EPA | 8 hours | 85 mg/m^3^ | EPA 2007a
EPA | AEGL-2^d^ | | EPA 2007a
EPA | 10 minutes | 980 mg/m^3^ | EPA 2007a
EPA | 30 minutes | 682 mg/m^3^ | EPA 2007a
EPA | 60 minutes | 554 mg/m^3^ | EPA 2007a
EPA | 4 hours | 554 mg/m^3^ | EPA 2007a
EPA | 8 hours | 554 mg/m^3^ | EPA 2007a
EPA | AEGL-3^d^ | | EPA 2007a
EPA | 10 minutes^e^ | 8.094 mg/m^3^ (1,862 ppm) | EPA 2007a
EPA | 30 minutes^e^ | 8.094 mg/m^3^ (1,862 ppm) | EPA 2007a
EPA | 60 minutes^e^ | 4,686 mg/m^3^ (1,078 ppm) | EPA 2007a
EPA | 4 hours | 1.448 mg/m^3^ (333 ppm) | EPA 2007a
EPA | 8 hours | 1.448 mg/m^3^ (333 ppm) | EPA 2007a
EPA | Level of distinct odor awareness | 2.3 mg/m^3^ (0.5 ppm) | EPA 2007a
EPA | Hazardous air pollutant | Yes | EPA 2007c; 42 USC 7412
NIOSH | REL (10-hour TWA) | 50 ppm | NIOSH 2005
NIOSH | STEL (15-minute TWA) | 100 ppm | NIOSH 2005
NIOSH | IDLH | 700 ppm | NIOSH 2005
OSHA | PEL (8-hour TWA) for general industry | 100 ppm | OSHA 2006c; 29 CFR 1910.1000, Table Z-2
OSHA | Acceptable ceiling concentration | 200 ppm | OSHA 2006c; 29 CFR 1910.1000, Table Z-2
OSHA | Acceptable maximum peak above the acceptable ceiling concentration for an 8-hour shift for a maximum duration of 5 minutes in any 3 hours | 600 ppm | OSHA 2006c; 29 CFR 1910.1000, Table Z-2
OSHA | PEL (8-hour TWA) for shipyard industry | 100 ppm | OSHA 2006a; 29 CFR 1915.1000
OSHA | PEL (8-hour TWA) for construction industry | 100 ppm | OSHA 2006b; 29 CFR 1926.55, Appendix A
b. Water
EPA | Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act | Yes | EPA 2007b; 40 CFR 116.4
EPA | Drinking water standards and health advisories | | EPA 2006
EPA | 1 -day health advisory for a 10-kg child | 20 mg/L | EPA 2006
EPA | 10-day health advisory for a 10-kg child | 20 mg/L | EPA 2006
EPA | DWEL | 7 mg/L | EPA 2006
EPA | Lifetime | 0.1 mg/L | EPA 2006
EPA | 10^-4^ Cancer risk | No data | EPA 2006
EPA | Master Testing List | Yes^f^ | EPA 2007d
EPA | National primary drinking water standards^g^ | | EPA 2003
EPA | MCLG | 0.1 mg/L | EPA 2003
EPA | MCL | 0.1 mg/L | EPA 2003
EPA | Public health goal | 0.1 mg/L | EPA 2003
EPA | Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | 1,000 pounds | EPA 2007e; 40 CFR 117.3
c. Food
FDA | Bottled drinking water | 0.1 mg/L | FDA 2006a; 21 CFR 165.110
FDA | Food additives permitted for direct addition to food for human consumption | Yes | FDA 2007b; 21 CFR 172
FDA | Indirect food additives: adhesives and components of coatings | Yes | FDA 2006b; 21 CFR 175
FDA | EAFUS | Yes^h^ | FDA 2007a
d. Other
ACGIH | Carcinogenicity classification | A4^i^ | ACGIH 2008
ACGIH | Biological exposure indices (end of shift at end of workweek) | | ACGIH 2008
ACGIH | Sum of mandelic acid and phenyl glyoxylic acid in urine | 400 mg/g creatinine | ACGIH 2008
ACGIH | Styrene in venous blood | 0.2 mg/L | ACGIH 2008
EPA | Carcinogenicity classification | No data | IRIS 2009
EPA | RfC | 1 mg/m^3^ (0,2 ppm)
EPA | RfD | 0.2 mg/kg/day
EPA | Superfund, emergency planning, and community right-to-know
EPA | Designated CERCLA hazardous substance | Yes^j^ | EPA 2007f; 40 CFR 302.4
EPA | Reportable quantity | 1,000 pounds | EPA 2007f; 40 CFR 302.4
EPA | Effective date of toxic chemical release reporting | 01/01/2000 | EPA 2007g; 40 CFR 372.65
NTP | Carcinogenicity classification | No data | NTP 2005

a Group 2B: possibly carcinogenic to humans

b Concentrations of the substance at or below the health-based guideline value may affect the appearance, taste, or odor of the water, leading to consumer complaints (WHO 2004).

c ERPG-1 is the maximum airborne concentration below which nearly all individuals could be exposed for up to 1 hour without experiencing other than mild, transient health effects; ERPG-2 is the maximum airborne concentration below which nearly all individuals could be exposed for up to 1 hour without experiencing irreversible or other serious adverse effects; and ERPG-3 is the maximum airborne concentration below which nearly all individuals could be exposed for up to 1 hour without life-threatening health effects (AIHA 1995).

d AEGL-1 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience notable discomfort, irritation, or certain asymptomatic nonsensory effects, however, the effects are not disabling and are transient and reversible upon cessation of exposure; AEGL-2 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience irreversible or other serious, long-lasting adverse health effects or an impaired ability to escape; and AEGL-3 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience life-threatening health effects or death (EPA 2007a).

e Safety considerations against the hazard of explosion must be taken into account.

f Styrene was recommended to the MTL by the U.S. EPA’s Office of Pollution Prevention and Toxics on the basis of the SIDS. Styrene was added to the MTL in 1993 and the chemical testing program is currently underway by way of a VTA. The testing needs include health effects, environmental effects, and environmental fate and exposure.

g Potential health effects from exposure above the MCL include liver, kidney, or circulatory system problems. Common sources of contaminant in drinking water include discharges from rubber and plastic factories and leaching from landfills (EPA 2003).

h The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

i A4: not classifiable as a human carcinogen

j Designated CERCLA hazardous substance pursuant to Section 311(b)(2) of the Clean Water Act and Section 112 of the Clean Air Act.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; AIHA = American Industrial Hygiene Association; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; ERPG = emergency response planning guidelines; FDA = Food and Drug Administration; GRAS = Generally Recognized As Safe; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; MCLG = maximum contaminant level goal; MTL = Master Testing List; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; SIDS = Screening Information Data Sets; STEL = short-term expsoure limit; TLV = threshold limit values; TWA = time-weighted average; USC = United States Code; VTA = Voluntary Testing Agreement; WHO = World Health Organization