# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of styrene is located in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of styrene is located in Table 4-2.

Table 4-1 Chemical Identity of Styrene

Characteristic | Information | Reference
Chemical name | Styrene | Verschueren 1983
Synonym(s) | cinnamene; cinnamol; ethenylbenzene; phenylethylene; styrol; vinylbenzene; | Verschueren 1983; HSDB 2009
Registered trade name(s) | No data
Chemical formula | C_8_H_8_ | Windholz 1983
Chemical structure | [image] | IARC 1994
Identification numbers:
CAS registry | 100-42-5 | Sax and Lewis 1987
NIOSH RTECS | WL3675000 | HSDB 2009
EPA hazardous waste | No data
EINICS | 202-851-5 | ESIS 2009
OHM/TADS | 7216911 | HSDB 2009
DOT/UN/NA/IMDG shipping | IMDG 3.3 | HSDB 2009
| UN 2055 | HSDB 2009
HSDB | 171 | HSDB 2009
NCI | C02200 | HSDB 2009

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; ESIS = European chemical Substances Information System HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Styrene

Property | Information | Reference
Molecular weight | 104.15 | O’Neil et al. 2001 Lide 2005
Color | Colorless to yellowish | Windholz 1983
Physical state | Liquid | Sax and Lewis 1987
Melting point | -30.6 °C | O’Neil et al. 2001
Boiling point | 145.2 °C | Verschueren 2001; Weast 1985
Density at 20 °C | 0.9059 | O’Neil et al. 2001
Odor | If pure, sweet and pleasant; commonly contains aldehydes which provide it with a penetrating, sharp, and unpleasant smell | Verschueren 2001
Odor threshold:
Water | 0.73 mg/L | HSDB 2009
| 0.011 mg/L | Amoore and Hautala 1983
Air | 1.36 mg/m^3^ | Amoore and Hautala 1983
Solubility:
Water at 15 °C | 280 mg/L | Verschueren 2001
Water at 20 °C | 300 mg/L
Water at 40 °C | 400 mg/L
Organic solvents | Soluble in alcohol, ether, acetone, carbon disulfide | Windholz 1983
Partition coefficients:
Log K_ow_ | 2.95 | Hansch et al. 1995; EPA 1984a
Log K_oc_ | 2.96 | Sabljic et al. 1995
Vapor pressure at 20 °C | 5 mmHg | Verschueren 2001
Henry’s law constant at 25 °C | 2.61x10^-3^ atm-m^3^/mol (calculated) | EPA 1981
Autoignition temperature | 914 °F (490 °C) | Sax and Lewis 1987
Flashpoint | 87 °F (31 °C) (closed cup); 34.4°C (Tag open cup) | O’Neil et al. 2001;; Kirk-Othmer 2001
Flammability limits | No data; 0.9 (lower); 6.8 (higher); 1.1 (lower); 6.1 (higher) | CEFIC 2008;; Kirk-Othmer 2001
Conversion factors | 1 mg/m^3^=0.23 ppm;; 1 ppm=4.33 mg/m^3^ | Verschueren 2001