# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Environmental Medicine, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Environmental Medicine, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-62, Atlanta, Georgia 30333.

## Styrene Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Styrene
CAS Numbers: | 100-42-5
Date: | June 2010
Profile Status: | Final Draft Post-Public Comment
Route: | [X] Inhalation [ ] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 17
Species: | Human

[underlined: Minimal Risk Level]: 5 [ ] mg/kg/day [X] ppm

[underlined: Reference]: Ska B, Vyskocil A, Tardif R, . 2003. Effects of peak concentrations on the neurotoxicity of styrene in volunteers. Hum Exper Toxicol 22:407–415 12948080 .

[underlined: Experimental design]: Groups of 24 healthy men (aged 20–50 years) were exposed to 1 ppm (control exposure), 24 ppm, and 24 ppm with four 15-minute exposures to peak concentrations of 49 ppm, 49 ppm, or 49 ppm with four 15-minute exposures to peak concentrations of 98 ppm for 6 hours. The subjects were exposed to each concentration with a 2-week period between each session. The subjects did not have a history of styrene exposure. At the end of the exposure session the subjects were tested for color discrimination (using the Lanthony D-15 desaturated panel), vision contrast, olfactory threshold, simple reaction time, color word stress (response time), symbol digit matching, digit span memory, and continuous tracking. The subjects were also given a questionnaire to assess mood and symptoms.

[underlined: Effect noted in study and corresponding doses]: No significant styrene-related alterations in performance on color discrimination, olfactory threshold, neurobehavioral tests, mood, or subjective symptoms were found.

[underlined: Dose and end point used for MRL derivation]:

[X] NOAEL [ ] LOAEL

A NOAEL of 49 ppm for the lack of alterations in tests of simple reaction time, choice reaction time, memory, or attention.

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [ ] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? No, because the subjects were only exposed once for 6 hours; adjusting this NOAEL from intermittent exposure to continuous exposure 0.04 ppm) may result in an overly conservative MRL.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Exposure to 99 ppm for 7 hours or 376 ppm for 1 hour (Stewart et al. 1968) resulted in eye irritation in experimental subjects; nasal irritation was also reported at 376 ppm. A significant inhibition of the vestibular-oculomotor system was observed in subjects exposed to 87 ppm for 1 hour (Ödkvist et al. 1982). Studies by Stewart et al. (1968) found alterations in tests of balance or coordination in subjects exposed to 376 ppm for 1 hour, but not after exposure to 99 ppm for 7 hours or 216 ppm for 1 hour; the test used in the Stewart et al. (1968) studies is probably less sensitive than those used by Ödkvist et al. (1982). No significant alterations in performance on neurobehavioral tests were observed in subjects exposed to 20 ppm for 3 hours (Seeber et al. 2004).

The available data suggest that the nervous system is the most sensitive target of styrene toxicity following acute-duration inhalation exposure. The lowest LOAEL for a relevant end point in humans is 87 ppm for vestibular impairment in subjects exposed to styrene for 1 hour (Ödkvist et al. 1982). A similar LOAEL (80 ppm) was identified for nasal effects in mice exposed to styrene for 3 days (Cruzan et al. 2001); this effect was not considered suitable as the basis of an MRL. As stated previously, mice appear to have a greater capacity than humans to generate the reactive metabolite, styrene oxide, in the nasal cavity and a lower capacity to detoxify styrene oxide (Green et al. 2001a). The identification of the nervous system as the critical target of toxicity for styrene is supported by a large number of occupational exposure studies. Delays in reaction time have been observed in workers exposed to 21.9–92 ppm (Cherry et al. 1980; Fallas et al. 1992; Gamberale et al. 1976; Jegaden et al. 1993; Mutti et al. 1984a; Tsai and Chen 1996) and vestibular effects have been observed at 18–36 ppm (Calabrese et al. 1996; Möller et al. 1990; Toppila et al. 2006).

[underlined: Agency Contact (Chemical Manager)]: Selene Chou

## Styrene Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Styrene
CAS Numbers: | 100-42-5
Date: | June 2010
Profile Status: | Final Draft Post-Public Comment
Route: | [X] Inhalation [ ] Oral
Duration: | [] Acute [ ] Intermediate [X] Chronic
Graph Key: | 61
Species: | Human

[underlined: Minimal Risk Level]: 0.2 [ ] mg/kg/day [X] ppm

[underlined: Reference]: Benignus VA, Geller AM, Boyes WK, . 2005. Human neurobehavioral effects of long-term exposure to styrene: a meta-analysis. Environ Health Perspect 113:532–538 15866759 .

[underlined: Experimental design]: Benignus et al. (2005) used data from occupational exposure studies examining color vision impairment (Campagna et al. 1996; Eguchi et al. 1995; Gobba et al. 1991; Gong et al. 2002; Kishi et al. 2001) and delays in choice reaction time (Jegaden et al. 1993; Mutti et al. 1984a; Triebig et al. 1989; Tsai and Chen 1996). Average styrene exposure concentrations for each study were estimated from individual data reported in the papers; for studies reporting individual data as urinary mandelic acid levels, standardized methods for converting to styrene exposure levels were used. Cumulative styrene exposure was estimated by multiplying exposure level by length of employment. A common metric of effect magnitude (percentage of baseline) was calculated for the different neurological effects.

[underlined: Effect noted in study and corresponding doses]: A significant linear relationship between choice reaction time and cumulative styrene exposure was found; cumulative exposure accounted for 91% of the variance in reaction time. Similarly, a significant relationship between CCI and cumulative styrene exposure was found, with cumulative exposure accounting for 35% of the variance in CCI. Using the regression equations for these two effects, the investigators estimated that exposure to 150 ppm for 8 work-years would result in a 50% increase in choice reaction time and a 17% increase in CCI score; exposure to 20 ppm for 8 work-years would result in a 6.5% increase in choice reaction time and a 2.23% increase in CCI score. As discussed in Benignus et al. (2005), a 7% decrease in reaction time would prevent 58,000–70,000 injuries per year from automobile accidents. The investigators also noted that CCI increases with age, and the rate of increase is about 10% per 13 years of age; thus, a 2.23% decrease in color perception would be roughly equivalent to 2.9 additional years of age. Based on this analysis, 20 ppm is considered a LOAEL for neurological effects.

[underlined: Dose and end point used for MRL derivation]:

[ ] NOAEL [X] LOAEL

A minimal LOAEL of 20 ppm in the Benignus et al. (2005) meta-analysis was selected as the point of departure for the chronic-duration inhalation MRL. The LOAEL was classified as a minimal LOAEL based on the findings of Triebig et al. (2001) that alterations in color vision were reversible and the workers were not aware of any changes in color vision.

[underlined: Uncertainty Factors used in MRL derivation]: 30

- [X] 3 for use of a minimal LOAEL
- [ ] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Yes.

LOAEL_ADJ_ = 20 ppm x 8 hours/24 hours x 5 days/7 days

LOAEL_ADJ_ = 4.8 ppm

[underlined: Other additional studies or pertinent information that lend support to this MRL]: A large number of occupational exposure studies have examined the toxicity of styrene; however, most of these studies have focused on the potential neurotoxicity of styrene, which appears to be the most sensitive effect. Two common limitations of the occupational exposure studies are: (1) the range of current styrene levels for the workers is typically large and it is difficult to ascribe the observed effects to the mean or median exposure level and (2) historical exposure to higher styrene levels are not adequately taken into consideration. The use of urinary levels of mandelic acid, phenylglyoxylic acid, or mandelic acid plus phenylglyoxylic acid levels as biomarkers for styrene exposure eliminates another common limitation of styrene occupational exposure studies, which is poor characterization of styrene exposure levels due to the lack of personal air samples and the workers’ use of respirators with or without canisters.

A variety of neurological effects have been reported in workers at reinforced plastic manufacturing facilities, including decreased color discrimination, slowed reaction time, impaired performance on other neurobehavioral tests, permanent hearing threshold shifts, vestibular effects, altered nerve conduction velocity, and increases in subjective symptoms. A summary of the results of studies for some of these neurological effects is presented in Table A-1 (more details regarding these studies and other studies of neurological effects in styrene workers are presented in Table 3-2). An alteration in color discrimination is one of the more consistently found neurological effects; it may also be one of the more sensitive effects. Color discrimination was typically measured using the Lanthony desaturated panel D-15 test in which the subjects were asked to arrange 15 painted caps in a line with definite chromatic sequence; the TCDS and CCI are used to quantitatively analyze the results. LOAEL values of 6–93 ppm have been identified; however, these LOAELs often reflect the mean exposure level or the lower end of the range of exposure levels. Other neurological effects that have been frequently found include alterations in performance on neurobehavioral tests, particularly reaction time, in workers exposed to ≥21 ppm; vestibular alterations at ≥18 ppm; and increased frequency of clinical symptoms (e.g., tiredness and headaches in workers exposed to ≥6 ppm). Hearing loss and alterations in nerve conduction velocity have also been reported in some studies, but the finding is not consistent across studies.

Table A-1 Results of Selected Human Neurotoxicity Studies

Result | Reference | NOAEL (ppm) | LOAEL (ppm)
Decreased color discrimination | Chia et al. (1994) | | 6
| Kishi et al. (2001) | 4 | 10
| Gong et al. (2002) | | 10
| Gobba et al. (1991) | | 16
| Triebig et al. 2001 | | 20
| Iregren et al. (2005) | | 22
| Fallas et al. (1992) | | 24.3
| Campagna et al. (1996) | | 265
| Eguchi et al. (1995) | 8 | 93
Neurological symptoms | Flodin et al. (1989) | 6
| Edling et al. (1993) | 8.6
| Checkoway et al. (1992) | 10.8 | 18.9
| Cherry et al. 1980 | | 92
Vestibular effects | Möller et al. (1990) | | 18
| Toppila et al. (2006) | | 24.8
| Calabrese et al. (1996) | | 36
Reaction time | Edling et al. (1993) | 8.6 | 21.9
| Tsai and Chen (1996) | | 21.9
| Jegaden et al. (1993) | | 22.68
| Fallas et al. (1992) | | 24.3
| Mutti et al. (1984a) | | 25
| Gamberale et al. (1976) | | 4,755
| Cherry et al. (1980) | | 92

Non-neurological effects observed in styrene workers include obstructive lung effects (Chmielewski and Renke 1975), mild hematological alterations (Checkoway and Williams 1982; Stengel et al. 1990; Thiess and Friedheim 1978), and impaired immune response to concanavalin (Somorowská et al. 1999; Tulinska et al. 2000). Although exposure levels were not reported in all of these studies, effects were typically observed at styrene concentrations of >20 ppm. Clinical chemistry studies did not find alterations indicative of impaired liver (Härkönen et al. 1984; Hotz et al. 1980; Lorimer et al. 1978; Thiess and Friedheim 1978) or kidney (Verplanke and Herber 1998; Viau et al. 1987; Vyskocil et al. 1989) function in workers exposed to ≥24 ppm.

Chronic-duration studies in laboratory animals identify the nasal olfactory epithelium as the most sensitive end point. Atrophic and/or degenerative changes were observed in rats exposed to 50 ppm styrene 6 hours/day, 5 days/week for 104 weeks (Cruzan et al. 1998) and respiratory metaplasia in the nasal olfactory epithelium were observed in mice exposed to 20 ppm 6 hours/day, 5 days/week for 98–104 weeks (Cruzan et al. 2001). As noted previously, mice do not appear to be a good model for potential respiratory effects in humans.

In addition to the studies included in the Benignus et al. (2005) meta-analysis, a LOAEL of 20 ppm is supported by a color discrimination study conducted by Triebig et al. (2001). In this study, significant increases in CCI values were observed in styrene workers with urinary mandelic acid plus phenylglyoxylic acid levels of ≥472 mg/g creatinine (approximately 20 ppm air styrene concentration), when compared to >95^th^ percentile age-dependent reference CCI values. An advantage of the Triebig et al. (2001) study is that individual exposure and CCI data were reported, which diminishes the problem of ascribing an observed effect to the mean or median concentration and the study addresses the issue of biological relevance because the CCI scores were compared to the 95^th^ percentile of age-dependent reference values rather than values in the control group.

In comparisons between styrene workers and a control group employed at the same facility without styrene exposure, Triebig et al. (2001) found no significant differences in CCI scores between workers and controls when the tests were conducted on a Monday morning, but CCI scores were significantly different when measured on a Thursday afternoon. Within the styrene-exposed workers, CCI scores on Monday morning and Thursday afternoon were not significantly different. After a 4-week nonexposure period, the CCI scores were significantly reduced in the styrene workers. After styrene exposure levels were lowered, no difference between workers and controls was observed on Monday morning or Thursday afternoon. However, among styrene workers, there were significant differences between Monday morning and Thursday afternoon measurements and between Monday morning and postvacation levels. These findings provide suggestive evidence that the alterations in color discrimination were reversible.

[underlined: Agency Contact (Chemical Manager)]: Selene Chou

## Styrene Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Styrene
CAS Numbers: | 100-42-5
Date: | June 2010
Profile Status: | Final Draft Post-Public Comment
Route: | [] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 3
Species: | Rat

[underlined: Minimal Risk Level]: 0.1 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Husain R, Srivastava SP, Seth PK. 1985. Some behavioral effects of early styrene intoxication in experimental animals. Arch Toxicol 57:53–55.4015399

[underlined: Experimental design]: Groups of 15 male Wistar rats were administered by gavage 0, 100, or 200 mg/kg/day styrene in ground nut oil for 14 consecutive days. Spontaneous motor activity for a period of 10 minutes was measured 24 hours after the last dose. After baseline activity was measured, the rats received an intraperitoneal injection of 2.5 mg/kg amphetamine, and amphetamine-induced spontaneous motor activity was measured. Two days after exposure termination, acquisition training was initiated using a Cook’s pole climbing apparatus. Learning was assessed by measuring the number of times the rat climbed the pole after the conditioned stimulus to avoid the foot-shock unconditioned stimulus. The rats were tested for 4 days. Noradrenaline, dopamine, and serotonin levels were measured in seven regions of the brain in six rats/group killed after the acquisition training.

[underlined: Effect noted in study and corresponding doses]: No overt signs of toxicity were observed. No significant alterations in locomotor activity were observed with or without amphetamine induction. Significantly greater increases in percent avoidance response (indicative of impaired learning) were observed at 100 and 200 mg/kg/day; no difference was found between the two styrene groups. The effects were observed on test days 3 and 4. Significant increases in the level of serotonin in the hypothalamus (70%), hippocampus (51%), and midbrain (29%) were observed at 200 mg/kg/day. Styrene did not affect brain noradrenaline and dopamine levels.

[underlined: Dose and end point used for MRL derivation]:

[ ] NOAEL [X] LOAEL

A LOAEL of 100 mg/kg/day for impaired learning

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: A limited number of studies have examined the acute toxicity of orally-administered styrene; these studies have examined potential neurotoxicity and developmental toxicity. No developmental effects were observed in rats administered a single dose of 300 mg/kg on gestational day 11 (Daston et al. 1991) or administered 300 mg/kg/day (administered as two daily doses of 150 mg/kg) on gestational days 6–15 (Murray et al. 1978). Impaired learning was observed in rats administered via gavage 100 or 200 mg/kg/day for 14 days (Husain et al. 1985); increases in serotonin levels in the hypothalamus, hippocampus, and midbrain were also observed at 200 mg/kg/day. In another study, increases in dopamine receptor binding was observed in rats administered a single gavage dose of 200 mg/kg (Agrawal et al. 1982).

Although there is a limited acute toxicity database, longer-term oral studies support the selection of neurotoxicity as the principal effect. The lowest LOAEL identified for a systemic effect is 400 mg/kg/day for Heinz body formation in dogs administered styrene by gavage for 561 days (Quast et al. 1979); the identified NOAEL was 200 mg/kg/day. Decreased spermatozoa counts were observed in adult rats administered 400 mg/kg 6 days/week for 60 days (Srivastava et al. 1989), young rats exposed via lactation on postnatal days 1–21 (maternal dose of 400 mg/kg/day) (Srivastava et al. 1992a), and young rats administered 200 mg/kg 6 days/week on postnatal days 1–61 (Srivastava et al. 1992b); the NOAELs identified in these three studies were 200, 200, and 100 mg/kg, respectively. Marked degeneration of the seminiferous tubules was also observed in the adult rats administered 400 mg/kg (Srivastava et al. 1989). Impaired learning was also observed in rats administered 500 mg/kg 5 days/week for 8 weeks (Bushnell 1994); a NOAEL was not identified in this study. The extensive inhalation toxicity database for styrene also supports the selection of neurotoxicity as the most sensitive target of toxicity; both the acute- and chronic-duration inhalation MRLs are based on neurological effects in humans. Neurological effects observed in chronically exposed styrene workers include decreased color discrimination, slowed reaction time, increased prevalence of neurological symptoms, and ototoxicity (hearing and vestibular effects).

[underlined: Agency Contact (Chemical Manager)]: Selene Chou