# 9 REFERENCES

* Cited in text

Aarkrog A. 1971. Prediction models for strontium-90 and caesium-137 levels in the human food chain. Health Phys 20:297–311.5108964
Aarkrog A. 1972. Are the rate factors in the ^90^Sr prediction models constant? Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59^th^ ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 447–456.
Aarkrog A, Dahlgaard H, Nielsen SP. 1999. Marine radioactivity in the Arctic: A retrospect of environmental studies in Greenland waters with emphasis on transport of ^90^Sr and ^137^Cs with the east Greenland current. Sci Total Environ 237/238:143–151.10568272
Aberg B, Crabo B, Ekman L, . 1968. Rapid uptake of radiostrontium in sperm. Acta Physiol Scand 74:381–383.5708561
*ACGIH. 1999a. Strontium. 1999 TLVs and BEIs: Threshold limit values for chemical substances and physical agents biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
*ACGIH. 1999b. Strontium chromate. 1999 TLVs and BEIs: Threshold limit values for chemical substances and physical agents biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
*ACGIH. 2002. Strontium chromate. 2000 TLVs and BEIs: Threshold limit values for chemical substances and physical agents biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
*Adams WT. 1975. Strontium. In: Bureau of Mines. Mineral facts and problems. 1975 edition. U.S. Department of the Interior. Bulletin 667, 1049–1056.
*ADEC. 2000. Maximum contaminant levels (MCLs). Title 18 environmental conservation: Chapter 80. Drinking water 18 AAC 80. Alaska Department of Environmental Conservation. http://www.state.ak.us/local/akpages/ENV.CONSERV/title18/aac80ndx.htm. June 13, 2000.
*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
Adler SS, Trobaugh FE. 1978. Hemopoiesis in diffusion chambers in strontium-89 marrow-ablated mice (40328). Proc Soc Exp Biol Med 159:260–265.714955
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
*Agency for Toxic Substances and Disease Registry. 1989. Agency for Toxic Substances and Disease Registry. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Federal Register 54(174):37618–37634.
*Agency for Toxic Substances and Disease Registry. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Subcommittee on Biomarkers of Organ Damage and Dysfunction, Agency for Toxic Substances and Disease Registry, Atlanta, GA.
*Agency for Toxic Substances and Disease Registry. 1999. Toxicological profile for ionizing radiation. Agency for Toxic Substances and Disease Registry, Atlanta, GA.
*Agency for Toxic Substances and Disease Registry. 2000. Toxicological profile for chromium. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
*Aghajanian GK, Marek GJ. 1999. Serotonin, via 5-HT_2A_ receptors, increases EPSCs in layer V pyramidal cells of prefrontal cortex by an asynchronous mode of glutamate release. Brain Res 825:161–171.10216183
Akerley W. 2000. Secondary leukemia. Twice a coincidence? Cancer 88(3):497–499.10649239
*Akleyev AV, Kossenko MM, Silkina LA, . 1995. Health effects of radiation incidents in the southern Urals. Stem Cells 13(Suppl. 1):58–68.7488969
*Alda JO, Escanero JF. 1985. Transport of calcium, magnesium and strontium by human serum proteins. Rev Esp Fisiol 41:145–150.4035051
Alexakhin RM, Ginsburg LR, Mednik IG, . 1994. Model of ^90^Sr cycling in a forest biogeocenosis. Sci Total Environ 157:83–91.
*Alexander FW, Clayton BE, Delves HT. 1973. The uptake and excretion by children of lead and other contaminants. International Symposium of Environmental and Health Aspects of Lead, Amsterdam, Oct. 2–6, 1972.
*Alexander FW, Clayton BE, Delves HT. 1974. Mineral and trace-metal balances in children receiving normal and synthetic diets. Quart J Med XLIII:89–111.
Alexander FW, Delves HT, Clayton BE. 1973. The uptake and excretion by children of lead and other contaminants. In: International Symposium of Environmental and Health Aspects of Lead, Amsterdam, Oct. 2–6, 1972, 319–331.
*Alfrey AC, Rudolph H, Smythe WR. 1975. Mineral metabolism in uremia. Kidney Int (Suppl.):85–89.
Allain P, Mauras Y, Premel-Cabic A, . 1991. Effects of an EDTA infusion on the urinary elimination of several elements in health subjects. Br J Clin Pharmacol 31:347–349.1905148
*Alimov R. 2003. Radioisotope thermoelectric generators: Bellona’s working paper. http://www.bellona.no/en/international/russia/navy/northern fleet/incidents/31772.html. December 08, 2003.
*Alm PE, Bloom GD. 1981a. Effects of norepinephrine on transmembrane calcium transport in rat mast cells. Int Arch Allergy Appl Immunol 66:427–438.6170595
*Alm PE, Bloom GD. 1981b. What - if any - is the role of adrenergic mechanisms in histamine release from mast cells? Agents Actions 11(1/2):60–66.6166168
*Altman PL, Dittmer DS. 1974. In: Biological handbooks: Biology data book. Vol. III. 2^nd^ ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
Amano H, Yanase N. 1990. Measurement of ^90^Sr in environmental samples by cation-exchange and liquid scintillation counting. Talanta 37(6):585–590.18964983
*Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
*Andersen ME, Clewell HJ III, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
Anderson HL, Brady PV, Gruenhagen SE, . 1999a. Cs, Sr, and Ba sorption on clays and Fe-oxides. DE 2001 7898.
*Anderson J, Kahn B, LaBone T, . 1999b. Solubility of various forms of strontium titanate in lungs: In vitro and in vivo studies. Health Phys 76(6):628–634.10334578
Anderson JJB. 1968. Effect of time on distribution of injected radiostrontium in the skeleton of young pigs. Health Phys 15:237–241.5676163
Anderson JJB. 1972. Whole-body retention of single injections of ^85^Sr in swine and dogs as a function of age: A review. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59^th^ ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 31–38.
Anderson JJB, Comar CL. 1968. Strontium retention as a function of age in the dog. Radiat Res 34:153–169.5644006
Anderson JJB, Balk MW, Crackel WC, . 1971a. Effects of calcitonin on ^85^Sr whole body retention in the dog. Nature (London) New Biol 232:93–94.
Anderson JJB, Crackel WC, Norton HW. 1972. Effect of time on distribution of injected radiostrontium in the skeleton of six-month-old swine. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59^th^ ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 123–136.
Anderson JJB, Greenfield JW, Posada JR, . 1970. Effect of estrogen on bone mineral turnover in mature female rats as measured by strontium-85. Proc Soc Exp Biol Med 135(3):883–886.5486727
Anderson JJB, Milin L, Crackel WC. 1971b. Effect of exercise on mineral and organic bone turnover in swine. J Appl Physiol 30(6):810–813.4996361
Ando A, Ando I. 1994. Biodistributions of radioactive bipositive metal ions in tumor-bearing animals. BioMetals 7(2):185–192.7511950
Andreyeva LP, Shvedov VL. 1977. [Changes in the rat hemopoietic system when exposed to Strontium 89 and Iodine 131 simultaneously]. Radiobiologiia 17(5):752–757. (Russian)594335
Anger KS, Aigner S, Bühler M, . 1980. [Quantitative whole-body bone scintigraphy. II. Pharmacokinetics of osteotropic radiopharmaceuticals]. Nuklearmedizin 19(3):97–107. (German)7465432
Angeyo KH, Patel JP, Mangala JM, . 1998. Measurement of trace element levels in Kenyan cigarettes with the energy dispersive x-ray fluorescence spectroscopy technique. J Trace Microprobe Tech 16(2):233–246.
Anonymous. 1966a. Mopping up strontium. Br Med J 2(521):1024.
Anonymous. 1966b. Strontium metabolism. Br Med J 2(524):1215–1216.5917828
Anonymous. 1969a. Calcium, phosphorus, and strontium metabolism in infants. Nutr Rev 27(9):254–256.4900945
Anonymous. 1969b. Strontium-90 contamination down. Nature 222:210.
*AOAC. 1990. Official methods of analysis of the association of official analytical chemists. 15^th^ ed. Methods 911.03, 973.66, 974.37.
*APHA. 1992. Strontium. Standard methods for the examination of water and wastewater, 18^th^ ed. American Public Health Association.
Apostoaei AI. 2002. Absorption of strontium from the gastrointestinal tract into plasma in healthy human adults. Health Phys 83(1):56–65.12075684
*Apostoli P, Giusti S, Bartoli D, . 1998. Multiple exposure to arsenic, antimony, and other elements in art glass manufacturing. Am J Ind Med 34:65–72.9617389
Apostoli P, Porru S, Morandi C, . 1997. Multiple determination of elements in human seminal plasma and spermatozoa. J Trace Elem Med Biol 11:182–184.9442469
*Apostolidis N, Paradellis T, Karydas A, . 1998. Calcium and strontium metabolic studies in patients on CAPD. Perit Dial Int 18(4):410–414.10505563
Appelgren LE, Nilsson A, Ullberg S. 1963. Autoradiographic localization of strontium 85 in osteosarcomas. Acta Radiol Ther Phys Biol 1(6):459–464.14102681
Appleton J. 1993. The structure of dentine after the injection of strontium chloride by backscattered electron imaging in the scanning electron microscope. Arch Oral Biol 38(1):1–4.8442716
*Appleton J. 1995. Changes in the plasma electrolytes and metabolites of the rat following acute exposure to sodium fluoride and strontium chloride. Arch Oral Biol 40(4):265–268.7605252
Arden NK, Major P, Poole JR, . 2002. Size at birth, adult intestinal calcium adsorption and 1,25(OH)2 vitamin D. Q J Med 95:15–21.
Ardissino G, Schmitt CP, Bianchi ML, . 2000. No difference in intestinal strontium absorption after oral or IV calcitrol in children with secondary hyperparathyroidism. Kidney Int 58:981–988.10972662
Argiro G, Atzei G, Boemi S, . 1998. A process for the recovery of strontium from the urine of patients injected with ^89^Sr. Appl Radiat Isot 49(7):777–778.9570096
Argyris BF, Reif AE. 1981. Lack of suppressor cell activity in the spleens of mice with radiation-induced osteogenic sarcomas. Cancer Res 41:839–844.6450637
*Armbrecht HJ, Boltz MA, Christakos S, . 1998. Capacity of 1,25-dihydroxyvitamin D to stimulate expression of calbindin D changes with age in the rat. Arch Biochem Biophys 352(2):159–164.9587402
*Armbrecht HJ, Wasserman RH, Bruns MEH. 1979. Effect of 1,25-dihydroxyvitamin D_3_ on intestinal calcium absorption in strontium-fed rats. Arch Biochem Biophys 192(2):466–473.107861
Arner A, Lövgren B, Uvelius B. 1983. The effects of Ca^2+^ and Sr^2+^ at different modes of activation in the smooth muscle of the rat portal vein. Acta Physiol Scand 117:541–545.6136154
Arskan Z, Tyson JF. 1999. Determination of calcium, magnesium and strontium in soils by flow injection flame atomic absorption spectrometry. Talanta 50:929–937.18967785
Artalejo CR, Garcia AG, Aunis D. 1987. Chromaffin cell calcium channel kinetics measured isotopically through fast calcium, strontium, and barium fluxes. J Biol Chem 262(2):915–926.2433271
*Arthur WJ, Janke DH. 1986. Radionuclide concentrations in wildlife occurring at a solid radioactive waste disposal area. Northwest Sci 60(3):154–165.
Arthur WJ, Markham OD. 1982. Radionuclide export and elimination by coyotes at two radioactive waste disposal areas in southeastern Idaho. Health Phys 43(3):493–500.7152910
*Ash P, Loutit JF. 1977. The ultrastructure of skeletal haemangio-sarcomas induced in mice by strontium-90. J Pathol 122:209–218.562397
Ashrafi MH, Spector PC, Curzon MEJ. 1980. Pre- and posteruptive effects of low doses of strontium on dental caries in the rat. Caries Res 14:341–346.6931644
Assimakopoulos PA, Divanes K, Pakou AA, . 1995. Radiostrontium transfer to sheep’s milk as a result of soil ingestion. Sci Total Environ 172:17–20.8560216
*ASTM. 1999. Methods D3352, D3920, D4185. 1999 Annual book of ASTM standards: Water and environmental technology. Vol. 11.02. American Society for Testing and Materials. http://www.astm.org.
*Atkinson G, Ennis M, Pearce FL. 1979. The effect of alkaline earth cations on the release of histamine from rat peritoneal mast cells treated with compound 48/80 and peptide 401. Br J Pharmacol 65:395–402.85466
*Audi L, Garcia-Ramirez M, Carrascosa A. 1999. Genetic determinants of bone mass. Horm Res 51(3):105–123. (Abstract)10461016
Augustin W, Gellerich F, Wiswedel I, . 1979. Inhibition of cation efflux by antioxidants during oscillatory ion transport in mitochondria. FEBS Lett 107(1):151–154.499538
Avenant-Oldewage A, Marx H. 2000. Manganese, nickel and strontium bioaccumulation in the tissues of the African sharptooth catfish, Clarias gariepinus from the Olifants River. Kruger National Park. Koedoe 43(2):17–33.
*AZ Dept Health Serv. 1999. Health based guidance levels for the ingestion of contaminants in drinking water (HBGL). Arizona Department of Health Services. http://www.hs.state.az.us/edc/oeh/hbgl.htm. Novemeber 15, 1999.
Bacon JR, Bain DC. 1995. Characterization of environmental water samples using strontium and lead stable isotope compositions. Environ Geochem Health 17(1):39–49.24194039
Bader H, Wilkes AB, Jean DH. 1970. The effect of hudroxylamine, mercaptans, divalent metals and chelators on (Na^+^ + K^+^)-ATPase. Biochim Biophys Acta 198:583–593.4244997
*Baes CF, Garten CT, Taylor FG, . 1986. Long-term environmental problems of radioactively contaminated land. Environ Int 12:543–553.
Bairakova AK. 1974. Dose and germ cell stage dependence of strontium 89 mutagenic effects in rat males. Strahlentherapie 148(4):394–396.
Balonov MI. 1997. Internal exposure of populations to long-lived radionuclides releases into the environment. Ciba Found Symp 203:120–133.9339314
Banno H, Imaizumi Y, Watanabe M. 1987. Cellular mechanisms of supersensitivity to acetylcholine and potassium ion after ciliary ganglionectomy in the rat iris sphincter muscle. Jpn J Pharmacol 43:153–163.3573423
*Baratta EJ, Ferri ES. 1966. Radionuclides in selected human tissues. Am Ind Hyg Assoc J 438–443.5971106
Bard D, Verger P, Hubert P. 1997. Chernobyl, 10 years after: Health consequences. Epidemiol Rev 19(2):187–204.9494782
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Barnes DWH, Carr TEF, Evans EP, . 1970. ^90^Sr-induced osteosarcomas in radiation chimaeras. Int J Radiat Biol 18(6):531–537.
*Barnes KW. 1997. Trace metal determinations in fruit, juice, and juice products using an axially viewed plasma. Atom Spectrosc 18(3):84–101.
*Barrie LA, Gregor D, Hargrave B, . 1992. Arctic contaminants: sources, occurrence and pathways. Sci Total Environ 122:1–74.1514103
*Barry WH, Marion AM, Harrison DC. 1972. The hemodynamic effects of strontium chloride in the intact dog. Proc Soc Exp Biol Med 141(1):52–58.5082321
*Bartholomay RC, Orr BR, Liszewski MJ, . 1995. Hydrologic conditions and distribution of selected radiochemical and chemical constituents in water, Snake River Plain aquifier, Idaho National Engineering Laboratory, Idaho, 1989 through 1991. Water-Resources Investigations Report 95-4175. Idaho Falls, Idaho: U.S. Geological Survey.
Barto R, Sips AJAM, van der Vijgh WJF, . 1995. Sensitive method for analysis of strontium in human and animal plasma by graphite furnace atomic absorption spectrophotometry. Clin Chem 41(8):1159–1163.7628091
Bates TH, Smith H. 1966a. Influence of polyphosphates on retention of radioactive strontium in rat and mouse. Nature 212:925–926.
Bates TH, Smith H. 1966b. Influence of sodium saliculate on radioactive strontium retention in rat and mouse. Nature 209:824–825.5922164
*Bauchinger M, Salassidis K, Braselmann H, . 1998. FISH-based analysis of stable translocations in a Techa river population. Int J Radiat Biol 73:605–612.9690678
Baud CA, Bang S, Lee HS, . 1968. X-ray studies of strontium incorporation into bone mineral in vivo. Calcif Tissue Res 2(Suppl.):6.
*Bauerova K, Koprda V, Harangzo M. 2001. Contribution to the penetration of radionuclides across the skin. Concentration dependence of stronium through the skin in vitro. J Appl Toxicol 21:241–243.11404837
Baverstock KF, Vennart J. 1976. Emergency reference levels for reactor accidents: A re-examination of the windscale reactor accident. Health Phys 30:339–344.946425
*Baziotis N, Yakoumakis E, Zissimopoulos A, . 1998. Strontium-89 chloride in the treatment of bone metastasis from breast cancer. Oncology 55:377–381.9732212
Beddington JR, Mills CA, Beards F, . 1989. Long-term changes in strontium-90 concentrations within a freshwater predator-prey system. J Fish Biol 35:679–686.
*Bekerus M. 1970. [Late reaction following radiation with Sr^90^-derma plates, followed up for 8 and more years]. Strahlentherapie 140(1):105–107. (German)5486784
*Benjamin SA, Boecker BB, Cuddihy RG, . 1976a. Nasal carcinomas in beagle dogs after inhalation of relatively soluble forms of beta-emitting radionuclides. Radiat Res 67(3):572–573.
*Benjamin SA, Boecker BB, Cuddihy RG, . 1979. Nasal carcinomas in beagles after inhalation of relatively soluble forms of beta-emitting radionuclides. J Natl Cancer Inst 63:133–139.286823
*Benjamin SA, Brooks AL, McClellan RO. 1976b. Biological effectiveness of ^239^Pu, ^144^Ce and ^90^Sr citrate in producing chromosome damage, bone-related tumours, liver tumours and life shortening in the Chinese hamster. In: Lewis M, ed. Biological and environmental effects of low-level radiation: Proceedings of a symposium on biological effects of low-level radiation pertinent to protection of man and his environment. Vienna: International Atomic Energy Agency, Vol. 2, 143–152.
*Benjamin SA, Hahn FF, Chiffelle TL, . 1975. Occurrence of hemangiosarcomas in beagles with internally deposited radionuclides. Cancer Res 35:1745–1755.1169116
*Benjamin SA, Jones RK, Snipes MB, . 1974a. Comparative effects of inhaled relatively insoluble forms of ^90^Y, ^144^Ce and ^90^Sr on canine peripheral lymphocyte function. In: Annual reports of the Inhalation Toxicology Research Institute. Albuquerque, NM: Inhalation Toxicology Research Institute, 192–196.
*Benjamin SA, Jones RK, Snipes MB, . 1976c. Comparative effects of inhaled relatively insoluble forms of ^90^Y, ^144^Ce, and ^90^Sr on canine peripheral lymphocyte function. In: Radiation and the lymphatic system: Proceedings of the fourteenth annual Hanford biology symposium at Richland, Washington, September 30-October 2, 1974. Springfield, VA: Energy Research and Development Administration, 90–99.
*Benjamin SA, Muggenburg BA, Boecker BB, . 1974b. Toxicity of inhaled ^90^SrCl_2_ in beagle dogs, VIII. In: Annual reports of the Inhalation Toxicology Research Institute. Albuquerque, NM: Inhalation Toxicology Research Institute, 89–92.
Ben-Josef E, Lucas DR, Vasan S, . 1995a. Selective accumulation of strontium-89 metastatic deposits in bone: Radio-histological correlation. Nucl Med Commun 16:457–463.7545802
*Ben-Josef E, Maughan RL, Vasan S, . 1995b. A direct measurement of strontium-89 activity in bone metastasis. Nucl Med Commun 16:452–456.7675358
Bennett BG. 1972. Fallout ^90^Sr in diet and human bone. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 457–468.
*Bennett M, Baker EE, Eastcott JW, . 1976. Selective elimination of marrow precursors with the bone-seeking isotope ^89^Sr: Implications for hemopoiesis, lymphopoiesis, viral leukemogenesis and infection. J Reticuloendothel Soc 20(1):71–87.781225
*Beresford NA, Mayes RW, MacEachern PJ, . 1999. The effectiveness of alginates to reduce the transfer of radiostrontium to the milk of dairy goats. J Environ Radioact 44:43–54.
*Berg D, Oberhausen E, Muth H. 1973. [Interaction of ^47^Ca, ^85^Sr, ^133^Ba and ^226^Ra with serum proteins]. Biophysik 10:309–319. (German)4791125
*Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag.
Berger VHJ, Eger W. 1965. Über den mechanismus der strontiumeinlagerung ins knochengewebe. Acta Histochem (Jena) 22:298–308.4225675
Berman MC, King SB. 1990. Stoichiometries of calcium and strontium transport coupled to ATP and acetyl phosphate hydrolysis by skeletal sarcoplasmic reticulum. Biochim Biophys Acta 1029:235–240.2245209
Bernard SR, Nestor CW. 1980. Studies of age-dependent strontium metabolism with application to fallout data. In: International Radiation Protection Society, ed. Radiation protection: A systemic approach to safety: Proceedings of the 5th congress of the International Radiation Protection Society, Jerusalem, March 1980. New York, NY: Pergamon Press, Vol. 2, 1083–1086.
*Best LC, Bone EA, Russell RGG. 1981. Strontium ions induce production of thromboxane B_2_ and secretion of 5-hydroxytryptamine in washed human platelets. Biochem Pharmacol 30:635–637.6268118
Betti M, Giannarelli S, Hiernaut T, . 1996. Detection of trace radioisotopes in soil, sediment and vegetation by glow discharge mass spectrometry. Fresenius J Anal Chem 355:642–646.
*Bhattacharyya MH, Silbergeld EK, Jeffery E, . 1995. Metal-induced osteotoxicities. In: Goyer RA, Klaassen CD, Waalkes MP, eds. Metal toxicology. New York, NY: Academic Press, 465–510.
Bialkowski MM, Wierzbicki JG, Porter AT. 1997. Modeling of internal dose distributions during SR-89 treatment of a patient with bone metastases. Cancer Biother Radiopharm 12(5):355–362.10851487
*Bianchi ML, Ardissino GL, Schmitt CP, . 1999. No difference in intestinal strontium absorption after an oral or an intravenous 1,25(OH)_2_D_3_ bolus in normal subjects. J Bone Miner Res 14(10):1789–1795.10491227
Bibak A, Sturup S, Haahr V, . 1999. Concentrations of 50 major and trace elements in Danish agricultural crops measured by inductively coupled plasma mass spectrometry. 3. potato (Solanum tuberosum Folva). J Agric Food Chem 47:2678–2684.10552544
Bibak A, Sturup S, Knudsen L, . 1999. Concentrations of 63 elements in cabbage and sprouts in Denmark. Commun Soil Sci Plant Anal 30(17&18):2409–2418.
*Bierke P. 1990. Immune competence in ^90^Sr-exposed, adult thymectomized and antilymphocyteglobulin-treated CBA mice: II. Reticuloendothelial phagocyte function and in vitro mitogen responsiveness of spleen cells. Acta Oncol 29(5):615–621.2206576
*Bierke P, Nilsson A. 1990. Radiostrontium-induced oncogenesis and the role of immunosuppression: II. Influence of ^90^Sr dose, adult thymectomy and antilymphocyteglobulin treatment on the development of lympho-reticular and extraskeletal, neoplastic lesions in CBA mice. Acta Oncol 29(1):53–63.2310604
*Bishop M, Harrison GE, Raymond WHA, . 1960. Excretion and retention of radioactive strontium in normal men following a single intravenous injection. Int J Radiat Biol 2(2):125–142.
Biskis BO, Finkel MP. 1964. Histopathology of bone in dogs given radiostrontium. Fed Proc 23(2,pt1):393.
Bittel R, Magnaval R. 1977. Microlocalization of artificial radionuclides in radiological protection of the environment. Curr Top Radiat Res Q 12:33–43.
Blair HA. 1972. Radiation dose-time relations for induction of osteosarcoma in mice and dogs and their bearing on maximal permissible burden of ^90^Sr in man. Health Phys 23:759–765.4509055
Blake GM, Gray JM, Zivanovix MA, . 1987a. Strontium-89 radionuclide therapy: A dosimetric study using impulse response function analysis. Br J Radiol 60:685–692.3620827
*Blake GM, Wood JF, Wood PJ, . 1989a. ^89^Sr therapy: Strontium plasma clearance in disseminated prostatic carcinoma. Eur J Nucl Med 15:49–54.2537216
Blake GM, Zivanovic MA, Gray JM. 1987b. Strontium kinetics in metastasized prostatic carcinoma: A comparison with the predictions of impulse response function analysis. Nucl Med Commun 8:909–919.3441327
*Blake GM, Zivanovic MA, Lewington VJ. 1989b. Measurements of the strontium plasma clearance rate in patients receiving ^89^Sr radionuclide therapy. Eur J Nucl Med 15:780–783.2516486
*Blake GM, Zivanovic MA, McEwan AJ, . 1986. Sr-89 therapy: Strontium kinetics in disseminated carcinoma of the prostate. Eur J Nucl Med 12:447–454.3102236
*Blake GM, Zivanovic MA, McEwan AJ, . 1987c. ^89^Sr radionuclide therapy: Dosimetry and haematological toxicity in two patients with metastasising prostatic carcinoma. Eur J Nucl Med 13:41–46.3109917
Blake GM, Zivanovic MA, McEwan AJ, . 1987d. Strontium-89 therapy: Strontium kinetics and dosimetry in two patients treated for metastasising osteosarcoma. Br J Radiol 60:253–259.3471288
Blanco Gomis G, Fuente Alonso E, Arias Abrodo P. 1989. Ion-pair extraction and fluorimetric determination of ultratraces of strontium with cryptand 2.2.2 and eosin. Mikrochim Acta III:59–68.
Bland MR, Carr TEF, Loutit JF, . 1972. Tumours induced by ^90^Sr in normal and chimaerical CBA/H mice. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 167–172.
Blincoe C, Bohman VR, Fountain EL. 1969. Fallout concentrations in cattle grazing highly contaminated range. Health Phys 17:559–564.5344468
*Blumsohn A, Morris B, Eastell R. 1994. Stable strontium absorption as a measure of intestinal calcium absorption: Comparison with the double-radiotracer calcium absorption test. Clin Sci 87:363–368.
*BNA. 2001. Environment and Safety Library on the Web States and Territories. Bureau of National Affairs, Inc. Washington, D.C. http//www.esweb.bna.com (http://www.esweb.bna.com). May 08, 2001.
Bobovnikova TI, Virchenko YP, Konoplev AV, . 1991. Chemical forms of occurrence of long-lived radionuclides and their alteration in soils near the Chernobyl nuclear power station. Sov Soil Sci 23(5):52–57.
*Boecker BB, Chiffelle TL, Hobbs CH, . 1969. Toxicity of inhaled ^90^SrCl_2_ in beagle dogs. III. In: McClellan RO, Rupprecht FC, eds. Annual report of the fission product inhalation program. Albuquerque, NM: Lovelace Foundation for Medical Education and Research, 1–7.
Boecker BB, Hahn FF, Cuddihy RG, . 1983. Is the human nasal cavity at risk from inhaled radionuclides? In: Thompson RC, Mahaffey JA, eds. Life-span radiation effects studies in animals: What can they tell us? Proceedings of the twenty-second Hanford life science symposium held at Richland, Washington, September 27-29, 1983. Hanford Life Sciences Symposium 22^nd^. Springfield, VA: United States Department of Energy, 564–577.
*Boecker BB, Muggenburg BA, Miller SC, . 1991. Annual report on long-term dose-response studies of inhaled or injected radionuclides: October 1, 1990 through September 30, 1991. Albuquerque, NM: Lovelace Foundation for Medical Education and Research.
Boegler VF, Kriegel H. 1968. Leukämoide reaktion nach 90-strontium-inkorporation bei ratten. Blut 17(6):345–350.5723348
Bohr DF. 1974. Reactivity of vascular smooth muscle from normal and hypertensive rats: Effect of several cations. Fed Proc 33:127–132.4811888
Boivin G, Deloffre P, Perrat B, . 1996. Strontium distribution and interactions with bone mineral in monkey iliac bone after strontium salt (S 12911) administration. J Bone Miner Res 11(9):1302–1311.8864905
Bondar PF. 1984. Influence of soil climate on accumulation by plants of ^89^Sr from the soil, and prediction of harvest contamination. Sov Soil Sci 16(2):100–112.
Bondar PF. 1987. Some aspects of the evaluation and forecasting of aerial contamination of plants by radioactive substances and chemicals. Sov Soil Sci 18(5):104–114.
*Bone EA, Best LC, Jones PBB, . 1980. The effects of strontium and calcium ions on 5-hydroxytryptamine secretion and thromboxane B_2_ biosynthesis in washed human platelets. Biochem Soc Trans 8(5):530–531.7450206
*Book SA, Spangler WL, Swartz LA. 1982. Effects of lifetime ingestion of ^90^Sr in beagle dogs. Radiat Res 90:244–251.7079461
Book SA, Rosenblatt LS, Goldman M. 1983. Lifetime effects of long-term exposures to strontium-90 and radium-226 in beagle dogs. In: Thompson RC, Mahaffey JA, eds. Life-span radiation effects studies in animals: What can they tell us? Proceedings of the twenty-second Hanford life science symposium held at Richland, Washington, September 27-29, 1983. Hanford Life Sciences Symposium 22^nd^. Springfield, VA: United States Department of Energy, 646–659.
Boonen GJJC, VanSteveninck J, Elferink JGR. 1993. Strontium and barium induce exocytosis in electropermeabilized neutrophils. Biochim Biophys Acta 1175:155–160.8418894
Borisov BK. 1972. Strontium-90 metabolism in the human foetus. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59^th^ ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 469–476.
Borisova VV, Zapol’Skaya NA. 1972. Investigation of doses produced by ^90^Sr taking into account age-dependent biological parameters: An experimental investigation on rats. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59^th^ ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 39–48.
*Breen SL, Powe JE, Porter AT. 1992. Dose estimation in strontium-89 radiotherapy of metastatic prostatic carcinoma. J Nucl Med 33:1316–1323.1613572
Brent R, Meistrich M, Paul M. 1993. Ionizing and nonionizing radiations. In: Paul M, ed. Occupational and environmental reproductive hazards: A guide for clinicians. Baltimore, MD: Williams & Wilkins, 165–189.
Brent RL, Beckman DA. 1992. Principles of teratology. In: Evans MI, ed. Reproductive risks and prenatal diagnosis. Norwalk, CT: Appleton & Lange, 43–68.
*Brooks AL, McClellan RO. 1969. Chromosome aberrations and other effects produced by ^90^Sr-^90^Y in Chinese hamsters. Int J Radiat Biol 16(6):545–561.
*Brooks AL, Benjamin SA, McClellan RO. 1974. Toxicity of ^90^Sr-^90^Y in Chinese hamsters. Radiat Res 57:471–481.10874961
*Bronner F, Pansu D, Stein WD. 1986. An analysis of intestinal calcium transport across the rat intestine. Am J Physiol 250(13):G561–G569.2939728
Bruenger FW, Miller SC, Lloyd RD. 1991. A comparison of the natural survival of beagle dogs injected intravenously with low levels of ^239^Pu, ^226^Ra, ^228^Ra, ^228^Th, or ^90^Sr. Radiat Res 126:329–337.
Bruenger FW, Stover BJ, Atherton DR. 1967. The incorporation of various metal ions into in vivo- and in vitro-produced melanin. Radiat Res 32:1–12.6053863
*Brues AM, Auerbach H, Grube D, . 1967. Studies on soft-tissue dosage from strontium-90. In: Lenihan JMA, Loutit JF, Martin JH, eds. Strontium metabolism: Proceedings of the international symposium on some aspects of strontium metabolism held at Chapelcross, Glasgow and Strontian, 5-7 May, 1966. New York, NY: Academic Press, 207–212.
*Brues AM, Auerbach H, Grube DD, . 1969. Retention of radiostrontium in soft tissues. ANL-7635. 119–120.
Bull S, Stotz S, Munsterer F, . 1974. Konzentration und verteilung ^85^Sr in degenerativ, nekrotisch und entzundlich veranderten femurkopfen. Radiologe 14:383–391.4428034
*Bunde RL, Rosentreter JJ, Liszewski MJ, . 1997. Effects of calcium and magnesium on strontium distribution coefficients. Environ Geol 32(3):219–229.
*Bunde RL, Rosentreter JJ, Liszewski MJ. 1998. Rate of strontium sorption and the effects of variable aqueous concentrations of sodium and potassium on strontium distribution coefficients of a surficial sediment at the Idaho National Engineering Laboratory, Idaho. Environ Geol 34(2/3):135–142.
*Bunker DJ, Smith JT, Livens FR, . 2000. Determination of radionuclides exchangeability in freshwater systems. Sci Total Environ 263(1–3):171–183.11194151
Bunzl K, Kracke W. 1990. Simultaneous determination of ^238^Pu, ^239+240^Pu, ^241^Pu, ^241^Am, ^242^Cm, ^244^Cm, ^89^Sr, and ^90^Sr in vegetation samples, and application to Chernobyl-fallout contaminated grass. J Radioanal Nucl Chem 138(1):83–91.
*Bunzl K, Schimmack W. 1989. Associations between the fluctuations of the distribution coefficients of Cs, Zn, Sr, Co, Cd, Ce, Ru, Tc and I in the upper two horizons of a podzol forest soil. Chemosphere 18(11/12):2109–2120.
*Burguera M, Burguera JL, Rondón C, . 1999. Appraisal of different electrothermal atomic absorption spectrometric methods for the determination of strontium in biological samples. Spectrochim Acta, Part B 54:805–818.
Burt VK, Green JW. 1971. Studies of a calcium-sensitive ATPase in chick heart ventricle cells. Exp Cell Res 65:170–176.4251462
Busselen P. 1971. Potassium chloride contractures in rabbit auricles: Interaction of Sr^2+^ and Ca^2+^. Arch Int Physiol Biochim 79(4):809.4110219
Butler GC. 1968. Metabolism of radionuclides in workers. Environ Health Ser [Radiol Health] 33:33–44.
Butler GC, Veld A. 1967. Evaluation of radiation exposure from internal deposition of three bone-seeking radionuclides. Health Phys 13(8):916–918.
Cabrera WE, Schrooten I, De Broe ME, . 1999. Strontium and bone. J Bone Miner Res 14(5):661–668.10320513
*CA Department of Health Services. 2000. Chemical contaminants in drinking water. California Department of Health Services. http://www.dhs.cahwnet.gov/org_indx.htm.
Calhoun NR, Campbell S, Smith JC. 1970. Accumulation of labeled zinc, strontium, and calcium in bone injuries. J Dent Res 49(5):1083–1085.5272090
*Capar SG, Cunningham WC. 2000. Element and radionuclide concentrations in food: FDA total diet study 1991-1996. J AOAC Int 83(1):157–177.10693017
*Capo RC, Stewart BW, Chadwick OA. 1998. Strontium isotopes as tracers of ecosystem processes: theory and methods. Geoderma 82:197–225.
Carafoli E. 1967. In vivo effect of uncoupling agents on the incorporation of calcium and strontium into mitochondria and other subcellular fractions of rat liver. J Gen Physiol 50:1849–1864.6050970
Carafoli E, Tiozzo R. 1967. Time course of the distribution of in vivo administered ^89^Sr++ in rat liver subcellular fractions. Experientia 23(12):1017–1018.6077866
Carafoli E, Rossi CS, Lehninger AL. 1965. Energy-coupling in mitochondria during resting of state 4 respiration. Biochem Biophys Res Commun 19(5):609–614.5834712
*Carini F, Anguissola Scotti I, D’Alessandro PG. 1999. ^134^Cs and ^85^Sr in fruit plants following wet aerial deposition. Health Phys 77(5):520–529.10524505
*Carlton WH, Murphy CE, Jannik GT, . 1998. Radiostrontium in the Savannah River site environment. U.S. Department of Energy. DE-AC09-96SR18500. WSRC-MS-98-00454, Rev. 1. http://www.srs.gov/general/sci-tech/fulltext/ms9800454.html.
*Carlton WH, Simpkins AA, Jannik GT. 1999. Radionuclides in the Savannah River site environment. Health Phys 77(6):677–685.10568547
*Carmichael KA, Fallon MD, Dalinka M, . 1984. Osteomalacia and osteitis fibrosa in a man ingesting aluminum hydroxide antacid. Am J Med 76:1137–1143.6328994
Carmon B, Eliah Y. 1980. A relatively fast assay of Sr-90 by measuring the Cherenkov effect from the ingrowing Y-90. In: Radiation Protection: A systematic approach to safety: Proceedings of the 5th congress of the International Radiation Protection Society, Jerusalem, March 1980. New York, NY: Pergamon Press, Vol. 2, 889–1142.
Carmon B, German U. 1982. Radioassay of low ^90^Sr activities by early counting of the Cerenkov radiation induced by the ingrowing daughter nuclide ^90^Y. Health Phys 42(4):529–530.7085294
*Carr TEF, Nolan J. 1968. Inhibition of the absorption of dietary radiostrontium by aluminum phosphate gel and sodium alginate in the rat. Nature 219:500–501.5668436
Carr TEF, Harrison GE, Humphreys ER, . 1968. Reduction in the absorption and retention of dietary strontium in man by alginate. Int J Radiat Biol 14(3):225–233.
Carrier GO, Matheny JL, Ahlquist RP. 1975. Adrenergic drug-receptor interaction in the presence of strontium (Sr++) in mammalian myocardium. Arch Int Pharmacodyn 218:11–18.2115
Carvalho CAM. 1979. Fluxes of Ca^2+^, Sr^2+^ and Mg^2+^ in synaptosomes. Life Sci 25:73–82.481124
Carvalho ML, Custodio PJ, Reus U, . 2001. Elemental analysis of human amniotic fluid and placenta by total-reflection X-ray fluorescence and energy-dispersive X-ray flourescence: Child weight and maternal age dependence. Spectrochim Acta, Part B 56(11):2175–2180.
Carvalho ML, Ferreira JG, Amorim P, . 1997. Study of heavy metals and other elements in macrophyte algae using energy-dispersive x-ray fluorescence. Environ Toxicol Chem 16(4):807–812.
*Casarett GW, Tuttle LW, Baxter RC. 1962. Pathology of imbibed Sr^90^ in rats and monkeys. In: Dougherty TF, Jee WSS, Mays CW, ., eds. Some aspects of internal irradiation: Proceedings of a symposium held at the Homestead, Heber, Utah, 8-11 May 1961. New York, NY: Pergamon Press, 329–336.
Cawse PA. 1989. The origin, transport and persistence of radionuclides. J Sci Food Agric 49:123–129.
*CDC. 1994. Radionuclide releases to the atmosphere from Hanford operations, 1944-1972: Hanford environmental dose reconstruction project. Richland, WA: Centers for Disease Control and Prevention.
CELDs. 1994. Computer-assisted environmental Legislative database. University of Illinois at Urbana.
*Chan TL, Lippman M. 1980. Experimental measurements and empirical modeling of the regional deposition of inhaled particles in humans. Am Ind Hyg Assoc J 47:399–408.
Chang L-Y, Davidson W, Zhang H, . 1998. Performance characteristics for the measurement of Cs and Sr by diffusive gradients in thin films (DGT). Anal Chim Acta 368:243–253.
Chaudhuri TK, Chaudhuri TK. 1972. Altered metabolism of strontium by phosphate. In: International Conference on Strontium Metabolism, ed. Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 289–296.
Chaudhuri TK, Chaudhuri TK, Christie JH. 1972a. Two stage liver and bone scans with single dose of one isotope. Int J Appl Radiat Isot 23(4):204–205.5024333
Chaudhuri TK, Chaudhuri TK, Christie JH. 1972b. Uptake of radiostrontium in lungs and other extraosseous tissues. J Nucl Med 13(11):860.5080024
Chaudhuri TK, Chaudhuri TK, Go RT, . 1973. Uptake of ^85m^Sr by liver metastasis from carcinoma of colon. J Nucl Med 14(5):293–294.4698331
Chaudhuri TK, Chaudhuri TK, Peterson RE, . 1971. Effect of phosphate on serum strontium. Proc Soc Exp Biol Med 137(1):1–4.5581661
Chaudhuri TK, Chaudhuri TK, Suzuki Y, . 1972c. Splenic accumulation of ^85m^Sr in a patient with Hodgkin’s disease. Radiology 105:617–618.4635101
Cheburkin AK, Shotyk W. 1996. A energy-dispersive miniprobe multielement analyzer (EMMA) for direct analysis of Pb and other trace elements in peats. Fresenius J Anal Chem 354:688–691.
*ChemFinder. 2002. Strontium. Chemfinder.com: Database and internet searching. http://www.chemfinder.com/.
Cherny SN, Chausmer AB, Bellavia JV, . 1970. Interactions of thyroxine and thyrocalcitonin in the rat. Endocrinology 86(6):1337–1346.5441870
Cherruault Y, Sarin VB. 1987. A four compartment model to study the kinetics of strontium metabolism in man. Int J Biomed Comput 20:21–26.3557689
Chesser RK, Rodgers BE, Wickliffe JK, . 2001. Accumulation of ^137^cesium and ^90^strontium from abiotic and biotic sources in rodents at Chornobyl, Ukraine. Environ Toxicol Chem 20(9):1927–1935.11521818
*Chesser RK, Sugg DW, Lomakin MD, . 2000. Concentrations and dose rate estimates of ^134,137^cesium and ^90^strontium in small mammals at Chornobyl, Ukraine. Environ Toxicol Chem 19(2):305–312.
*Chines A, Pacifici R. 1990. Antacid and sucralfate-induced hypophosphatemic osteomalacia: A case report and review of the literature. Calcif Tissue Int 47:291–295.2257522
Christensen GC, Alstad J, Kvåle E, . 1975. Strontium-90 in human bone in Norway 1956-1972. Health Phys 28:677–684.1173577
Christoffersen J, Christoffersen MR, Kolthoff N, . 1997. Effects of strontium ions on growth and dissolution of hydroxyapatite and on bone mineral detection. Bone 20(1):47–54.8988347
Chowdhury MJ, Blust R. 2001. A mechanism model for the uptake of waterborne strontium in the common carp (Cyprinus carpio L.). Environ Sci Technol 35(4):669–675.11349276
Choudhury MJ, Blust R. 2002. Bioavialability of waterborne strontium to the common carp, Cyprinus carpio, in complexing environments. Aquat Toxicol 58:215–227.12007876
Churchill PC, Churchill MC, McDonald FD. 1986. Extracellular strontium substitutes for calcium in in vitro renin secretion. J Pharmacol Exp Ther 236(2):331–333.3511220
*Clarke WJ, Busch RH, Hackett PL, . 1972. Strontium-90 effects in swine: A summary to date. AEC Symp Ser 25:242–258.
*Clarke WJ, Palmer RF, Howard EB, . 1970. Strontium-90: Effects of chronic ingestion on farrowing performance of miniature swine. Science 169:598–600.5426780
Claver KT, Brey RR, Gesell TF. 1998. Developing a methodology for analysis of ^90^Sr in milk using 3M empore rad discs. Health Phys 76:S115.
*Clayton E, Wooller KK. 1985. Sample preparation and system calibration for proton-induced x-ray emission analysis of hair from occupationally exposed workers. Anal Chem 57:1075–1079.4014696
Clayton RF. 1966. Health physics problems during the demolition of highly radioactive chemical processing plants. Health Phys 12:1571–1580.5971943
Clayton RF, Smith JW. 1971. Health physics aspects of the decontamination of a high level activity cell line. Health Phys 20:153–165.5580418
Clegg DJ. 1971. Embryotoxicity of chemical contaminants of foods. Food Cosmet Toxicol 9:195–205.4934609
*Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Cochrane E, McCarthy ID. 1991. Rapid effects of parathyroid hormone(1-34) and prostaglandin E_2_ on bone blood flow and strontium clearance in the rat in vivo. J Endocrinol 131:359–365.1783882
*CO Dept of Public Health and Environ. 1999. Ground water quality classifications and standards. Colorado Department of Public Health & Environment. http://www.cdphe.state.co.us/cdphehom.asp.
Cofield RH, Bassingthwaighte JB, Kelly PJ. 1975. Strontium-85 extraction during transcapillary passage in tibial bone. J Appl Physiol 39(4):596–602.1104562
Coggle JE, Williams JP. 1990. Experimental studies of radiation carcinogenesis in the skin: A review. Int J Radiat Biol 57(4):797–808.1969908
Cohen Y, Brook G, Sobel JD, . 1974. ^85^Sr uptake in lung metastasis of osteogenic sarcoma: A case report. Oncology 30:493–498.4534182
Cohn SH, Gusmano EA. 1967. Kinetics of strontium and calcium skeletal metabolism in the rat. Proc Soc Exp Biol Med 126:79–83.
Cohn SH, Bozzo SR, Jesseph JE, . 1966. Strontium and calcium skeletal discrimination determined by compartmental analysis. J Appl Physiol 21:67–72.5903946
*Cole KL, Engstrom DR, Futyma RP, . 1990. Past atmospheric deposition of metals in Northern Indiana measured in a peat core from Cowles Bog. Environ Sci Technol 24:543–549.
Cole P, Green LC, Lash TL. 1999. Lifestyle determinants of cancer among Danish mastic asphalt workers. Regul Toxicol Pharmacol 30:1–8.10464041
*Cole VV, Harned BK, Hafkesbring R. 1941. The toxicity of strontium and calcium. J Pharmacol Exp Ther 71:1–5.
*Colomina T, Llobet JM, Domingo JL, . 1991. The effects of repeated administration of various chelating agents on the removal of strontium from the mouse. Vet Hum Toxicol 33(2):121–124.1903571
Comar CL, Wasserman RH, Lengemann FW. 1966. Effect of dietary calcium on secretion of strontium into milk. Health Phys 12:1–6.5937870
Coob J, Warwick P, Carpenter RC, . 1994. Determination of strontium-90 in water and urine samples using ion chromatography. Analyst 119:1759–1764.7978325
Cooley JL. 1973. Effects of chronic environmental radiation on a natural population of the aquatic snail Physa heterostropha. Radiat Res 54:130–140.4699790
*Cooper EL, Rahman MM. 1994. A study of cycling of ^90^Sr in a natural forest on the Canadian Shield. Sci Total Environ 157:107–113.
Corhay J-L, Bury T, Delavignette J-P, . 1995. Nonfibrous mineralogical analysis of bronchoalveolar lavage fluid from blast-furnace workers. Arch Environ Health 50(4):312–319.7677432
Corradino RA. 1972. Strontium inhibition of the vitamin D-induces calcium-binding protein and the intestinal calcium absorptive mechanism. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59^th^ ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 277–288.
*Corradino RA, Wasserman RH. 1970. Strontium inhibition of vitamin D_3_-induced calcium-binding protein (CaBP) and calcium absorption in chick intestine. Proc Soc Exp Biol Med 133(3):960–963.4314155
*Corradino RA, Ebel JG, Craig PH, . 1971a. Calcium absorption and the vitamin D_3_-dependent calcium-binding protein: I. Inhibition by dietary strontium. Calcif Tissue Res 7:81–92.4327082
*Corradino RA, Ebel JG, Craig PH, . 1971b. Calcium absorption and the vitamin D_3_-dependent calcium-binding protein: II. Recovery from dietary strontium inhibition. Calcif Tissue Res 7:93–102.4327083
Côté P, Harrison DC. 1974. Hemodynamic effects of strontium chloride in acute experimental myocardial infarction. Can J Physiol Pharmacol 52:920–929.4425993
Cotman CW, Haycock JW, White WF. 1976. Stimulus-secretion coupling processes in brain: Analysis of noradrenaline and gamma-aminobutyric acid release. J Physiol 254:475–505.765446
*Cotton FA, Wilkinson G, eds. 1980. Beryllium and the group II elements: Mg, Ca, Sr, Ba, Ra. In: Advanced inorganic chemistry: A comprehensive text. New York, NY: John Wiley & Sons.
Coulon R. 1972. Deposition of ^90^Sr and contamination of milk, proposition of a model of transfer. In: International Conference on Strontium Metabolism, ed. Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59^th^ ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 447–456.
*Couttenye MM, D’Haese PC, Verschoren WJ, . 1999. Low bone turnover in patients with renal failure. Kidney Int 56(Suppl. 73):S-70–S-76.
Cowan RL, Hartsook EW, Whelan JB. 1968. Calcium-strontium metabolism in white tailed deer as related to age and antler growth. Proc Soc Exp Biol Med 129(3):733–737.5725085
*Cragle RG, Stone WH, Bacon JA, . 1969. Effects of large doses of orally ingested strontium-90 on young cattle. Radiat Res 37:415–422.5765550
Creger CR, Colvin LB. 1971. Strontium and bone development under conditions of suboptimal vitamin D. Calcif Tissue Res 8:83–86.4332607
Creger CR, Colvin LB, Couch JR, . 1967. The effect of various dietary calcium levels on the elimination. Health Phys 13:401–404.6029685
Creutzig VH, Creutzig A, Gerdts K-G, . 1975. [Comparative investigations of osteotropic isotopes. I. Animal experiments on the uptake of ^18^F, ^85^Sr and ^99m^Tc-EHDP]. 123(2):137–143. (German)
Crist RH, Oberholser K, Schwartz D, . 1988. Interactions of metals and protons with algae. Environ Sci Technol 22(7):755–760.22195657
Cross MA, Smith JT, Saxen R, . 2002. An analysis of the environmental mobility of radiostrontium from weapons testing and Chernobyl in Finnish river catchments. J Environ Radioact 60:149–163.11936605
*Cuddihy RG, Ozog JA. 1973. Nasal absorption of CsCl, SrCl_2_, BaCl_2_ and CeCl_3_ in Syrian hamsters. Health Phys 25:219–224.4785408
Cukierman S, Krueger BK. 1990. Modulation of sodium channel gating by external divalent cations: Differential effects on opening and closing rates. Pflugers Arch(Eur J Physiol) 416:360–367.2169040
*Cummins CL, Hetrick CS, Martin Dk. 1991. Radioactive releases a t the Savannah River site 1954-1989. Environmental department protection summary. DE92-009983. WSRC-RP-91-684.
*Cunningham WC, Anderson DL, Baratta EJ. 1994. Radionuclides in domestic and imported foods in the United States, 1987-1992. J AOAC Int 77(6):1422–1427.7819751
*Cunningham WC, Stroube WB, Baratta EJ. 1989. Chemical contaminants monitoring: Radionuclides in domestic and imported foods in the United States, 1983-1986. J Assoc Off Anal Chem 72(1):15–18.2715131
Cuthbertson DP, Tilstone WJ. 1968a. The effect of environmental temperature on healing of bone lesions in the rat. I. Effect of environmental temperature on mineral metabolism. Q J Exp Physiol 53:422–427.5188432
Cuthbertson DP, Tilstone WJ. 1968b. The effect of environmental temperature on healing of bone lesions in the rat. II. The effect of bone injury on mineral metabolism at 20° C and 30° C. Q J Exp Physiol 53:428–436.5188433
Daculsi G, Bouler J-M, LeGeros RZ. 1997. Adaptive crystal formation in normal and pathological calcifications in synthetic calcium phosphate and related biomaterials. Int Rev Cytol 172:129–191.9102393
Dahl SG, Allain P, Marie PJ, . 2001. Incorporation and distribution of strontium in bone. Bone 28(4):446–453.11336927
Davies CN. 1964. Inhaled radioactive particles and gases. Nature 203:352–355.
Davies DR, Bassingthwaighte JB, Kelly PJ. 1976. Transcapillary exchange of strontium and sucrose in canine tibia. J Appl Physiol 40(1):17–22.1248978
*Davies J. 1979. Lung cancer mortality of workers in chromate pigment manufacture: An epidemiological survey. J Oil Colour Chem Assoc 62:157–163.
*Davies J. 1984. Lung cancer mortality among workers making lead chromate and zinc chromate pigments at three English factories. Br J Ind Med 41:158–169.6722042
Davis J, Cook ND, Pither RJ. 2000. Biologic mechanisms of ^89^SrCl_2_ incorporation into type I collagen during bone mineralization. J Nucl Med 41:183–188.10647622
Davis WD. 1977. Continuous mass spectrometric determination of concentration of particulate impurities in air by use of surface ionization. Environ Sci Technol 11(6):593–596.
*Dawson EB, Frey MJ, Moore TD, . 1978. Relationship of metal metabolism to vascular disease mortality rates in Texas. Am J Clin Nutr 31:1188–1197.665571
De Agostini A, Mascaro L, Pizzocaro C, . 1993. ^85^Sr contaminant as a reliable tracer of ^89^Sr for monitoring urinary radioactivity in patients treated with ^89^Sr for bone metastasis. J Nucl Biol Med 37:38–44.7687149
Dean JM. 1968. Cycling of Sr^90^ in molting crayfish. Comp Biochem Physiol 25:113–116.
DeFiore JC, Nilsson BER. 1969. Uptake of ^85^Sr in osteoarthrosis of the spine in man. Acta Radiol Diagn 8:321–328.
Degteva MO, Kozheurov VP. 1994. Age-dependent model for strontium retention in human bone. Radiat Prot Dosim 53(1–4):229–233.
Degteva MO, Kozheurov VP, Tolstykh EI. 1998. Retrospective dosimetry related to chronic environmental exposure. Radiat Prot Dosim 79(1–4):155–160.
Degteva MO, Kozheurov VP, Tolstykh EI, . 2000. The techa river dosimetry system: methods for the reconstruction of internal dose. Health Phys 79(1):24–35.10855775
Degteva MO, Kozheurov VP, Vorobiova MI. 1994. General approach to dose reconstruction in the population exposed as a result of the release of radioactive wastes into the Techa river. Sci Total Environ 142:49–61.8178136
*de la Sierra A, Hannaert P, Ollivier J-P, . 1990. Kinetic study of the Ca^2+^ pump in erythrocytes from essential hypertensive patients. J Hypertens 8:285–293.2159510
Dell’Antone P, Frigeri L, Azzone GF. 1973. The effects of electrolytes on the interaction of cationic dyes with energized mitochondrial fragments. Eur J Biochem 34:448–454.4715655
Della Rosa RJ, Peterson G, Gielow F. 1966. Strontium-90 in beagle hair. Nature 5050:777–779.
*Demayo A. 1986. Elements in sea water. In: Weast RD, ed. CRC Handbook of Chemistry and Physics. Boca Raton, FL: CRC Press, Inc. FL:F-148.
*de Oliveira EM, Suzuki MF, do Nascimento A, . 2001. Evaulation of the effect of ^90^Sr beta-radiation on human blood cells by chromosome aberration and single cell gel electrophoresis (comet assay) analysis. Mutat Res 476:109–121.11336988
*De Rooij DG, Rönnbäck C. 1989. The effect of ^90^Sr given to pregnant mice on spermatogenesis in the male offspring: A comparison with the effect on the ovaries in the female offspring. Int J Radiat Biol 56(2):151–159.2569017
*D’Haese PC, De Broe ME. 1996. Adequacy of dialysis: Trace elements in dialysis fluids. Nephrol Dial Transplant 11(Suppl. 2):92–97.8804004
*D’Haese PC, Couttenye MM, Lamberts LV, . 1999. Aluminum, iron, lead, cadmium, copper, zinc, chromium, magnesium, strontium, and calcium content in bone of end-stage renal failure patients. Clin Chem 45(9):1548–1556.10471660
*D’Haese PC, Schrooten I, Goodman WG, . 2000. Increased bone strontium levels in hemodialysis patients with osteomalacia. Kidney Int 57:1107–1114.10720963
*D’Haese PC, Van Landeghem GF, Lamberts LV, . 1996. Measurement of strontium in serum, urine, bone, and soft tissues by Zeeman atomic absorption spectrometry. Clin Chem 43(1):121–128.
*Dietz ML, Horwitz EP, Nelson DM, . 1991. An improved method for determining ^89^Sr and ^90^Sr in urine. Health Phys 61(6):871–877.1955331
DiPietro ES, Phillips DL, Paschal DC, . 1989. Determination of trace elements in human hair. Biol Trace Elem Res 22:83–100.2484231
*Doberenz AR, Weber CW, Reid BL. 1969. Effect of high dietary strontium levels on bone and egg shell calcium and strontium. Calcif Tissue Res 4:180–184.5363273
*DOE. 1984. Strontium-90 in the US diet, 1982. New York, NY: Environmental Measurements Laboratory, U.S. Department of Energy. DE85002012.
*DOE. 1991. Radioactive releases at the Savannah River site 1954-1989 (U). Washington, DC: U.S. Department of Energy. NTIS/DE92009983. 82–97; 219–254.
*DOE. 1992. Chemical contaminants on DOE lands and selection of contaminant mixtures for subsurface science research. Washington, DC: U.S. Department of Energy. DE92-014826.
*DOE. 1993. Occupational radiation protection. U.S. Department of Energy. Code of Federal Regulations. 10 CFR 835.
*DOE. 1995. Radionuclide concentrations in terrestrial vegetation and soil on and around the Hanford site, 1983 through 1993. Richland, WA: U.S. Department of Energy. DE-AC06-76RLO1830.
*DOE. 1996a. Closing the circle on the splitting of the atom: The environmental legacy of nuclear weapons production in the United States and what the department of energy is doing about it. Washington, DC: Office of Environmental Management, U.S. Department of Energy. DOE/EM-0266.
*DOE. 1996b. Selected radionuclides important to low-level radioactive waste management: National low-level waste management program. U.S. Department of Energy. DOE/LLW-238.
*DOE. 1996c. High-level waste inventory, characteristics, generation, and facility assessment for treatment, storage, and disposal alternatives considered in the U.S. Department of Energy environmental management programmatic environmental impact statement. Argonne, IL: U.S. Department of Energy. ANL/EAD/TM-17.
*DOE. 1996d. Worldwide deposition of strontium-90 through 1990. New York, NY: Environmental Measurements Laboratory, U.S. Department of Energy. EML-579.
*DOE. 1996e. Strontium-90 adsorption-desorption properties and sediment characterization at the 100N-area. Richland, WA: U.S. Department of Energy. DE-AC06-76RLO 1830.
*DOE. 1998a. Subpart N-accidents and emergencies. US Department of Energy. Code of Federal Regulations. 10 CFR 835 Sub N.
*DOE. 1998b. Occupational radiation protection; final rule. U.S. Department of Energy. Federal Register. 63 FR 59662. November 4, 1998.
DOE. 2000a. Location of laboratories and national laboratories. Laboratory site map. U.S. Department of Energy. http://www.doe.gov/people/labsmap.htm.
*DOE. 2000b. General provisions. Department of Energy. 10 CFR 835, App. A. http://frwebgate5access.gpo.gov/.
*DOE. 2001a. Individual monitoring. U.S. Department of Energy. Code of Federal Regulations. 10 CFR 835.402. http://frwebgate.access.gpo.gov/. May 11, 2001.
*DOE. 2001b. Limits for members of the public entering a controlled area. U.S. Department of Energy. Code of Federal Regulations. 10 CFR 835.208. http://frwebgate.access.gpo.gov/. May 11, 2001.
*DOE. 2001c. Limits for the embryo/fetus. U.S. Department of Energy. Code of Federal Regulations. 10 CFR 835.206. http://frwebgate.access.gpo.gov/. May 11, 2001.
*DOE. 2001d. Occupational dose limits for general employees. U.S. Department of Energy. Code of Federal Regulations. 10 CFR 835.202. http://frwebgate.access.gpo.gov/. May 11, 2001.
*DOE. 2001e. Occupational dose limits for minors. U.S. Department of Energy. Code of Federal Regulations. 10 CFR 835.207. http://frwebgate.access.gpo.gov/. May 11, 2001.
Donaldson SKB, Kerrick WGL. 1975. Characterization of the effects of Mg^2+^ on Ca^2+^- and Sr^2+^-activated tension generation of skinned skeletal muscle fibers. J Gen Physiol 66:427–444.1081122
*DOT. 1995. Carriage by public highway. Class 7 (radioactive) material. U.S. Department of Transportation. Code of Federal Regulations. 49 CFR 177.842.
*DOT. 1996. Radiation protection program. U.S. Department of Transportation, Washington, D.C. 49 CFR 172.803.Subpart I.
*DOT. 1997. General requirements for shipments and packaging. Class 7 (radioactive) materials. U.S. Department of Transportation. Code of Federal Regulations. 49 CFR 173, Subpart I.
*DOT. 1998. Hazardous materials; withdrawal of radiation protection program requirement; final rule. U.S. Department of Transportation. Federal Register. 63 FR 48566. September 10, 1998.
*DOT. 2001a. List of hazardous substances and reportable quantities. U.S. Department of Transportation. 49 CFR 172.101 Appendix A. http://63.141.231.97/cgi-bin/. May 10, 2001.
*DOT. 2001b. Activity values for radionuclides. U.S. Department of Transportation. 49 CFR 173.435 Appendix A. http://63.141.231.97/cgi-bin/om. May 10, 2001.
*DOT. 2001c. Carriage by public highway. U.S. Department of Transportation. Code of Federal Regulations. 49 CFR 177.842. http://63.141.97/cgi-bin/. May 09, 2001.
*DOT. 2001d. General requirements for shipments and packaging. U.S. Department of Transportation. Code of Federal Regulations. 49 CFR 173, Subpart I. http://63.141.97/cgi-bin/. May 10, 2001.
*DOT. 2001e. Radiation level limitations. U.S. Department of Transportation. Code of Federal Regulations. 49 CFR 173.441. http://63.141.97/cgi-bin/. May 08, 2001.
*Dougherty JH, Taylor GN, Mays C. 1972. Strontium-90 toxicity in adult beagles after acute exposure. AEC Symp Ser 25:259–276.
*Downey HF, Stewart WE, Cragie RG. 1964. Depletion of strontium from calves by hemodialysis. Trans Am Soc Artif Intern Organs 10:350–352.4963344
*Downie ED, Macpherson S, Ramsden EN, . 1959. The effect of daily feeding of ^90^Sr to rabbits. Br J Cancer 13:408–423.13817911
Duce RA, Hoffman GL, Zoller WH. 1975. Atmospheric trace metals at remote northern and southern hemisphere sites: Pollution or natural? Science 187:59–61.17844209
*Duncan EL, Brown MA, Sunsheimer J, . 1999. Suggestive linkage of the parathyroid receptor type 1 to osteoporosis. J Bone Miner Res 14(12):1993–1999.10620056
*Dungworth DL, Goldman M, Switzer JW, . 1969. Development of a myeloproliferative disorder in beagles continuously exposed to ^90^Sr. Blood 34(5):610–632.5260601
Durbin PW, Lynch J, Murray S. 1970. Average milk and mineral intakes (calcium, phosphorus, sodium and potassium) of infants in the United States from 1954 to 1968; Implication for estimating annual intakes of radionuclides. Health Phys 19:187–222.5537939
*Dzubay TG, Stevens RK. 1975. Ambient air analysis with dichotomous sampler and x-ray fluorescence spectrometer. Environ Sci Technol 9(7):663–668.
Eagling EM, Lovell HG, Pickles VR. 1972. Interaction of prostaglandin E_1_ and calcium in the guinea-pig myometrium. Br J Pharmacol 44:510–516.5040661
Eakins JD, Gomm PJ. 1966. A new method for the determination of radiostrontium in urine. Health Phys 12:1557–1563.4961666
*Eary LE, Rai D, Mattigod SV, . 1990. Geochemical factors controlling the mobilization of inorganic constituents from fossil fuel combustion residues: II. Review of the minor elements. J Environ Qual 19:202–214.
Ebel JG, Comar CL. 1968. Effect of dietary magnesium on strontium-calcium discrimination and incorporation into bone of rats. J Nutr 96:403–408.5725895
Edwards C, Lorkovic H, Weber A. 1966. The effect of the replacement of calcium by strontium on excitation-concentration coupling in frog skeletal muscle. J Physiol 186:295–306.4226414
Eisenberg E. 1966. Effects of androgens, estrogens and corticoids on strontium kinetics in man. J Clin Endocrinol 26:566–572.
Eisenberg E. 1970. Effect of intravenous phosphate on serum strontium and calcium. N Engl J Med 282(16):889–892.5434935
*Eisenbud M, ed. 1987. Environmental radioactivity: From natural, industrial, and military sources. New York, NY: Academic Press, Inc.
*Eisenbud M, Gesell T, eds. 1997. Environmental radioactivity from natural, industrial, and military sources. 4^th^ ed. San Diego, CA: Academic Press, 426–428.
El Alfy S, Abdel-Rassoul AA. 1993. Trace metal pollutants in El Manzala lakes by inductively coupled plasma spectroscopy. Water Res 27(7):1253–1256.
El-Hodhdod MA, Abdelkarim AH, Samaan MN. 2000. Does serum strontium carry a relationship to rickets in Egyptian infants? J Pediatr Gastroenterol Nutr 31:S90–S91.
*Elias Z, Poirot O, Baruthio F, . 1991. Role of solubilized chromium in the induction of morphological transformation of Syrian hamster embryo (SHE) cells by particulate chromium (VI) compounds. Carcinogenesis 12(10):1811–1816.1934262
*Elias Z, Poirot O, Pezerat H, . 1989. Cytotoxic and neoplastic transforming effects of industrial hexavalent chromium pigments in Syrian hamster embryo cells. Carcinogenesis 10(11):2043–2052.2680145
*Ellenhorn MJ, Schonwald S, Ordog G, . 1997. Ellenhorn’s medical toxicology: Diagnosis and treatment of human poisoning. 2^nd^ ed. Baltimore, MD: Williams & Wilkins, 1682–1723.
El Solh N, Rousselet F, Girard ML. 1972. A study on protein-strontium bonds. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 255–272.
El-Yazigi A, Kanaan I, Martin CR, . 1990. Cerebrospinal fluid content of manganese, platinum, and strontium in patients with cerebral tumors, leukemia, and other noncerebral neoplasms. Oncology 47(5):385–388.2216293
*Emmanuel FXS, Vaughan ATM, Catty D. 1981. Mice treated with strontium 90: An animal model deficient in NK cells. Br J Cancer 44:160–165.7272185
*EMMI. 2000a. Metals in water by nebulization and ICP-AES - Method 200.15. Environmental Monitoring Methods Index. U.S. Environmental Protection Agency.
*EMMI. 2000b. Strontium-89 and strontium-90 in water - Method 008. Environmental Monitoring Methods Index. U.S. Environmental Protection Agency.
*EMMI. 2000c. Strontium in high level samples - Method RP501. Environmental Monitoring Methods Index. U.S. Environmental Protection Agency.
*EMMI. 2000d. Strontium-90 in soil, water and filter- Method RP520. Environmental Monitoring Methods Index. U.S. Environmental Protection Agency.
Engfeldt B, Reinholt FP, Svensson O, . 1986. The parathyroid gland in metal rickets. Calcif Tissue Int 39(Suppl.):A104.
*EPA. 1976a. Maximum contaminant levels for beta particle and photon-radioactivity from man-made radionuclides in community water systems. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.16.
*EPA. 1976b. Monitoring frequency for radioactivity in community water systems. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.26.
EPA. 1980. Prescribed procedures for measurement of radioactivity in drinking water. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory. EPA-600/4-80-032.
*EPA. 1981. Data base for influent heavy metals in publicly owned treatment works. Cincinnati, OH: Municipal Environmental Research Laboratory. U.S. Environmental Protection Agency. EPA-600/S2-81-220.
*EPA. 1987. Radiation protection guidance to federal agencies for occupational exposure. U.S. Environmental Protection Agency. 52 FR 2822.
*EPA. 1988. Recommendations for and documentation of biological values for use in risk assessment. U.S. Environmental Protection Agency. Office of Research and Development, Cincinnati, OH. PB88-179874.
*EPA. 1989a. Compliance procedures methods for determining compliance with subpart I [40 CFR 61]. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 61, Appendix E.
*EPA. 1989b. Methods for estimating radionuclide emissions. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 61, Appendix D.
*EPA. 1989c. National emission standards for emissions of radionuclides other than radon from Department of Energy facilities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 61, Subpart H.
*EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA 600/8-90/066A.
*EPA. 1993a. Environmental radiation protection standards for management and disposal of spent nuclear fuel, high-level and transuranic radioactive wastes. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 191.
*EPA. 1993b. Standards for management of uranium byproduct material pursuant to section 84 of the Atomic Energy act of 1954, as amended. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 192, Subpart D.
*EPA. 1995a. Determination of background concentrations of inorganics in soils and sediments at hazardous waste sites. Washington, DC: Office of Solid Waste and Emergency Response. U.S. Environmental Protection Agency. EPA 540/S-96/500.
*EPA. 1995b. Standards for cleanup of land and buildings contaminated with residual radioactive materials from inactive uranium processing sites. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 192, Subpart B.
*EPA. 1995c. Implementation. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 192, Subpart C.
*EPA 1995d. Standards for the control of residual radioactive materials from inactive uranium processing sites. Standards. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 192, Subpart A.
*EPA 1995e. Environmental radiation data. Office of Radiation and Indoor Air. Washington, DC. U.S. Environmental Protection Agency. Report 84, Table 13. http://www.epa.gov/narel/erd84w.htm#Table13. December 21, 2003.
*EPA. 1996a. Drinking water regulations and health advisories. Office of Water. US Environmental Protection Agency. EPA 822-B-96-002.
*EPA. 1996b. National emission standards for radionuclide emissions from federal facilities other than nuclear regulatory commission licensees and not covered by subpart H. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 61, Subpart I.
*EPA. 1996c. Test methods. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 61, Appendix B.
*EPA. 1997a. National primary drinking water regulations: Analytical methods for radionuclides; final rule and proposed rule. U.S. Environmental Protection Agency. Federal Register. 62 FR 10168. March 5, 1997.
*EPA. 1997b. Health effects assessment summary tables. FY-1997 update. Office of Research and Development, Office of Emergency and Remedial Response. Washington, DC: U.S. Environmental Protection Agency. EPA/540/R-97/036. NTIS PB 97-921199.
*EPA. 1997c. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA/630/R-96/012.
*EPA. 1998a. Land disposal restrictions phase IV: final rule promulgating treatment standards for metal wastes and mineral processing wastes; mineral processing secondary materials and bevill exclusion issues; treatment standards for hazardous soils, and exclusion of recycled wood preserving wastewaters. U.S. Environmental Protection Agency. Federal Register. 63 FR 28566. May 26, 1998.
*EPA. 1998b. Class V injection wells underground injection control regulations, revisions; proposed rule. U.S. Environmental Protection Agency. Federal Register. 63 FR 40586. July 29, 1998.
*EPA. 1998c. Subpart C-Environmental standards for ground-water protection. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 191 SubC.
*EPA. 1999a. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
*EPA. 1999b. Maximum contaminant levels for beta particle and photon radioactivity from man-made radionuclides in community water systems. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.16.
*EPA. 1999c. Monitoring frequency for radioactivity in community water systems. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.26.
*EPA. 1999d. Cancer risk coefficients for environmental exposure to radionuclides. U.S. Environmental Protection Agency. Code of Federal Regulations. 402-R-99-001.
*EPA. 2000a. Environmental radiation data, Report 84, October - December 1995: U.S. Environmental Protection Agency, Office of Radiation and Indoor Air. http://www.epa.gov/narel/erd84w.htm.
*EPA. 2000b. Environmental radiation data, Report 91, July - September 1997. U.S. Environmental Protection Agency, Office of Radiation and Indoor Air. http://www.epa.gov/narel/erd91.pdf.
EPA. 2000c. National drinking water contaminant occurrence query user’s guide. National contaminant occurrence database. U.S. Environmental Protection Agency. http://www.epa.gov/ncodwork/html/ncod/ncod_userguide.html.
*EPA. 2000d. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. Office of Water. EPA-822-B-00-001. http://www.epa.gov/ost/drinking/standards/dwstandards.pdf.
*EPA. 2000e. Federal Guidance Report No. 13. Cancer risk coefficients for environmental exposure to radionuclides, CD Supplement [CD-ROM]. EPA 402/C-99-001.
*EPA. 2001a. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://ecfrback.access.gpo.gov/.
*EPA. 2001b. NPDES permit application testing requirements. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 122, App. D. http://ecfrback.access.gpo.gov/.
*EPA. 2001c. Release limits for containment requirements. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 191, App. A. http://ecfrback.access.gpo.gov/.
*EPA. 2001d. Compliance procedures methods for determining compliance with subpart I. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 61, App. E. http://ecfrback.access.gpo.gov/.
*EPA. 2001e. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://ecfrback.access.gpo.gov/otcgi/cfr/.
*EPA. 2001f. Maximum containment levels for beta particle and photon radioactivity from man-made radionuclides in community water systems. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.16. http://ecfrback.access.gpo.gov/.
*EPA. 2001g. Analytical methods for radioactivity. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.25. http://ecfrback.access.gpo.gov/.
*EPA. 2001h. Monitoring frequency for radioactivity in community water systems. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.26. http://ecfrback.access.gpo.gov/.
*EPA. 2001i. Environmental radiation protection standards for management and disposal of spent nuclear fuel, high-level and transuranic radioactive wastes. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 191, Subpart A, B, and C. http://www4.law.cornell.edu/cfr/40p191.htm. May 11, 2001.
*EPA. 2001j. Hazardous waste injection restrictions. Waste specific prohibitions–newly listed and identified wastes. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 148.18. http://www.access.gpo.gov.html. May 11, 2001.
*EPA. 2001k. Health and environmental protection standards for uranium and thourium mill tailings. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 192, Subpart A, B, C, and D. http://www4.law.cornell.edu/cfr/40p192.htm. May 11, 2001.
*EPA. 2001l. Land disposal restrictions. LDR effective dates of injected prohibited hazardous waste. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268, Appendix VIII. http://www.access.gpo.gov/nara/cfr/cfrhtml_00/Title_40/40tab_00.html. May 11, 2001.
*EPA. 2001m. Methods for estimating radionuclide emissions. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 61, Appendix D. http://www.epa.gov/epahome/cfr40.html. May 08, 2001.
*EPA. 2001n. Underground injection control regulations for Class V injection wells. U.S. Environmental Protection Agency. Federal Register. 63 FR 40586. http://frwebgate5.access.gpo.gov/. May 11, 2001.
*EPA. 2002a. Strontium and Srontium-90. Environmental Protection Agency. Federal Register. http://www.epa.gov.ncod/
*EPA. 2002b. National drinking water contaminant occurrence query user’s guide. National contaminant occurrence database. U.S. Environmental Protection Agency. http://www.epa.gov/ncodwork/html/ncod/ncod_userguide.html.
Ercegovich CD, Vallejo RP, Gettig RR, . 1981. Development of a radioimmunoassay for parathion. J Agric Food Chem 29:559–563.7251987
Erickson BE. 2002. A simple way to remediate strontium? Environ Sci Technol 36(1):20A–21A.
Escanero JF, Cordova A. 1991. Effects of glucagon on serum calcium, magnesium and strontium levels in rats. Miner Electrolyte Metab 17:190–193.1779942
Escanero J, Carre M, Miravet L. 1976. [Effects of different metabolites of vitamin D3 and of calcium concentration on the intestinal absorption of strontium]. C R Seances Soc Biol Fil 170(1):47–53. (French)134783
*Etoh H, Taguchi YH, Tabachnick J. 1977. Cytokinetics of regeneration in β-irradiated guinea-pig epidermis. Radiat Res 71:109–118.877235
*Evans GJ, Tan PV. 1998. The fate of elements in residential composters. Arch Environ Contam Toxicol 34:323–329.9543500
*Fatayerji D, Mawer EB, Eastell R. 2000. The role of insulin-like growth factor I in age-related changes in calcium. J Clin Endocrinol Metab 85(12):4657–4662.11134124
*FDA. 1997. Ionizing radiation for the treatment of food. U.S. Department of Health and Human Services. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 179.26.
*FDA. 1998. Accidental radioactive contamination of human food and animal feeds: Recommendations for state and local agencies. U.S. Department of Health and Human Services. U.S. Food and Drug Administration. Center for Devices and Radiological Health. Rockville, MD 20850. August 13, 1998.
*FDA. 1999. Sources of radiation used for inspection of food, for inspection of packaged food, and for controlling food processing. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 179.21.
*FDA. 2000. Irradiation in the production, processing and handling of food. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 179.21. http://www.access.gpo.gov/nara/cfr/waisidx_00/21cfr179_00.html.
*Federman JH, Sachter JJ. 1997. Status asthmaticus in a paramedic following exposure to a roadside flare: A case report. J Emerg Med 15(1):87–89.9017492
*FEDRIP. 2002. Dialog Information Systems, Inc., Palo Alto, CA: Federal Research in Progress.
Felt TP, Harrison JD, Leggett RW. 1998. A model for the transfer of calcium and strontium to the fetus. Radiat Prot Dosim 79(1–4):311–315.
Feng X, Melander AP, Klaue B. 2000. Contribution of municipal waste incineration to trace metal deposition on the vicinity. Water Air Soil Pollut 119:295–316.
*Ferenbaugh JK, Fresque PR, Ebinger MH, . 2002. Radionuclides in soil and water near a low-level disposal site and potential ecological and human health impacts. Environ Monit Assess 74:243–254.11944797
Ferrendelli JA, Rubin EH, Kinscherf DA. 1976. Influence of divalent cations on regulation of cyclic GMP and cyclic AMP levels in brain tissue. J Neurochem 26:741–748.184244
Finkel MP. 1947. The transmission of radio-strontium and plutonium from mother to offspring in laboratory animals. Physiol Zool 20:405–421.18921410
*Finkel MP, Biskis BO. 1969. Pathologic consequences of radiostrontium administered to fetal and infant dogs. AEC Symp Ser 17:543–566.
*Finkel MP, Bergstrand PJ, Biskis BO. 1960. The consequences of the continuous ingestion of Sr^90^ by mice. Radiology 74:458–467.13822905
*Finkel MP, Biskis BO, Greco I, . 1972. Strontium-90 toxicity in dogs: Status of Argonne study on influence of age and dosage pattern. AEC Symp Ser 52:285–312.
Finston RA, Woodard HQ, Laughlin JS. 1966. Effects of external irradiation on mineral metabolism in the bones of adult dogs. Clin Orthop Relat Res 46:183–201.5915108
Firschein HE. 1970. Collagen and mineral accretion rates in bone during vitamin A deficiency. Am J Physiol 219(5):1183–1187.5473095
Firschein HE, Alcock NW. 1969. Rate of removal of collagen and mineral from bone and cartilage. Metabolism 18(2):115–119.5766386
Firusian N. 1974. Kinetik des radiostrontium. Nucl Med Commun 13(2):127–138.
*Fission Product Inhalation Project. 1967a. Toxicity of inhaled ^90^Sr in beagle dogs. In: Fission product inhalation program annual report 1966-1967. Albuquerque, NM: Lovelace Foundation for Medical Education and Research.
*Fission Product Inhalation Project. 1967b. Toxicity of inhaled ^90^Sr in rats. In: Fission product inhalation program annual report 1966-1967. Albuquerque, NM: Lovelace Foundation for Medical Education and Research.
*FL DEP. 2000. Water resource management. Florida Department of Environmental Protection. http://www.dep.state.fl.us/water/wf/dw/dw_contm_radio.htm.
Fleschner CR, Kraus-Friedmann N. 1986. The effect of Mg^2+^ on hepatic microsomal Ca^2+ 2+^ transport. Eur J Biochem 154:313–320.2935394
*Fomon SJ. 1966. Body composition of the infant: Part I: The male “reference infant”. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
*Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
*Forbes GB, Reina JC. 1972. Effect of age on gastrointestinal absorption (Fe, Sr, Pb) in the rat. J Nutr 102:647–652.5022199
Forbes GB, Zalenski D. 1971. Uptake and elution of radiosodium in bone powder: Comparison with ^47^Ca and ^85^Sr. Calcif Tissue Res 8:172–176.5145212
Forbes M, Mitchell HH. 1957. Accumulation of dietary boron and strontium in young and adult albino rats. AMA Arch Ind Health 16:489–492.13478188
*Foreman JC. 1977. Spontaneous histamine secretion from mast cells in the presence of strontium. J Physiol 271:215–232.72147
*Foreman JC, Mongar JL. 1972a. Activation of anaphylactic histamine release by calcium and strontium ions. Br J Pharmacol 44(2):326.
*Foreman JC, Mongar JL. 1972b. The role of the alkaline earth ions in anaphylactic histamine secretion. J Physiol 224:753–769.4116105
*Foreman JC, Hallett MB, Monger JL. 1977. Movement of strontium ions into mast cells and its relationship to the secretory response. J Physiol 271:233–251.72148
Forlani F, Arnoldi A, Pagani S. 1992. Development of an enzyme-linked immunosorbent assay for triazole fungicides. J Agric Food Chem 40:328–331.
Forsberg S, Rosen K, Brechignac. 2001. Chemical availability of ^137^Cs and ^90^Sr in undisturbed lysimeter soild maintained under controlled and close-to-real conditions. J Environ Radioact 54:253–265.11378919
*Foster PR, Elharrar V, Zipes DP. 1977. Accelerated ventricular escapes induced in the intact dog by barium, strontium and calcium. J Pharmacol Exp Ther 200(2):373–383.839442
Foulkes EC. 1985. Interactions between metals in rat jejunum: implications on the nature of cadmium uptake. Toxicology 37:117–125.4060163
*Fresquez PR, Foxx TS, Naranjo L. 1996a. Uptake of strontium by Chamisa (Chrysothamnus nauseosus) shrub plants growing over a former liquid waste disposal site at Los Alamos National Laboratory: Proceedings of the HSRC/WERC joint conference on the environment. Los Alamos, NM: Los Alamos National Laboratory.
*Fresquez PR, Mullen MA, Ferenbaugh JK, . 1996b. Radionuclides and radioactivity in soils within and around Los Alamos National Laboratory, 1974 through 1994: Concentrations, trends, and dose comparisons. Los Alamos, NM: Los Alamos National Laboratory.
*Friday GP. 1996. Radiological bioconcentration factors for aquatic terrestrial and wetland ecosystems at the savannah river site. Aiken, SC: U.S. Department of Energy. DE-AC09-89SR18035. WSRC-TR-96-0231.
Friedland JA, Brdlik OB, Methfessel AH, . 1969. Reduction of radiostrontium uptake in the rat. Radiat Res 38:340–348.5771801
Friedman M, Hirschfeld Z. 1982. EDTA enhancement of strontium uptake by intact human enamel. J Oral Rehabil 9:327–333.6809921
*Friedman PA, Gesek FA. 1995. Cellular calcium transport in renal epithelia: Measurement, mechanisms and regulation. Physiol Rev 75:429–471.7624390
Fugimori T, Jencks WP. 1992. The kinetics for the phosphoryl transfer steps of the sarcoplasmic reticulum calcium ATPase are the same with strontium and with calcium bound to the transport sites. J Biol Chem 267(26):18466–18474.1388154
Fujiki H, Mori M, Tanooka H. 1982. Delayed induction of ornithine decarboxylase in mouse skin after irradiation with beta-rays. Cancer Lett 15:15–17.7059960
Fujimori T, Jencks WP. 1992. Binding of two Sr^2+^ ions changes the chemical specificities reticulum calcium ATPase through a stepwise mechanism. J Biol Chem 267(26):18475–18487.1388155
Fujita M, Iwamoto J, Kondo M, . 1969a. Correlation between ingestion, accumulation and excretion of fallout ^90^Sr in man on a long-term scale. Health Phys 17:41–50.5798577
Fujita M, Iwanoto J, Kondo M. 1969b. Variation of strontium-calcium observed ratio (urine/diet) in man. Health Phys 16:441–447.5787367
*Fukushi Y, Ozawa T, Wakui M, . 1995a. Sr^2+^ can pass through Ca^2+^ entry pathway activated by Ca^2+^ depletion, but can be hardly taken up by the Ca^2+^ stores in the rat salivary acinar cells. Tohoku J Exp Med 176:83–97.7482526
*Fukushi Y, Suga S, Kamimura N, . 1995b. Stimulated Ca^2+^ entry activates Cl^−^ currents after releasing Ca^2+^ from the intracellular store in submandibular gland cells of the rat. Jpn J Physiol 45:1071–1085.8676575
*Furr AK, Parkinson TF, Hinrichs RA, . 1977. National survey of elements and radioactivity in fly ashes absorption of elements by cabbage grown in fly ash-soil mixtures. Environ Sci Technol 11(13):1194–1201.
*Gachályi A, Naményi J, Szegedi I, . 1988. Mobilization of ^85^Sr by flavone derivatives (Morin and Iproflavone) in normal and pregnant rats. Radiobiol Radiother 29(4):513–517.
Garder K, Skulberg O. 1964. Sorption phenomena of radionuclides to clay particles in river water. Int J Air Wat Poll 8:229–241.
Garner RJ, Morley F. 1967. Agricultural implications of a release of fission products from a criticality incident. Health Phys 13:465–475.6071839
Garnier A, Lanzola E, Karhausen L. 1972. Variability of ^90^Sr bone burdens. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 489–504.
*Gastberger M, Steinhäusler F, Gerzabek MH, . 2000. ^90^Sr and ^137^Cs in environmental samples from dolon near the semipalatinsk nuclear test site. Health Phys 79(3):257–265.10949250
Gastberger M, Steinhäusler F, Gerzabek MH, . 2001. Fallout strontium and caesium transfer from vegetation to cow milk at two lowland and two alpine pastures. J Environ Radioact 54:267–273.11378920
Gatti LV, Mozeto AA, Artaxo P. 1999. Trace elements in lake sediments measured by the PIXE technique. Nucl Instrum Meth Phys Res B 150:298–305.
Gedalia I. 1975. Strontium uptake by the developing femur bone and deciduous dentition. J Dent Res 54:B125–B130.1055736
*Gehr P. 1994. Anatomy and morphology of the respiratory tract. In: Human respiratory tract model for radiological protection. ICRP Publication 66. International Commission on Radiological Protection. Oxford: Pergamon Press, 121–166.
*Gennari L, Becherini L, Masi L, . 1997. Vitamin D receptor genotypes and intestinal calcium absorption in postmenopausal women. Calcif Tissue Int 61:460–463.9383272
*George GA, Mehdi EI, Toma NA. 1979. Internal deposition of radiostrontium and its removal. In: Biological Implications of Radionuclides Released from Nuclear Industries. Proceedings of an International Symposium on Biological Implications. Vol. 2:53–64.
Gerritse RG, Vriesema R, Dalengerg JW, . 1982. Effect of sewage sludge on trace element mobility in soils. J Environ Qual 11(3):359–364.
*Ghosh S, Talukder G, Sharma A. 1990. Clastogenic activity of strontium chloride on bone marrow cells in vivo. Biol Trace Elem Res 25:51–56.1696112
Giang N, Shiraishi K, Sinh N, . 2001. Estimation of dietary ^232^Th, ^238^U, cesium, and strontium intakes in Vietnamese people from different geographical regions. Health Phys 80(6):605–611.11388732
Gibbons RA, Sanson BF, Sellwood R. 1972. The passage of calcium and strontium across the gut of the anaesthetized goat. J Physiol 222:397–406.5033470
*Gidlund M, Bierke P, Örn A, . 1990. Impact of ^90^Sr on mouse natural killer cells and their regulation by alpha interferon and interleukin 2. Scand J Immunol 31:575–582.2140623
*Gillett NA, Muggenburg BA, Boecker BB, . 1987a. Single inhalation exposure to ^90^SrCl_2_ in the beagle dog: Hematological effects. Radiat Res 110:267–288.3575656
*Gillett NA, Muggenburg BA, Boecker BB, . 1987b. Single inhalation exposure to ^90^SrCl_2_ in the beagle dog: Late biological effects. J Natl Cancer Inst 79:359–376.3110478
Gillett NA, Pool R, Taylor G, . 1986. Strontium-90 induced bone tumors in beagle dogs: Effects of route exposure and dose rate. Health Phys 56(Suppl. 1):S26.
*Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
*Glowiak B, Pacyna J. 1978. Radionuclide movement in an ecological chain. Ecotoxicol Environ Saf 1:447–455.720274
Goblet C, Mounier Y. 1987. Activation of skinned muscle fiber by calcium and strontium ions. Can J Physiol Pharmacol 65:642–647.2440539
Goldberg J, Sacks R. 1982. Direct determination of metallic elements in solid, powder samples with electrically vaporized thin film atomic emission spectrometry. Anal Chem 54:2179–2186.
Goldman M, Longhurst WM, Della Rosa RJ, . 1965. The comparative metabolism of strontium, calcium and cesium in deer and sheep. Health Phys 11:1415–1422.5884546
Goldman M, Pool R, Momeni MH, . 1972. Quantitation of ^90^Sr toxicity in dogs. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 17–30.
Goldman M, Rosenblatt LS, Book SA. 1983. Lifetime radiation effects research in animals: An overview of the status and philosophy of studies at University of California-Davis Laboratory for energy-related health research. In: Thompson RC, Mahaffey JA, eds. Life-span radiation effects studies in animals: What can they tell us? Proceedings of the twenty-second Hanford life science symposium held at Richland, Washington, September 27-29, 1983. Hanford Life Sciences Symposium 22^nd^. Springfield, VA: United States Department of Energy, 53–65.
*Goncalves PP, Meireles SM, Neves P, . 1999. Ionic sensitivity of the Ca^2+^/H^+^ antiport in synaptic vesicles of sheep brain cortex. Mol Brain Res 67:283–291.10216226
Gong JK, Burgeww E, Bacalao P. 1966. Accretion and exchange of strontium-85 in trabecular and cortical bones. Radiat Res 28:753–765.5920290
*Gong YF, Huang ZJ, Qiang MY . 1991. Suppression of radioactive strontium absorption by sodium alginate in animals and human subjects. Biomed Environ Sci 4:273–282.1764217
*Gonzalez MD, Vassalle M. 1990. Strontium induces oscillatory potentials in sheep cardiac Purkinje fibers. Int J Cardiol 27:87–99.2335412
*Gonzalez-Reimers E, Rodriguez-Moreno F, Martinez-Riera A, . 1999. Relative and combined effects of ethanol and protein deficiency on strontium and barium bone content and fecal and urinary excretion. Biol Trace Elem Res 68:41–49.10208655
Gould JM, Sternglass EJ. 1994. Nuclear fallout, low birth weight, and immune deficiency. Int J Health Serv 24(2):311–335.8034395
*Gould JM, Sternglass EJ, Sherman JD, . 2000. Strontium-90 decidous teeth as a factor in early childhood cancer. Int J Health Serv. 30(3):515–539.11109179
*Grahek Z, Zecervic N, Lulic S. 1999. Possibility of rapid determination of low-level ^90^Sr activity by combination of extraction chromatography separation and Cherenkov counting. Anal Chim Acta 399:237–247.
Graustein WC, Armstrong RL. 1983. The use of strontium-87/strontium-86 ratios to measure atmospheric transport into forested watersheds. Science 219:289–292.17798277
*Green MO, Brannen AL. 1995. Hyperbaric oxygen therapy for Beta-radiation - induced scleral necrosis. Ophthalmology 102(7):1038–1041.9121750
Green N. 2001. The effect of storage and processing on radionuclide content of fruit. J Environ Radioact 52:281–290.11202700
Greenawalt JW, Carafoli E. 1966. Electron microscope studies on the active accumulation of Sr^++^ by rat-liver mitochondria. J Cell Biol 29(1):37–61.5920196
Greenberg EJ, Chu FCH, Dwyer AJ, . 1972. Effects of radiation therapy on bone lesions as measured by ^47^Ca and ^85^Sr local kinetics. J Nucl Med 13(10):747–751.4560347
*Gregoire G, Loirand G, Pacaud P. 1993. Ca^2+^ and Sr^2+^ entry induced Ca^2+^ release from the intracellular Ca^2+^ store in smooth muscle cells of rat portal vein. J Physiol 474:483–500.
Gridgeman NT. 1971. Methods of assay of the relative toxicity of certain bone-seeking radionuclides. Radiat Res 48:291–302.5286614
*Griffith WC, Boecker BB, Hahn FF, . 1992. Effect of dose protraction on the incidence of lung carcinomas in beagle dogs with internally deposited (beta)-emitting radionuclides. Albuquerque, NM: Lovelace Biomedical and Environmental Research Institute. Inhalation Toxicology Research Institute. DE92004258.
*Gross M, Kumar R. 1990. Physiology and biochemistry of vitamin D-dependent calcium binding proteins. Am J Physiol 259:F195–209.2201202
Grubb BR, Bentley PJ. 1984. The biology of strontium: Interactions with the mammalian crystalline lens. Exp Eye Res 39:107–112.6434337
Gruden N. 1984. The effect of lactose and iron on strontium absorption. Experientia 40(9):941–942.6468619
Gruden N, Stantic M, Buben M. 1974. Influence of lead on calcium and strontium transfer through the duodenal wall in rats. Environ Res 8:203–206.4455506
Grundt TJ, Usowicz MM, Henderson G. 1996. Ca^2+^ entry following store depletion in SH-SY5Y neuroblastoma cells. 36:93–100.
*Grynpas MD, Hamilton E, Cheung R, . 1996. Strontium increases vertebral bone volume in rats at a low dose that does not induce detectable mineralization defect. Bone 18(3):253–259.8703581
Grzegorzewski K, Komschlies KL, Mori M, . 1994. Administration of recombinant human interleukin-7 to mice induces the exportation of myeloid progenitor cells from the bone marrow to peripheral sites. Blood 83(2):377–385.8286738
Guimaraes-Motta H, Sande-Lemos MP, Mrid LD. 1984. Energy interconversion in sarcoplasmic reticulum vesicles in the presence of Ca^2+^ and Sr^2+^ gradients. J Biol Chem 259(14):8699–8705.6235215
*Gulson BL, Mizon KJ, Korsch MJ, . 2001. Dietary intakes of selected elements from longitudinal 6-day duplicate diets for pregnant and nonpregnant subjuects and elemental concentrations of breast milk and infant formula. Environ Res A87:160–174.
Guogang J, Testa C, Desideri D, . 1998. Sequential separation and determination of plutonium, americium-241 and strontium-90 in soils and sediments. J Radioanal Nucl Chem 230(1–2):21–27.
Gusmano EA, Concannon JN, Bozzo SR, . 1968. Evaluation of the parameters of strontium metabolism in the rat as a function of age. Radiat Res 33:540–553.5640793
Gutteridge DH, Robinson CJ, Joplin GF. 1968. Delayed strontium absorption in post-menopausal osteoporosis and osteomalacia. Clin Sci 34:351–363.5653693
*Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Hackett PL, Thompson RC. 1966. Strontium and calcium excretion in the rat. In: Thompson RC, Swezea EG, eds. Pacific Northwest Laboratory annual report for 1965 in the biological sciences. Richland, WA: Pacific Northwest Laboratory, 28–31.
*Haddad LM, Shannon MW, Winchester JF, eds. 1998. Clinical management of poisoning and drug overdose. 3^rd^ ed. Philadelphia, PA: W.B. Saunders Company, 413–425.
*Hahn FF, Boecker BB, Cuddihy RG, . 1983a. Influence of radiation dose patterns on lung tumor incidence in dogs that inhaled beta emitters: A preliminary report. Radiat Res 96:505–517.6657919
*Hahn FF, Gillett NA, Boecker BB, . 1991. Comparison of bone lesions induced by inhaled ^90^SrCl_2_ or ^238^PuO_2_. Albuquerque, NM: Lovelace Biomedical and Environmental Research Institute. NTIS/DE91017509.
Hahn FF, Muggenburg BA, Boecker BB, . 1983b. Insights into radionuclide-induced lung cancer in people from life-span studies in beagle dogs. In: Thompson RC, Mahaffey JA, eds. Life-span radiation effects studies in animals: What can they tell us? Proceedings of the twenty-second Hanford life science symposium held at Richland, Washington, September 27-29, 1983. Hanford Life Sciences Symposium 22^nd^. Springfield, VA: United States Department of Energy, 521–534.
Hahn GS. 1999. Strontium is a potent and selective inhibitor of sensory irritation. Dermatol Surg 25:689–694.10491058
Hakem N, Al Mahamid I, Apps J, . 1997. Sorption of cesium and strontium on Savanah river soils impregnated with colloidal silica. Conf Proc-Int Containment Technol Conf.
Hall JC, Deschamps RJA, Krieg KK. 1989. Immunoassays for the detection of 2,4-D and picloram in river water and urine. J Agric Food Chem 37:981–984.
*Hall SC, Wells, J. 1988. Micronuclei in human lymphocytes as a biological dosemeter: preliminary data following beta irradiation in vitro. J Radiol Prot. 8(2):97–102.
*Haller O, Wigzell H. 1977. Suppression of natural killer cell activity with radioactive strontium: Effector cells are marrow dependent. J Immunol 118(4):1503–1506.300411
*Hällgren R, Svensson K, Johansson E, . 1984. Elevated granulocyte strontium in inflammatory arthritides is related to the inflammatory activity. J Lab Clin Med 104(6):893–900.6502000
*Hamilton TF, Millies-Lacrox JC, Hong GH. 1996. ^137^Cs (Sr) and Pu isotopes in the Pacific Ocean: Sources & trends. Livermore, CA: Lawrence Livermore National Laboratory.
*Hamlet R, Heryet JC, Hopewell JW, . 1986. III.3 Late changes in pig skin after irradiation from beta-emitting sources of different energy. Br J Radiol 19(Suppl.):51–54.
Hammermeister AM, Naeth MA, Chanasyk DS. 1998. Implications of fly ash application to soil for plant growth and feed quality. Environ Technol 19:143–152.
Hannaert-Merah Z, Combettes L, Coquil J-F, . 1995. Characterization of the co-agonist effects of strontium and calcium on myo-inositol trisphosphate-dependent ion fluxes in cerebellar microsomes. Cell Calcium 18:390–399.8581967
Hanson WC. 1968. Fallout radionuclides in northern Alaskan ecosystems. Arch Environ Health 17:639–648.5693144
Hanson WC, Thomas JM. 1982. Prediction of ^90^Sr body burdens and radiation dose in Anaktuvuk pass Alaskan Eskimos due to fallout. Health Phys 43(3):323–333.6129202
Hardy EP, Rivera J. 1968. Transfer of fallout strontium-90 to cows’ milk. J Dairy Sci 51(8):1210–1214.5669930
Harrison GE, Carr TEF, Sutton A, . 1966a. Plasma concentration and excretion of calcium-47, strontium-85, barium-133, and radium-223 following successive intravenous doses to a healthy man. Nature 209:526–527.
*Harrison GE, Carr TEF, Sutton A. 1967a. Distribution of radioactive calcium, strontium, barium and radium following intravenous injection into a healthy man. Int J Radiat Biol 13(3):235–247.
*Harrison GE, Howells GR, Pollard J, . 1966b. Effect of dietary phosphorus supplementation on the uptake of radioactive strontium in rats. Br J Nutr 21:561–569.
Harrison GE, Howells GR, Pollard J. 1967b. Comparative uptake and elution of ^45^Ca, ^85^Sr, ^133^Ba, Ra in bone powder. Calcif Tissue Res 1:105–113.6060148
*Harrison GE, Lumsden E, Raymond WHA, . 1959. On the metabolism of skeletal fixation of strontium I. II. Arch Biochem Biophys 80:97–113.
*Harrison GE, Raymond WHA, Tretheway HC. 1955. The metabolism of strontium in man. Clin Sci 14:681–695.13270452
*Harrison GE, Sutton A, Shepherd H, . 1965. Strontium balance in breast-fed babies. Brit J Nutr 19:111–117.14275943
*Harrison J, McNeill KG, Janiga A. 1966c. The effect of sodium alginate on the absorption of strontium and calcium in human subjects. Can Med Assoc J 95:532–534.5955715
Harrison JE, McNeill KG, Elaguppillai V. 1972. Strontium and calcium kinetics at the bone level. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 379–388.
*Hart H, Spencer H. 1967. Rate of initial entry of Ca^47^ and Sr^85^ from the intestine into the vascular space. Proc Soc Exp Biol Med 126:365–371.6079904
*Hartsook EW, Hershberger TV. 1973. Strontium-calcium discrimination during placental transfer and fetal uptake in rats: Effect of gestation duration. Proc Soc Exp Biol Med 143(2):343–349.4709000
Hartsook EW, Cowan RL, Chandler PT, . 1969. Effect of dietary protein source and corn oil and cellulose levels in strontium-calcium discrimination in growing rats. J Nutr 97:95–103.5763451
*Hayes KF, Traina SJ. 1998. Metal ion speciation and its significance in ecosystem health. In: Soil chemistry and ecosystem health. Soil Science Society of America, Special Publication no. 52. Madison, WI: Soil Science Society of America, 46–83.
*HazDat. 2003. Strontium. ATSDR’s hazardous substance release and health effects database. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/hazdat.html.
Hazzard DG. 1969. Percent cesium-134 and strontium-85 in milk, urine, and feces of goats on normal and verxite-containing diets. J Dairy Sci 52(7):990–994.4313326
Heine K, Wiechen A. 1980. Studies of the transfer factors of Sr^90^ and Cs^137^ in the food-chain soil-plant-milk. In: Radiation protection: A systemic approach to safety: Proceedings of the 5th congress of the International Radiation Protection Society, Jerusalem, March 1980. New York, NY: Pergamon Press, Vol. 2, 1099–1102.
*Helal AA, Aly HF, Imam DM, . 1998a. Effect of some metal ions on the complexation of strontium with humic acid. J Radioanal Nucl Chem 227(1–2):49–53.
*Helal AA, Imam DM, Khalifa SM, . 1998b. Effect of some environmental ligands and fertilizers on humic acid complexation with strontium. J Radioanal Nucl Chem 232(1–2):159–161.
Hems G, Mole RH. 1966. The relative toxicities of radium 226, plutonium 239 and strontium 90 for bone tumour induction. Br J Radiol 39:719–726.5926612
Henkart P, Henkart M, Millard P, . 1985. The role of cytoplasmic granules in NK cell cytotoxicity. In: Herberman RB, Callewaert DM, eds. Mechanisms of cytotoxicity by NK cells. New York, NY: Academic Press, 305–322.
Henquin J-C. 1980. Specificity of divalent cation requirement for insulin release: Effects of strontium. Pflugers Arch(Eur J Physiol) 383:123–129.6770336
Henricson B, Nilsson A. 1965. Effect of radiostrontium on oocytes and follicles of adult mice. Acta Radiol Ther Phys Biol 3:296–304.14334677
Henshaw DL. 1996. Chernobyl 10 years on: Thyroid cancer may be the only measurable health effect. Br Med J 312(7038):1052–1053.8616397
*Herring LC, Keefer DH. 1971a. II. Comparison of stable and radioactive strontium deposition in urinary calculi and human diet. Arch Environ Health 22:251–258.5540111
Herring LC, Keefer DH. 1971b. A radiologic study of inorganic urinary calculi: I. Comparison of stable and radioactive strontium deposition in urinary calculi and human bone. Arch Environ Health 22:239–250.5540110
Hert J, Mertl F, Babicky A. 1971. Reaction of bone to mechanical stimuli incorporation of ^45^Ca and ^35^S into rabbit tibia subjected to intermittent stress. Physiol Bohemoslov 20(6):575–581.4261971
Hesp R, Ramsbottom B. 1965. Radiobiology: Effect of sodium alginate in inhibiting uptake of radiostrontium by the human body. Nature 5017:1341–1342.
*Hibbins SG. 1997. Strontium and strontium compounds. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. New York, NY: John Wiley & Sons, Vol. 22, 947–955.
*HI Dept Health. 1999. Environmental health: Safe drinking water rules. Hawaii Department of Health. http://www.hawaii.gov/heath/rules/emd/dwrule.html.
Hilpert K, Waidmann E. 1986. Multi-element determination in environmental samples by mass spectrometric isotope dilution analysis using thermal ionization: Part I: Pine needles. Fresenius Z Anal Chem 325:141–145.
*Hirose K, Takatani S, Aoyama M. 1993. Wet deposition of radionuclides derives from the Chernobyl accident. J Atmos Chem 17:16–71.
*Hobbs CH, Snipes MB, Barnes JE, . 1972. Toxicity of inhaled ^90^Sr fused clay in dogs: Early effects. Radiat Res 51(2):503–504.
Hodgkinson A, Nordin BEC, Hambleton J, . 1967. Radiostrontium absorption in man: Suppression by calcium and by sodium alginate. Can Med Assoc J 97:1139–1143.6057133
*Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
*Hole DJ, Gillis CR, Sumner D. 1993. Childhood cancer in birth cohorts with known levels of strontium-90. Health Rep 5(1):39–43.8334237
Holguín JA. 1986. Cooperative effects of Ca^2+^ and Sr^2+^ on sarcoplasmic reticulum adenosine triphosphatase. Arch Biochem Biophys 251(1):9–16.3024577
Holmuhamedov EL, Teplova VV, Chukhlova EA, . 1995. Strontium excitability of the inner mitochondrial membrane: Regenerative strontium-induced strontium release. Biochem Mol Biol Int 36(1):39–49.7663421
Holopainen T, Rekonen A. 1966. Uptake of radioactive strontium (^85^Sr) in joints damaged by rheumatoid arthritis measured by external counting of radiation. Acta Rheumatol Scand 12:102–111.5917963
Holynska B, Olko M, Ostachowicz B, . 1998. Performance of total reflection and grazing emission x-ray fluorescence spectrometry for the determination of trace metals in drinking water in relation to other analytical techniques. Fresenius J Anal Chem 362:294–298.
Hong G-H, Lee S-H, Kim S-H, . 1999. Sedimentary fluxes of 90Sr, 137Cs, 239, 240Pu, and 210Pb in the East Sea (Sea of Japan). Sci Total Environ 237/238:225–240.10568278
*Hopewell JW, Coggle JE, Wells J, . 1986. III.2. The acute effects of different energy beta-emitters on pig and mouse skin. Br J Radiol 19(Suppl.):47–51.
*Hopewell JW, Hamlet R, Peel D. 1985. The response of pig skin to single doses of irradiation from strontium-90 sources of differing surface area. Br J Radiol 58:778–780.3842286
*Hopkins BJ. 1967. The retention of strontium-90 transferred through milk (and placenta) in rat offspring. Health Phys 13:973–976.6069913
*Hopkins BJ, Casarett GW. 1972. Some pathogenic aspects of gross pathological changes in ^90^Sr-treated bone of newborn rats. Int J Radiat Biol 21(5):405–416.
*Hopkins BJ, Casarett GW, Baxter RC, . 1966. A roentgenographic study of terminal pathological changes in skeletons of strontium-90 treated rats. Radiat Res 29:39–49.5921600
*Hopkins BJ, Casarett GW, Tuttle LW, . 1967. Strontium-90 and intrauterine development in the rat. J Embryol Exp Morphol 17(2):583–591.6049667
*Horwitz EP, Dietz ML, Fisher DE. 1991. Separation and preconcentration of strontium from biological, environmental, and nuclear waste samples by extraction chromatography using a crown ether. Anal Chem 63:522–525.1829590
*Hoshino H, Tanooka H. 1975. Interval effect of β-irradiation and subsequent 4-nitroquinoline 1-oxide painting on skin tumor induction in mice. Cancer Res 35:3663–3666.811353
*Howard EB. 1970. Experimental induction of porcine leukemia. In: Dutcher RM, ed. Comparative leukemia research 1969. New York, NY: Karger, 430–439.
*Howard EB, Clarke WJ. 1970. Induction of hematopoietic neoplasms in miniature swine by chronic feeding of strontium-90. J Natl Cancer Inst 44(1):21–38.11515032
*HSDB. 2000. Strontium. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. http://toxnet.nlm.nih.gov/cgi-bin/sis/search/f?./temp/~BAArea4Ke:1:FULL.
*HSDB. 2002. Strontium. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. http://toxnet.nlm.nih.gov/cgi-bin/sis/htmlgen?HSDB.
Hueper WC. 1961. Environmental carcinogenesis and cancers. Cancer Res 21:842–857.13716558
Hult M, Fessler A. 1998. Sr/Ca mass ratio determination in bones using fast neutron activation analysis. Appl Radiat Isot 49(9–11):1319–1323.9699293
Hulth AG, Nilsson BE. 1969. Effect of actinomycin-D on bone mineral metabolism in rats. Calcif Tissue Res 3:194–197.5769905
Humphreys ER, Howells GR. 1972. Promotion of excretion of injected ^85^Sr, ^133^Ba and ^244^Ra from the rat by injected derivatives of sodium alginate. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59^th^ ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 315–324.
Humphreys ER, Van Puymbroeck S, Vanderborght O. 1972. Inhibition of intestinal absorption of simultaneously administered ^47^Ca, ^85^Sr, ^133^Ba and ^226^Ra by different sodium alginates. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59^th^ ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 309–314.
*IARC. 1990. Chromium and chromium compounds. IARC Monographs on the Evaluation of Carcinogenic Risks to Humans. International Agency fro Research on Cancer. Lyon, France. Vol.49, pp.49–256.
*IARC. 2001. Ionizing radiation, part 2: Some internally deposited radionuclides. In: IARC monographs on the evaluation of carcinogen risks to humans. International Agency for Research on Cancer. Lyon, France. Vol 78.
*IARC. 2002a. Chromium and chromium compounds: Chromium[IV](group 1), metallic chromium and chromium[III] compounds (group3). International Agency for Research on Cancer. http://www.cie.iarc.fr/htdocs/monographs/vol149/chromium.html. October 23, 2002.
*IARC. 2002b. Some internally deposited radionuclides (generally Group 1). International Agency for Research on Cancer. http://www.cie.iarc.fr/htdocs/monographs/col178-radionuclides.html. October 23, 2002.
*ICRP. 1990. 1990 Recommendations of the International Commission on Radiological Protection, ICRP Publication 60. Oxford: Pergamon Press.
*ICRP. 1993. Age-dependent doses to members of the public from intake of radionuclides: Part 2 Ingestion dose coefficients. International Commission on Radiological Protection. Publication No. 67. Pergamon Press, Oxford. 95–120.
*ICRP. 1994a. Human respiratory tract model for radiological protection. International Commission on Radiological Protection. Publication No. 66. Pergamon Press, Oxford.
*ICRP. 1994b. Dose coefficients for intakes of radionuclides by workers. International Commission on Radiological Protection. Annals of the ICRP. Vol. 24(4). ICRP publication 68.
*ICRP. 1996. Age-dependent doses to members of the public from intake of radionuclides. Part 5. International Commission on Radiological Protection. Pergamon Press, Oxford. Publication No. 72.
*ICRP. 1995. Age-dependent doses to members of the public from intake of radionuclides: Part 4 inhalation dose coefficients. Publication No. 71. Pergamon Press, Oxford.
*ID Department of Health Welfare. 2000. Ground water quality rules. Idaho Department of Health and Welfare. http://www2.state.id.us/adm/adminrules/rules/idapa16/16index.htm.
*Iiyinskikh NN, Iiyinskikh IN, Shakirov NN, . 1999. Chromosome aberrations in the radiation-exposed residents around Mayak nuclear facility in the Chelyabinsk region, Russia. Environ Toxicol 14(4):414–423.
*IL Environmental Protection Agency. 1999. Water quality standards. Illinois Environmental Protection Agency. http:www.epa.state.il.us/regulations.html (http://www.epa.state.il.us/regulations.html).
*Ilyin LA, Ivannikov AT, Parfenov YD, . 1975. Strontium absorption through damaged and undamaged human skin. Health Phys 29:75–80.807536
*IN General Assembly. 2000. Title 327 water pollution control board. Indiana Administrative Code. Indiana General Assembly. http://www.state.in.us/legislative/iac/title327.html.
*Inoue Y, Saijoh K, Katsuyama H, . 1988. Effects of heavy metal cations on second messenger systems in the brains of mice. In: Sumino K, ed. Environmental and occupational chemical hazards, No. 8. Asia-Pacific Symposium on Environmental and Occupational Toxicology, Singapore, October 4-7, 1987. Kobe, Japan: Kobe University School of Medicine.
IRIS. 2000. Strontium. Integrated Risk Information System. U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/0550.htm.
*IRIS. 2002. Strontium. Integrated Risk Information System. U.S. Environmental Protection Agency. http://www.epa.gov/ngispgm3/iris/subst/0550.htm.
*Iskander FY. 1986. Cigarette ash as a possible source of environmental contamination. Environ Pollut Ser B 11:291–301.
*Ito T, Nagao K, Kawamura Y, . 1976. Studies on the leukemogenic and immunologic effects of radiostrontium (^90^Sr) and x rays in mice. In: Radiation and the lymphatic system: Proceedings of the fourteenth annual Hanford biology symposium at Richland, Washington, September 30-October 2, 1974. Springfield, VA: Energy Research and Development Administration, 209–217.
Ivanov SN, Shagalova ED. 1972. Strontium in the environment. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 437–446.
*Iyengar GV, Kollmer WE, Bowen HJM. 1978. The elemental composition of human tissues and body fluids: A compilation of values for adults. Weinheim, NY: Verlag Chemie.
Jacobs RL, Shapiro FD, Ray RD. 1972. In vitro study of mobilization and uptake of bone mineral. Clin Orthop Relat Res 82:214–220.5011029
Jacobsen N, Jonsen J. 1975. Strontium, lead and nickel incorporated into mouse calvaria in vitro. Pathol Eur 10:115–121.241957
*Jacobsen N, Alfheim I, Jonsen J. 1978. Nickel and strontium distribution in some mouse tissues passage through placenta and mammary glands. Res Commun Chem Pathol Pharmacol 20(3):571–584.674833
*James AC. 1978. Lung deposition of sub-micron aerosols calculated as a function of age and breathing rate. In: National Radiological Protection Board Annual Research and Development Report. Harwell, United Kingdom: National Radiological Protection Board, 71–75.
*James AC, Stahlhofen W, Rudolf G, . 1994. Deposition of inhaled particles. In: ICRP Publication 66. Oxford: Pergamon Press, 231–299.
*Järplid B. 1973. Radiostrontium induced early changes in the haematopoietic tissues. Acta Radiol Ther Phys Biol 12:145–154.4542223
Järplid B. 1974. Combined effect of roentgen irradiation and radiostrontium on the haematopoietic tissue and the development of lymphoma in mice. Acta Radiol Ther Phys Biol 13:217–231.4546759
Jasinski WK, Watras J, Gwiazdowska BA, . 1971. Retention of strontium^85^ in rats contaminated in utero and fed with the contaminated milk. Radiobiol Radiother 12(3):325–328.
Jeffree RA, Sarkich SJ, Twining JR. 2001. Element concentrations in the flesh and osteoderms of esturine crocodiles (Crocodylus porosus) from the alligator rivers region, Northern Australia: biotic and geographic effects. Arch Environ Contam Toxicol 40:236–245.11243326
Jethi RK, Mackey MG, Meredith PD, . 1972. Studies of the mechanism of biological calcification. 3. The interaction of strontium with a calcifiable matrix from beef tendon. Calcif Tissue Res 9(4):310–324.5068851
*Jia G, Triuzi C, Marzano N, . 1999. Plutonium, 241Am, ^90^Sr, and ^137^Cs concentrations in some Antarctic matrices. Biol Trace Elem Res 71–72:349–357.
Jiang M-S, Fletcher JE, Smith LA. 1989. Factors influencing the hemolysis of human erythrocytes by cardiotoxins from Naja naja kaiuthia and Naja naja atra venoms and a phopholipase A_2_ with cardiotoxin-like activities from Bungarus fasciatus venom. Toxicol 27(2):247–257.
*Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
Johnson AR, Armstrong AR, Singer L. 1970. The exchangeability of calcium and strontium of bone in vitro. Calcif Tissue Res 6:103–112.5501383
*Johnson AR, Armstrong WD, Singer L. 1968. The incorporation and removal of large amounts of strontium by physiologic mechanisms in mineralized tissues. Calcif Tissue Res 2(3):242–252.5748355
Johnson JR, Dunford DW, Kramer GH. 1983. Summary of a strontium-89 contamination case. Radiat Prot Dosim 5(4):247–249.
Jones P, Foulkes M, Paull B. 1994. Determination of barium and strontium in calcium-containing matrices using high-performance chelation ion chromatography. J Chromatogr A 673:173–179.
Jones P, Williams T, Ebdon L. 1990. Development of a novel multi-element detection system for trace metal determination based on chemiluminescence after separation by ion chromatography. Anal Chim Acta 237:291–298.
*Jones RK, Boecker BB, Hobbs CH, . 1972. Hematologic effects of inhaled ^90^Y, ^91^Y, ^144^Ce or ^90^Sr fused clay in beagle dogs. Radiat Res 51(2):470–471.
*Jones RK, Boecker BB, Pickrell JA, . 1976. Influence of radiation-dose pattern from inhaled beta-gamma-emitting radionuclides on canine peripheral lymphocytes. In: Radiation and the lymphatic system: Proceedings of the fourteenth annual Hanford biology symposium at Richland, Washington, September 30-October 2, 1974. Springfield, VA: Energy Research and Development Administration, 83–99.
Jones S, Robbins J, Brown DA. 1992. Neurotransmitter modulation of calcium channels is dependent on the charge carrier used in the recording of currents. Neurosci Lett 145:153–156.1361221
Jonsen J, Storeng R, Jacobsen N. 1980. Heavy metal toxicity to mouse embryos cultivated in vitro. J Dent Res 59(Special Issue B):948.
Jowsey J, Balasubramaniam P. 1972. Effect of phosphate supplements on soft-tissue calcification and bone turnover. Clin Sci 42:289–299.5013873
Kahn B, Jones IR, Porter CR, . 1965. Transfer of radiostrontium from cows’ feed to milk. J Dairy Sci 48:1023–1030.5837875
*Kahn B, Straub CP, Robbins PJ, . 1969a. Part 1: Long-term study in the home; Diet and results. Pediatrics 43(4):652–667.5818580
Kahn B, Straub CP, Robbins PJ, . 1969b. Part 3: Intake, excretion, and retention of stable strontium. Pediatrics 43(4):687–705.5778455
Kahn B, Straub CP, Robbins PJ, . 1969c. Part 4: Intake, excretion, and retention of strontium-90. Pediatrics 43(4):706–731.5818581
Kahn B, Straub CP, Robbins PJ, . 1969d. Strontium, calcium, and phosphorous retention. Pediatrics 43(4):733–756.5781671
Kahn DS, Nakhani JS, Skoryna SC. 1963. Studies of the late effects of internal irradiation by radioactive strontium in the rat. Laval Med 34(1):169–183.13958282
Kal’chenko VA, Budashkina EB, Khvostova VV. 1973. Content of Sr^90^, Ca, and strontium units in the grain of wheat hybrids obtained by crossing Triticum aestivum x Triticum dicoccum. Sov Genet 7(8):1018–1021.4783216
*Kan MK. 1995. Palliation of bone pain in patients with metastatic cancer using strontium-89 (Metastron). Cancer Nurs 18(4):286–291.7545083
*Kanematsu N, Hara M, Kada T. 1980. Rec assay and mutagenicity studies on metal compounds. Mutat Res 77:109–116.6769036
*Kano K, Horikawa M, Utsunomiya T, . 1993. Lung cancer mortality among a cohort of male chromate pigment workers in Japan. Int J Epidemiol 22(1):16–22.8449638
Karaki H, Urakawa N. 1972. Increase in ^85^Sr uptake by elevated concentration of K in guinea pig Taenia coli. Jpn J Pharmacol 22:437–439.4539404
Karaki H, Nakagawa H, Urakawa N. 1986. Strontium uptake during the different modes of contraction in the smooth muscle of rabbit aorta, rat aorta and guinea-pig taenia coli. Arch Int Pharmacodyn 282:93–107.3767525
*Karbach U, Rummel W. 1987. Strontium transport in the rat colon. Naunyn-Schmiedebergs Arch Pharmacol 335:91–96.3574496
Kargacin B, Kostial K. 1985. Reduction of ^85^Sr, ^137^Cs, ^131^I and ^141^Ce retention in rats by simultaneous oral administration of calcium alginate, ferrihexacyanoferrate(II), KI and Zn-DTPA. Health Phys 49(5):859–864.4066345
Kargacin B, Landeka M. 1990. Effect of glucocorticoids on metal retention in rats. Bull Environ Contam Toxicol 45:655–661.2265265
*Kashparov VA, Lundin SM, Khomutinin YV, . 2001. Soil contamination with ^90^Sr in the near zone of the Chernobyl accident. J Environ Radioact 56:285–298.11468820
Kerrick WGL, Zot HG, Hoar PE, . 1985. Evidence that the Sr^2+^ activation properties of cardiac troponin C are altered when substituted into skinned muscle fibers. J Biol Chem 260(29):15687–15693.3934162
*Keslev D, Van Puymbroeck S, Van Der Borght O. 1972. Effect of aluminum phosphate gel on whole-body retention of simultaneously administered ^226^Ra, ^85^Sr and ^47^Ca in mice. Experientia 28(5):524–525.5040798
Khairallah PA, Vadaparampil GJ, Page IH. 1965. Effect of ions on angiotensin interaction with smooth muscle. Arch Int Pharmacodyn 158(1):155–164.5892560
Kidman B, Tutt ML, Vaughan JM. 1951. The retention of radioactive strontium and yttrium (Sr^89^, Sr^90^ and Y^90^) in pregnant and lactating rabbits and their off-spring. J Pathol Bacterial 63:253–268.
Kinoshita A, Braga FJ, Graeff CF, . 2001. ESR dosimetry of ^89^Sr and ^153^Sm in bone. Appl Radiol 54(2):269–274.
Kirkeby OJ, Berg-Larsen T. 1991. Regional blood flow and strontium-85 incorporation rate in the rat hindlimb skeleton. J Orthop Res 9:862–868.1919849
Knight WM, Bohman VR, Lesperance AL, . 1967. Strontium retention in the bovine. J Anim Sci 26(4):839–844.6076877
Knivvsland Y, Skretting A, Bruland OS. 2001. Radionuclide therapy with bone-seeking compounds: Monte Carlo calculations of dose-volume histograms for bone marrow in trabecular bone. Phys Med Biol 46(4):1149–1161.11324957
Knizhnikov VA, Petukhova EV, Varkhudarov RM. 1972. ^90^Sr intake in food by the population of the Soviet Union 1963-1971. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59^th^ ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 477–482.
Knobel LL, Cecil LD, Wenger SJ, . 1992. Comparison of the effects of filtration and preservation methods on analysis for strontium-90 in ground water. Environ Monit Assess 20:67–80.24234031
Ko WH, Pediani JD, Bovell DL, . 1995. Sr^2+^ can become incorporated into an agonist-sensitive, cytoplasmic Ca^2^+ store in a cell line derived from the equine sweat gland epithelium. Experientia 51:804–808.7649240
Kobayashi E, Sugihira N, Suzuki KT. 1990. Renal handling and discrimination of calcium and strontium in the chronically cadmium-poisoned population. Trace Elem Med 7:114–117.
Kobayashi E, Sugihira N, Suzuki KT. 1991. Biological discrimination between calcium and strontium in kidneys and bone of young and adult rats. Biol Trace Elem Res 28:187–194.1713042
*Kodaira K, Tsumura A, Kobayashi H. 1973. Uptake of radioactive strontium and cesium in rice plants: (1) Accumulation of Sr and Cs in rice grains through roots. J Radiat Res 14:31–39.4732652
Kohama K, Saida K, Hirata M, . 1986. Superprecipitation is a model for in vitro contraction superior to ATPase activity. Jpn J Pharmacol 42:253–260.2948043
Kohara K, Ogura A, Akagawa K, . 2001. Increase in nunber of functional release sites by cyclic AMP-dependent protein kinase in cultured neurons isolated from hippocampal dentate gyrus. Neurosci Res 41:79–88.11535297
Kolar J, Babicky A, Bibr B, . 1968. Metabolic studies with bone-seekers in diseased joints. Calcif Tissue Res 2(Suppl.):34,34A,34B.
Kolhardt M, Haastert HP, Krause H. 1973. Evidence of non-specificity of the Ca channel in mammalian myocardial fibre membranes: Substitutions of Ca by Sr, Ba or Mg as charge carriers. Pflugers Arch(Eur J Physiol) 342:125–136.4795633
Kollenkirchen U. 1995. Measurement of bone resorption by strontium excretion in prelabelled rats. Bone 17(4):455S–460S.8579952
Kollmer WE, Kriegel H. 1965. Das biologische verhalten von radiostrontium bei ratten im verlauf der laktation. Int J Radiat Biol 9(4):369–381.
Komarneni S, Scheetz BE. 1981. Hydrothermal interactions of basalts with Cs and Sr of spent fuel elements. 43:1967–1975.
*Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
*Kossenko MM. 1996. Cancer mortality among Techa River residents and their offspring. Health Phys 71(1):77–82.8655334
*Kossenko MM, Degteva MO, Vyushkova OV, . 1997. Issues in the comparison of risk estimates for the population in the Techa River region and atomic bomb survivors. Radiat Res 148:54–63.9216619
*Kossenko MM, Hoffman DA, Thomas TL. 2000. Stochastic effects of environmental radiation exposure in populations living near the Mayak Industrial Association: Preliminary report on study of cancer morbidity. Health Phys 79(1):55–62.10855778
*Kossenko MM, Izhevsky PV, Degteva MO, . 1994. Pregnancy outcome and early heath status of children born to the Techa River population. Sci Total Environ 142:91–100.8178140
*Kossenko MM, Preston DL, Krestinina LY, . 2002. Studies on the extended Techna cohort: Cancer risk estimation. Radiat Environ Biophys 41(1):45–48.12014408
Kossmna SE, Weiss MA. 2000. Acute myelogenous leukemia after exposure to strontium-89 for the treatment of adenocarcinoma of the prostate. Cancer 88(3):620–624.10649256
Kostial K, Durakovic A, Simonovic I, . 1969a. The effect of some dietary additives on calcium and strontium absorption in suckling and lactating rats. Int J Radiat Biol 15(6):563–570.
*Kostial K, Gruden N, Durakovic A. 1969b. Intestinal absorption of calcium-47 and strontium-85 in lactating rats. Calcif Tissue Res 4(1):13–19.5344406
Kostial K, Gruden N, Durakovic A, . 1972. Reduction in strontium absorption in pregnant, lactating and suckling rats. Acta Radiol 11(3):277–287.
*Kostial K, Kargacin B, Landeka M. 1984. Influence of dietary ingredients on the body retention of strontium, cadmium and mercury in suckling rats. Toxicol Lett 23(2):163–168.6506091
Kostial K, Kargacin B, Rabar I, . 1981a. Simultaneous reduction of radioactive strontium, caesium and iodine retention by single treatment in rats. Sci Total Environ 22:1–10.7336198
Kostial K, Kargacin B, Simonovic I. 1987. Reduced radiostrontium absorption in a human subject treated with composite treatment for mixed fission product contamination. Health Phys 52(3):371–372.3818304
Kostial K, Maljkovic T, Kadic M, . 1967. Reduction of the absorption and retention of strontium in rats. Nature 215:182.
*Kostial K, Maljkovic T, Paulic N, . 1979. The effect of THPC, a new cyclic analogue of BAETA on radiostrontium removal in rats. Health Phys 37:181.120868
Kostial K, Simonovic I, Rabar I, . 1980a. Influence of human foods and rat diet on radiostrontium bioavailability in rats. Period Biol 82(2):229–234.
*Kostial K, Simonovic I, Rabar I, . 1981b. Effect of rat’s diet on ^85^Sr, ^115m^Cd, and ^203^Hg absorption in suckling rats. Environ Res 25(2):281–285.7274191
Kostial K, Vnucec M, Tominac C, . 1980b. A method for a simultaneous decrease of strontium, caesium and iodine retention after oral exposure in rats. Int J Radiat Biol 37(3):347–350.
Kostial K, Vojvodic S, Comar CL. 1965. Effects of dietary levels of phosphorus and calcium on the comparative behaviour of strontium and calcium. Nature 208:1110–1111.5870573
Kowalewski K, Rodin AE. 1964. Strontium-89-induced bone tumour in the rat. Can J Surg 7:204–215.14142593
*Kozheurov VP. 1994. SICH-9.1 - A unique whole-body counting system for measuring Sr-90 via bremsstrahlung. The main results from a long-term investigation of the Techa River population. Sci Total Environ 142:37–48.8178135
*Krachler M, Scharfetter H, Wirnsberger GH. 2000. Kinetics of the metal cations magnesium, calcium, copper, zinc, strontium, barium, and lead in chronic hemodialysis patients. Clin Nephrol 54(1):35–44.10939755
*Kramer GH, Davies JM. 1982. Isolation of strontium-90, yttrium-90, promethium-147, and cerium-144 from wet ashed urine by calcium oxalate coprecipitation and sequential solvent extraction. Anal Chem 54:1428–1431.7114480
Kramer HJ, Gonick HC, Lu E. 1986. In vitro inhibition of Na-K-ATPase by trace metals: Relation to renal and cardiovascular damage. Nephron 44:329–336.3025755
*Kraybill HF. 1983. Assessment of human exposure and health risk to environmental contaminants in the atmosphere and water with special reference to cancer. J Environ Sci Health C 1(2):175–232.
Krieger HL, Martin ER, Frishkorn GW. 1976. Sequential radiochemical analysis for ruthenium, strontium and cesium in environmental air. Health Phys 30:465–470.955902
Krishnamurthy GT, Krishnamurthy. 2000. Radionuclides for metastatic bone pain palliation: a need for rational re-evaluation in the new millennium. J Nucl Med 41(4):688–691.10768570
*Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3^rd^ ed. New York, NY: Raven Press, Ltd., 149–188.
*Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
*Kroes R, den Tonkelaar EM, Minderhoud A, . 1977. Short-term toxicity of strontium chloride in rats. Toxicology 7(1):11–21.841579
Krusemark LL, Boomgaardt J, Harmon BG, . 1974. Distribution of injected ^85^Sr in tissues and bones of growing pigs. J Anim Sci 39(2):331–334.4845709
Krushevska A, Barnes RM. 1994. Inductively coupled plasma atomic emission spectrometric determination of aluminium, barium, silicon, strontium and titanium in food after sample fusion. Analyst 119:131–134.8154595
*KS Dept Health & Environ. 1999. Water pollution control. Kansas Department of Health and Environment. Wysiwig://29/http://www.kdhe.state.ks.us/regs/index.html (http://Wysiwig://29/http://www.kdhe.state.ks.us/regs/index.html).
Kshirsagar SG. 1975. The effect of stable strontium on the alkaline phosphatase activity of rat tissues -- In vitro studies. Biochem Pharmacol 24:13–20.1122253
*Kshirsagar SG. 1976. Effect of stable strontium on the tissue alkaline and acid phosphatase activities of rat: Feeding studies. J Nutr 106(10):1475–1483.966072
*Kshirsagar SG. 1977. Radiostrontium distribution measured in vitro between bound and free forms in the soft tissues of rat. Int J Radiat Biol 32(6):561–569.
*Kshirsagar S, Vaughan J, Williamson M. 1965. The occurrence of squamous carcinoma and osteosarcoma in young rabbits injected with ^90^Sr(50-100 µc/kg). Br J Cancer 19(4):777–786.5217403
*Kulev YD, Polikarpov GG, Pridodey EV, . 1994. Strontium-90 concentrations in human teeth in south Ukraine, 5 years after the Chernobyl accident. Sci Total Environ 155:215–219.7801105
Kulp JL, Schulert AR, Hodges EJ. 1959. Strontium-90 in man III: The annual increase of this isotope and its pattern of world-wide distribution in man are defined. Science 129(3358):1249–1255.13658952
Kumar S, Singh S, Garg ML, . 1989. Elemental analysis of environmental samples using energy dispersive x-ray fluorescence technique. Indian J Environ Health 31(1):8–16.
Kumar V, Bennett M. 1981. The biology of marrow dependent cells in mice. In: Waters H, ed. The handbook of cancer immunology. New York, NY: Garland STPM Press, Vol. 6, 145–160.
Kurzel RB, Cetrulo CL. 1981. The effect of environmental pollutants on human reproduction, including birth defects. Environ Sci Technol 15(6):626–640.22299737
Lagged E, Akron K, Fonyó A. 1979. The inhibitor-sensitivity and pathways of P_i_ uptake during calcium and strontium accumulation in liver mitochondria. FEBS Lett 107(1):205–208.499543
Lamberts HB, Van Andel JG. 1965. The deposition of radioactive Ba and Sr in the aortic wall. Proc K Ned Akad Wet C 68(4):311–319.4221742
*Lansdown ABG, Longland RC, Grasso P. 1972. Reduced foetal calcium without skeletal malformations in rats following high maternal doses of a strontium salt. Experientia 28(5):558–560.5040807
LaPuma PT, Bolch WE. 1999. The impact of recirculating industrial air on aircraft painting operations. Appl Occup Environ Hyg 14(10):682–690.10561879
Larsson S-E, Lorentzon R, Boquist L. 1977. The effect of immunotherapy with BCG on the development of radiostrontium (^90^Sr)-induced osteosarcoma. Acta Pathol Microbiol Scand Sect A 85:433–446.268925
*Lassey KR. 1979. The transfer of radiostrontium and radiocesium from soil to diet: Models consistent with fallout analyses. Health Phys 37:557–573.536218
Latch C, Hoffmann E, Sole J. 1994. Studies on the determination of the metal content of airborne particulate by furnace atomization non-thermal excitation spectrometry. J Anal Atom Spectrum 9:685–689.
*Lavinia E, Kumar V, Bennett M. 1981. Hybrid resistance to EL-4 lymphoma cells. Scand J Immunol 13:563–571.6458878
Ledin M, Pedersen K, Allard B. 1997. Effects of pH and ionic strength on the adsorption of Cs, Sr, Eu, Zn, Cd and Hg by Pseudomonas putida. Water Air Soil Pollut 93:367–381.
*Lee CK, Aeppli DM, Unger J, . 1996. Strontium-89 chloride (metastron) for palliative treatment of bony metastasis: The University of Minnesota experience. Am J Clin Oncol 19(2):102–107.8610630
*Lee RE, von Lehmden DJ. 1973. Trace metal pollution in the environment. J Air Pollut Control Assoc 23(10):853–857.4746266
*Leeder JS, Kearns GL. 1997. Pharmcogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Leeuwenkamp OR, van der Vijgh WJH, Hüsken BCP, . 1989. Quantification of strontium in plasma and urine with flameless atomic absorption spectrometry. Clin Chem 35(9):1911–1914.2776316
*Leeuwenkamp OR, van der Vijgh WJF, Hüsken BCP, . 1990. Human pharmacokinetics of orally administered strontium. Calcif Tissue Int 47:136–141.2224588
*Leggett RW. 1992. A generic age-specific biokinetic model for calcium-like elements. Radiat Prot Dosim 41(2/4):183–198.
Leggett RW, Eckerman KF, Williams LR. 1982. Strontium-90 in bone: A case study in age-dependent dosimetric modeling. Health Phys 43(3):307–322.7174326
Le Grand L. 1972. Contamination by osteotropic β emitters - An evaluation of the doses in bone marrow and endosteum - Effect of age. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59^th^ ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 49–66.
*Leininger JR, Riley MGI. 1990. Bones, joints, and synovia. In: Boorman GA, Eustis SL, Elwell MR, . eds. Pathology of the Fischer rat: Reference and atlas. New York, NY: Academic Press, Inc, 209–226.
*Lembrechts J. 1993. A review of literature on the effectiveness of chemical amendments in reducing the soil-to-plant transfer of radiostrontium and radiocesium. Sci Total Environ 137:81–98.
Lemon GJ, Davies DR, Hughes SPF, . 1980. Transcapillary exchange and retention of fluoride, strontium, EDTA, sucrose, and antipyrine in bone. Calcif Tissue Int 31:173–181.6770980
Lenexa J. 1971. Kinetics of calcium, strontium, barium and radium in rabbits. Health Phys 21:367–376.5095636
*LeRoy GV, Rust JH, Hasterlik RJ. 1966. The consequences of ingestion by man of real and simulated fallout. Health Phys 12:449–473.5960263
*Leung H-W. 1993. Physiologically-based pharmacokinetic modeling. In: Ballentine B, Marro T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Levis AG, Majone F. 1981. Cytotoxic and clastogenic effects of soluble and insoluble compounds containing hexavalent and trivalent chromium. Br J Cancer 44:219–235.7272188
Levy EM, Bennett M, Kumar V, . 1980. Adoptive transfer of spleen cells from mice treated with radioactive strontium: Suppressor cells, natural killer cells, and “hybrid resistance” in recipient mice. J Immunol 124(2):611–618.6444313
*Levy EM, Kumar V, Bennett M. 1981. Natural killer activity and suppressor cells in irradiates mice repopulated with a mixture of cells from normal and ^89^Sr-treated donors. J Immunol 127(4):1428–1432.6456306
*Levy LS, Martin PA, Bidstrup PL. 1986. Investigation of the potential carcinogenicity of a range of chromium containing materials on rat lung. Br J Ind Med 43:243–256.3964573
Lewis FV, Dobrota M, Taylor MG. 1999. Metal toxicity in two rodent species and redox potential evaluation of quantitative structure-activity relationships. Environ Toxicol Chem 18(10):2199–2204.29857628
*Li C, Davletov BA, Südhof TC. 1995. Distinct Ca^2+^ and Sr^2+^ binding properties of synaptotagmins: Definition of candidate Ca^2+^ sensors for the fast and slow components of neurotransmitter release. J Biol Chem 270(42):24898–24902.7559614
Li L, Kruszewski FH, Punnonen K, . 1993. Strontium induces marine keratinocyte differentiation in vitro in the presence of serum and calcium. J Cell Physiol 154:643–653.7679679
*Lide DR. 1995. Physical constants of inorganic compounds. In: CRC handbook of chemistry and physics. 76^th^ ed. Boca Raton, FL: CRC Press, 4-37 to 4-98.
*Lide DR. 2000. CRC handbook of chemistry and physics: A ready-reference book of chemical and physical data. 81^st^ ed. Boca Raton, FL: CRC Press.
Light JM, Stacey GK. 1972. Effect of fluoride-containing compounds on the skeletal retention of ^90^Sr and ^45^Ca in the rat. J Dent Res 51(4):909–917.4504710
*Light JM, Stacey GK, Mahler JC. 1970a. Effect of dietary sodium alginate on radiostrontium absorption and retention in rats. J Dent Res 49(2):442–453.5264611
Light JM, Stacey GK, Mahler JC. 1970b. The effects of sodium alginate and other untested polymers on radiostrontium retention in the rat. Proc Soc Exp Biol Med 133:1259–1269.5440416
Linner E, Rosengren B. 1969. Complications following eye treatment with ^90^Sr applicator. Acta Ophthalmol 47:202–207.5819826
*Lisk DJ. 1988. Environmental implications of incineration of municipal solid waste and ash disposal. Sci Total Environ 74:39–66.3065938
Litvak J, Oberhausen E, Rask J, . 1967. Strontium-85 kinetics in hypoparathyroidism at different levels of calcium intake. J Nucl Med 8:60–69.6019139
*Livingston, AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
*Llobet JM, Colomina MT, Domingo JL, . 1991a. Effect of chelating agents on tissue distribution and excretion of strontium following semichronic strontium ingestion. Res Commun Chem Pathol Pharmacol 71(2):243–246.2047570
*Llobet JM, Colomina MT, Domingo JL, . 1991b. Evaluation of the effects of chelation therapy with time following strontium exposure to mice. Arch Environ Contam Toxicol 21:612–620.1759854
*Llobet JM, Colomina MT, Domingo JL, . 1992a. Influence of several antidotal treatments on the distribution and excretion of strontium. J Environ Sci Health Part A A27(4):1103–1114.
*Llobet JM, Colomina MT, Domingo JL, . 1992b. Lack of effectiveness of several chelators in removing internally deposited strontium from mice following repeated parental strontium administration. Vet Hum Toxicol 34(1):7–9.1621368
*Llobet JM, Colomina MT, Domingo JL, . 1993. Evaluation of potential strontium chelators in an actinal-water system. Health Phys 65(5):541–544.8225994
*Lloyd E. 1968. Relative binding of strontium and calcium in protein and non-protein fractions of serum in the rabbit. Nature 217:355–356.5639151
Lloyd RD. 1990. Does the growth rate of a radionuclide-induced osteosarcoma depend of the skeletal dose rate during the growth period? Health Phys 58(1):73–76.2294077
*Lloyd RD, Angus W, Taylor GN, . 1995. Soft tissue tumors among beagles injected with ^90^Sr, ^228^Ra, ^228^Th. Health Phys 69(2):272–277.7622376
Lloyd RD, Miller SC, Taylor GN, . 1994a. Relative effectiveness of ^239^Pu and some other internal emitters for bone cancer induction in beagles. Health Phys 67(4):346–353.8083047
Lloyd RD, Miller SC, Taylor GN. 2001. Does longevity in beagles injected with bone-seeking radionuclides depend upon radiation dose in the absence of known radiation effects? Health Phys 81(4):456–459.11569641
*Lloyd RD, Taylor GN, Angus W, . 1994b. Eye tumors and other lesions among beagles give ^90^Sr or ^226^Ra. Health Phys 66(3):346–349.8106256
Lloyd RD, Taylor GN, Miller SC. 2000. Does body size contribute to sensitivity of bone tumor induction by radionuclide exposure? Health Phys 79(2):199–202.10910392
*Loeb LA, Sirover MA, Weymouth LA, . 1977. Infidelity of DNA synthesis as related to mutagenesis and carcinogenesis. J Toxicol Environ Health 2:1297–1304.886629
*Loeser D, Konwiser AL. 1930. A study of the toxicity of strontium and comparison with other cations employed in therapeutics. J Lab Clin Med 15:35–41.
Loutit JF. 1965. Diurnal variation in urinary excretion of calcium and strontium. Proc R Soc London, Ser B 162:458–472.4378459
Loutit JF. 1967. Strontium-90 and leukemia. Sci Basis Med 1967:340–355.
Loutit JF. 1968. What is the turnover of bone mineral? Calcif Tissue Res 2:111–114.5674911
*Loutit JF. 1976. Vasoformative non-osteogenic (agio) sarcomas of bone-marrow stroma due to strontium-90. Int J Radiat Biol 30(4):359–383.
Loutit JF, Vaughan JM. 1971. Correspondence: The radiosensitive tissues in bone. Br J Radiol 44:815.5165658
*Luevano E, Kumar V, Bennett M. 1981. Hybrid resistance to EL-4 lymphoma cells. Scand J Immunol 13:563–571.6458878
*Lüning KG, Fraulein H, Nelson A, . 1963a. Genetic effects of strontium-90 injected into male mice. Nature 197(4864):304–305.13931726
*Lüning KG, Fraulein H, Nelson A, . 1963b. Genetic effects of strontium-90 on immature germ-cells in mice. Nature 199(4890):303–304.14076710
Lust JA, Kumar V, Burton RC, . 1981. Heterogeneity of natural killer cells in the mouse. J Exp Med 154:306–317.7264561
Lykhtarev IA, Krasnostchekova GP. 1972. Mathematical model of endocrine regulation of calcium-strontium metabolism and its experimental study. In: International Conference on Strontium Metabolism, ed. Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 229–238.
MacDonald NS, Braden L, James E, . 1967. Short term tissue distribution of several radionuclides useful in bone scanning. Proc Soc Exp Biol Med 124(1):69–73.6017794
*MacDonald NS, Figaro WG, Crist MR. 1965. Short-term retention of strontium-85 and estimation of initial strontium-90 burdens in humans. Health Phys 11:1187–1194.5867871
MacDonald NS, Nusbaum RE, Stearns R, . 1951. The skeletal deposition of non-radioactive strontium. J Biol Chem 188:137–143.14814122
Mackay WA, Strange L, Walker MI, . 1994. A study of plutonium and americium concentrations in sea spray on the southern Scottish coast. Sci Total Environ 144:73–86.
*Madeddu L, Saito I, Hsiao TH, . 1985. Leptinotoxin-h action in synaptosomes and neurosecretory cells: Stimulation of neurotransmitter release. J Neurochem 45:1719–1730.2414401
Magna PJ, Baratta EJ, Leonard IE. 1966. Strontium-90 in human hair and blood. Health Phys 12:1493–1496.5972447
*Mahara Y. 1993. Heavy metals in the environment: Storage and migration of fallout strontium-90 and cesium-137 for over 40 years in the surface soil of Nagasaki. J Environ Qual 22:722–730.
*Malek MA, Hinton TG, Webb SB. 2002. A comparison of 90Sr and 137Cs uptake in plants via three pathways at two Chernobyl-contaminated sites. J Environ Radioact 58:129–141.11814162
Maltby B, Lemon GJ, Bassingthwaighte JB, . 1982. Exchange of potassium and strontium in adult bone. Am J Physiol 242:H705–H712.7065283
Marcus AH, Becker A. 1980. Alkaline earth metabolism: The ICRP model reformulated as a semimarkov model. Health Phys 38:825–832.7390846
Marcus CS. 1972. Use of ^87m^Sr and semiconductor radiation detectors for in vivo physiological studies. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 79–90.
Marcus CS, Vos O. 1967. Two-component radiation effect on strontium^85^ absorption by the rat ileum in situ. Proc Soc Exp Biol Med 121(3):885–888.
*Marcus CS, Wasserman RH. 1965. Comparison of intestinal discrimination between calcium 47, strontium 85, and barium 133. Am J Physiol 209:973–977.5849501
*Marei AN, Borisov BK, Petukhova EV. 1976. The content of ^90^Sr in the bone tissue of the population of the Soviet Union (1959-1971) (The basic laws of its accumulation and distribution). J Hyg Epidemiol Microbiol Immunol 20(3):257–265.
*Marie PJ, Hott M. 1986. Short-term effects of fluoride and strontium on bone formation and resorption in the mouse. Metabolism 35(6):547–551.3713515
Marie PJ, Ammann P, Boivin G, . 2001. Mechanisms of action and theraputic potential of strontium in bone. Calcif Tissue Int 69:121–129.11683526
*Marie PJ, Gaba MT, Hot M, . 1985. Effects of low doses of stable strontium on bone metabolism in rats. Miner Electrolyte Metab 11(1):5–13.3974537
Markham OD, Hafford DK, Autenrieth RE. 1980. Strontium-90 concentrations in pronghorn antelope bones near a nuclear fuel reprocessing plant. Health Phys 38:811–816.7390844
*MARLAP. 2001. Multi-Agency Radiological Laboratory Analytical Protocols Manual (MARLAP) Draft. U.S. Environmental Protection Agency. PB2001-106745. http://www.eml.doe.gov/marlap/. November 21, 2002.
Marois P, Marois M. 1971. [Action of tetracycline on tooth and bone. (General review and experimental study in rats)]. Biol Med (Paris) 60(3):293–362. (French)4257996
Marshall JH. 1964. Theory of alkaline earth metabolism: The power function makes possible a simple but comprehensive model of skeletal systems. J Theor Biol 6:386–412.5875212
Marshall JH. 1972. Alkaline earth metabolism in adult man: A condensation. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59^th^ ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 207–228.
*MARSSIM. 1997. Multi-agency radiation survey and site investigation manual. Nuclear Regulatory Commission, Energy Department, Environmental Protection Agency, and Defense Department. NUREG 1575, EPA 402 R 97 016.
Mart E. 1980. Immune T lymphocyte to tumor cell adhesion: Magnesium sufficient, calcium insufficient. J Cell Biol 84:584–598.6766945
Martin WE, Turner FB. 1966. Transfer of ^89^Sr from plants to rabbits in a fallout field. Health Phys 12:621–631.5956190
*Matsumoto A. 1976. Effect of strontium on the epiphyseal cartilage plate of rat tibiae -- Histological and radiographic studies. Jpn J Pharmacol 26:675–681.1021603
Matsumoto A. 1988. Effect of strontium chloride on bone resorption induced by prostaglandin E_2_ in cultured bone. Arch Toxicol 62:240–241.3196163
*Mayr U, Busch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, Phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
Mays CW, Dougherty TF. 1972. Progress in the beagle studies at the University of Utah. Health Phys 22:793–801.5084013
Mays CW, Lloyd RD. 1966. ^90^Sr and ^89^Sr dose estimates for the fetus and infant. Health Phys 12:1225–1236.5970975
Mays CW, Lloyd RD. 1972. Predicted toxicity of ^90^Sr in humans. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 181–206.
Mays CW, Jee WSS, Lloyd RD, ., eds. 1969. Delayed effects of bone-seeking radionuclides. Salt Lake City, UT: University of Utah Press.
Maxilla GF, Tyrannid L, Caen G, . 1966. Effects of thyrocalcitonin on bone and renal excretion of calcium 45 and strontium 85 in the rat. Foliar Endocrinol 19(1):7–13.
Mazzucotelli A, Raver P. 1993. Study of interferences in the spectrochemical behavior of strontium, related to its determination in the shell of marine organisms. Annals di Camacho 83:105–115.
McAughey JJ, Samuel AM, Baxter PJ, . 1988. Biological monitoring of occupational exposure in the chromate pigment production industry. Sci Total Environ 71:317–322.3406704
McBride MB, Richards BK, Steenhuis T, . 1997. Mobility and solubility of toxic metals and nutrients in soil fifteen years after sludge application. Soil Sci 162(7):487–500.
McBride MB, Richards BK, Steenhuis T, . 1999. Long-term leaching of trace elements in a heavily sludge-amended silty clay loam soil. Soil Sci 164(9):613–623.
McCarthy ID, Hughes SPF. 1986. Inhibition of bone cell metabolism increases strontium-85 uptake. Calcif Tissue Int 39:386–389.3100002
McCarthy ID, Hughes SPF. 1989. Multiple tracer studies of bone uptake of ^99m^Tc-M.P. and ^85^Sr. Am J Physiol 256:H1261–H1265.2719126
*McClellan RO, Benjamin SA, Boecker BB, . 1973. Neoplasms in dogs that inhaled ^90^SrCl_2_. AEC Symp Ser 29:215–232.
*McClellan RO, Boecker BB, Hahn FF, . 1983a. Lovelace TRI studies on the toxicity of inhaled radionuclides in beagle dogs. In: Thompson RC, Mahaffey JA, eds. Life-span radiation effects studies in animals: What can they tell us? Proceedings of the twenty-second Hanford life science symposium held at Richland, Washington, September 27-29, 1983. Hanford Life Sciences Symposium 22^nd^. Springfield, VA: United States Department of Energy, 74–96.
McClellan RO, Boecker B, Hahn FF. 1983b. Toxicity of inhaled ^90^SrCl_2_. In: Brewers JJ, Barendsen GW, Kan HB, ., eds. Somatic and genetic effects. Amsterdam: Margins Nijhoff Publishers, C7-05–C7-06.
*McClellan RO, Kerr ME, Bustard LK. 1963. Reproductive performance of female miniature swine ingesting strontium-90 daily. Nature 197:670–671.
*McCormack JG, Osbaldeston NJ. 1990. The use of the Ca^2+^-sensitive intra mitochondrial dehydrogenate and entrapped Furr-2 to study Sr^2+^ and Ba^2+^ transport across the inner membrane of mammalian mitochondria. Eur J Biochem 192:239–244.2401295
McCredie D, Rosenberg E. 1972. Strontium kinetic studies in children with bone disorders. Aust Paediat 69:79–86.
*McLachlan EM. 1977. The effects of strontium and barium ions at synapses in sympathetic ganglia. J Physiol 267:497–518.195042
McQueen CM, Smith DA. 1972. The relative uptake of ^45^Ca and ^85^Sr into bone. In:. Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59^th^ ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 403–412.
*MDEQ. 2000. Safe drinking water act. Michigan Department of Environmental Quality. http://www.deq.state.mi.us/dept/envregs.html.
Mellen PF, Lust JA, Bennett M, . 1982. Analysis of low natural killer cell activity in ^89^Sr-treated mice. Eur J Immunol 12:442–445.6212259
Menczel J, Mor E. 1972. The effect of thyrocalcitonin (TCT) on calcium binding protein (CABP) and strontium binding protein (SRBP). In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59^th^ ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 273–276.
Merck. 1989. The Merck index: An encyclopedia of chemicals, drugs, and biologicals. 11^th^ ed. Rahway, NJ: Merck and Company, Inc, 1394–1395.
*Merluzzi VJ, Levy EM, Kumar V, . 1978. In vitro activation of suppressor cells from spleens of mice treated with radioactive strontium. J Immunol 121(3):505–512.681747
*Mermier P, Hasselbach W. 1976. Comparison between strontium and calcium uptake by the fragmented sarcoplasmic reticulum. Eur J Biochem 69:79–86.136346
*Merriam GR. 1955. Late effects of beta radiation on the eye. AMA Arch Ophth 53:708–717.
*Meunier PJ, Roux C, Seeman E, . 2004. The effects of strontium ranelate on the risk of vertebral fracture in women with postmenopausal osteoporosis. N Engl J Med 350(5):459–468.14749454
*Meunier PJ, Slosman, DO, Delmas PD, . 2002. Strontium ranelate: dose-dependent effects in established postmenopausal vertebral osteoporosis—a 2-year randomized placebo controlled trial. J Clin Endocrinol Metab 87(5):2060–2066.11994341
Mewhinney JA, Griffith WC, Hahn FF, . 1983. Incidence of bone cancer in beagles after inhalation of ^90^SrCl_2_ or ^238^PuO_2_: Implications for estimation of risk to humans. In: Thompson RC, Mahaffey JA, eds. Life-span radiation effects studies in animals: What can they tell us? Proceedings of the twenty-second Hanford life science symposium held at Richland, Washington, September 27-29, 1983. Hanford Life Sciences Symposium 22^nd^. Springfield, VA: United States Department of Energy, 535–554.
Milin L, Anderson JJB. 1968. Whole-body retention of strontium-85 in swine given sodium alginate or barium and sodium sulfates. J Nutr 97:181–184.
*Miller DL, Schedl HP. 1976. Effects of experimental diabetes on intestinal strontium absorption in the rat. Proc Soc Exp Biol Med 152:589–592.135263
*Mill AJ, Wells J, Hall SC, . 1996. Micronucleus induction in human lymphocytes: comparitive effects of X-rays, alpha particles, beta particles and neutrons and implications for biological dosimetry. Radiat Res 145(5):575–585.8619023
*Milsom S, Ibbertson K, Hannan S, . 1987. Simple test of intestinal calcium absorption measured by stable strontium. Br Med J 295:231–234.3115389
*Miro M, Gomez E, Estela JM, . 2002. Sequential injection ^90^Sr determination in environmental samples using a wetting-flim extraction method. Anal Chem 74:826–833.11866063
Mitchel RE, Gragtmans NJ, Morrison DP. 1990. Beta-radiation-induced resistance to MNNG initiation of papiloma but not carcinoma formation in mouse skin. Radiat Res 121:180–186.2305036
Mitchell CE, Longwell BB. 1970. The effects of adrenocorticotrophin hormone and metyrapone on the excretion of urinary steroids by beagle dogs burdened with strontium-90. Radiat Res 41:78–88.4311750
Mittleman R, Chausmer A, Bellavia J, . 1967. Thyrocalcitonin activity in hypercalcemia produced by calcium salts, parathyroid hormone and vitamin D. Endocrinology 81:599–604.4291806
Möbius S, Ramamonjisoa T-L, Jongisook W, . 1995. Ion chromatography and liquid scintillation counting couples to determine α- and β-emitters. Sci Total Environ 173/174:231–235.
Moghissi AA, Mayes MG, Carter MW. 1972. Radiobioassay program of the institutional total diet sampling network: IV. Evaluation of the ^90^Sr data for children. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 505–512.
Mohammed J, Chowdhury J, Blust R. 2001. Effect of temperature on the uptake of waterborne strontium in the common carp, Cyprinus carpio (L). Aquat Toxicol 54:151–160.11489303
Moisecu DG, Thieleczek R. 1978. Calcium and strontium concentration changes within skinned muscle preparations following a change in the external bathing solution. J Physiol 275:241–262.24736
Molchanova IV, Karavaeva EN, Kulikov NV. 1973. Influence of soil moisture content on strontium-90 uptake by plants. Sov J Ecol 3(3):257–259.
Mole RH. 1963. Bone tumour production in mice by strontium-90: Further experimental support for a two-event hypothesis. Br J Cancer 17(3):524–531.14062500
Mole RH, Ward AH. 1970. Yttrium-90 in gonads of monkeys containing strontium-90. Nature 226:175.
Moloukhia MK, Abdel-Fattah AT. 1980. Equilibrium treatment for radiostrontium uptake by human and animal bones. Isot Radiat Res 12(1):35–42.
*Momčilovič B, Gruden N. 1981. The effect of dietary fibre on ^85^Sr and ^47^Ca absorption in infant rats. Experientia 37(5):498–499.6265272
*Momeni MH, Williams JR, Jow N, . 1976. Dose rates, dose and time effects of ^90^Sr + ^90^Y and ^226^Ra on beagle skeleton. Health Phys 30:381–390.1270266
Moon J. 1994. The role of vitamin D in toxic metal absorption: A review. J Am Coll Nutr 13(6):559–569.7706586
Moore W, Elder RL. 1965. Effect of alginic acid and the movement of strontium-85 and calcium-45 across surviving ileal segments. Nature 206:841–842.5840142
Moraes MEA, Aronson JK, Grahame-Smith DG. 1991a. The effect of nifedipine on the disposition of strontium gluconate used as a kinetic marker for calcium in healthy volunteers. Br J Clin Pharmacol 32:441–445.1958437
Moraes MEA, Aronson JK, Grahame-Smith DG. 1991b. Intravenous strontium gluconate as a kinetic marker for calcium in healthy volunteers. Br J Clin Pharmacol 31:423–427.2049251
Morgan JE, Richards SPG, Morgan AJ. 2001. Stable strontium accumulation by earthworms: a paradigm for radiostrontium interactions with its cationic analogue, calcium. Environ Toxicol Chem 20(6):1236–1243.11392133
Morohashi T, Sano T, Harai K, . 1995. Effects of strontium on calcium metabolism in rats II. Strontium prevents the increased rate of bone turnover in ovariectomized rats. Jpn J Pharmacol 68:153–159.7563972
*Morohashi T, Sano T, Yamada S. 1994. Effects of strontium on calcium metabolism in rats: I. A distinction between the pharmacological and toxic doses. Jpn J Pharmacol 64:155–162.8022117
Morrison SJ, Cahn LS. 1991. Mineralogical residence of alpha-emitting contamination and implications for mobilization from uranium mill tailings. J Contam Hydrol 8:1–21.
Morse BS, Giuliani D, Giuliani ER. 1974. Effect of radiation on bone formation: A functional assessment. Radiat Res 60:307–313.10881713
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
*Mortimer D. 1986. Comparison of the fertilizing ability of human spermatozoa preincubation in calcium- and strontium-containing media. J Exp Zool 237:21–24.3950559
*Mortimer D, Curtis EF, Dravland JE. 1986. The use of strontium-substituted media for capacitating human spermatozoa: an improved sperm preparation method for the zona-free hamster egg penetration test. Fertil Steril 46(1):97–103.3087792
*Moskalev JI, Buldakov LA, Lyaginskaya AM, . 1969. Experimental study of radionuclide transfer through the placenta and their biological action on the fetus. AEC Symp Ser 17:153–160.
Moskalev YI, Buldakov LA. 1968. The kinetics of accumulation and elimination of orally administered strontium-90. Health Phys 15:229–235.5676162
Moskalev YI, Strel’tsova VN, Kalistratova VS. 1972. The combined effects of ^131^J and ^90^Sr in experimental animals. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 155–166.
Muck K, Sinojmeri M, Whilidal H, . 2001. The long-term decrease of ^90^Sr availability in the environment and its transfer to man after a nuclear fallout. Radiat Prot Dosim 94(3):251–259.
Muggenburg BA, Boecker BB, Hahn FF, . 1983. The risk of liver tumors in dogs and man from radioactive aerosols. In: Thompson RC, Mahaffey JA, eds. Life-span radiation effects studies in animals: What can they tell us? Proceedings of the twenty-second Hanford life science symposium held at Richland, Washington, September 27-29, 1983. Hanford Life Sciences Symposium 22^nd^. Springfield, VA: U.S. Department of Energy, 556–563.
*Muggenburg BA, Hahn FF, Boecker BB, . 1979. Toxicity of inhaled ^90^SrCl_2_ in beagle dogs, XIII. In: Annual reports of the Inhalation Toxicology Research Institute. Albuquerque, NM: Inhalation Toxicology Research Institute, 57–61.
*Muggenburg BA, Rebar AH, Benjamin SA, . 1977. Toxicity of inhaled ^90^SrCl_2_ in beagle dogs, XI. In: Annual reports of the Inhalation Toxicology Research Institute. Albuquerque, NM: Inhalation Toxicology Research Institute, 62–65.
*Muggenburg BA, Rebar AH, Boecker BB, . 1978. Toxicity of inhaled ^90^SrCl_2_ in beagle dogs. XII. In: McClellan RO, ed. Annual report of the inhalation toxicology research institute. Albuquerque: Lovelace Biomedical and Environmental Research Institute.
*Müller J, Thomas J. 1968. The course in time of the strontium retention in man. Health Phys 14:285–292.5647257
Müller J, David A, Rejskova M, . 1961. Chronic occupational exposure to strontium-90 and radium-226. Lancet:129–131.13733013
*Müller J, Klener V, Tuscany R, . 1966. Study of internal contamination with strontium-90 and radium-226 in man in relation to clinical findings. Health Phys 12:993–1006.
Muller WA. 1967. Radiobiology: Gonad dose in male mice after incorporation of strontium-90. Nature 214:931–933.6054992
Muller WA. 1972. ^90^Y distribution in male mice after injection of ^90^Sr, and consequences for dose burden of bone, soft tissue, and gonads. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59^th^ ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 137–144.
*Müller WH. 1970. Sr-85 decorporation with a cryptating agent. Naturwissenschaften 57(5):248.
*Mumma RO, Raupach DC, Waldman JP, . 1984. National survey of elements and other constituents in municipal sewage sludges. Arch Environ Contam Toxicol 13:75–83.
*Muñiz CS, Marchante-Gayón JM, Alonso JIG, . 1999. Multi-elemental trace analysis of human serum by double-focusing ICP-MS. J Anal Atom Spectrom 14:193–198.
*Murray RL. 1994. Understanding radioactive waste. 4^th^ ed. Columbus, OH: Battelle Press, 58–193.
*Mutschke U, Pribilla O. 1967. Detection of radionuclides of biological interest in human bones and tissues. Prog Chem Toxicol 3:244–303.
Nakai GS, Guganig ME, Kelley RO, . 1971. Cytoplasmic DNA in ^90^Sr-induced rat chloro leukemia. Rev Eur Etud Clin Biol XVI:560–563.
Nakaji S, Fukuda S, Sakamoto J, . 2001. Relationship between mineral and trace element concentration in drinking water and gastric cancer mortality in Japan. Nutr Cancer 40(2):99–102.11962262
*Naményi J, Gachalyi A, Varga LP. 1986. Decorporation of ^85^Sr by radioadsorbents from the lungs of rats with bronchial disorders. Health Phys 51(4):539–544.3759468
Narayan K, Cliff WJ. 1981. Use of rabbit ear chamber and strontium-90 source to study radiation pathology in vivo. Microvasc Res 21:384–389.7242386
Narayan K, Cliff WJ. 1982. Morphology of irradiated microvasculature: A combined in vivo and electron-microscopic study. Am J Pathol 106:47–62.7055211
*NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press.
*Navarro T, López MA. 1998. Accidental contamination with ^90^Sr: A case study. Radiat Prot Dosim 79(1–4):67–70.
*NCRP. 1984. Radiological assessment: Predicting the transport, bioaccumulation, and uptake by man of radionuclides released to the environment. NCRP Report No. 76. Bethesda, MD: National Council on Radiation Protection and Measurements.
*NCRP. 1987a. Ionizing radiation exposure of the population of the United States. National Council on Radiation Protection and Measurements. NCRP Report No. 93, 1–69.
*NCRP. 1987b. Public radiation exposure from nuclear power generation in the United States. National Council on Radiation Protection and Measurements. Report No. 92. Bethesda, MD.
*NCRP. 1991. Some aspects of strontium radiobiology. Bathesda, MD: National Council on Radiation Protection and Measurements. NCRP Report No. 110.
*NCRP. 1993. Limitation of exposure to ionizing radiation. National Council on Radiation Protection and Measurements. Report No. 116.
*Neighbor PA, Huberman HS, Kress Y. 1982. Human large granular lymphocytes and natural killing: Ultrastructural studies of strontium-induced degranulation. Eur J Immunol 12:588–595.6956515
*Neufeld EB, Boskey AL. 1994. Strontium alters the complexed acidic phospholipid content of mineralizing tissues. Bone 15(4):425–430.7917582
Neumann GK. 1974. Diaplazentarer ubertritt von strontium-90 bei der ratte. Naturwissenschaften 61:221–222.4844150
Nevissi AE. 1992. Measurement of actinides and long-lived radionuclides in large coral samples. J Radioanal Nucl Chem 156(2):243–251.
*Newton D, Harrison GE, Rundo J, . 1990. Metabolism of Ca and Sr in late adult life. Health Phys 59(4):433–442.2398011
Nieuwinhuis BJWM, Weijers CAGM, Borst-Pauwels GWFH. 1981. Uptake and accumulation of Mn^2+^ and Sr^2+^ in Saccharomyces cerevisiae. Biochim Biophys Acta 649:83–88.6458334
*Niggli E. 1989. Strontium-induced creep currents associated with tonic concentrations in cardiac in cardiac myocytes isolated from guinea-pigs. J Physiol 414:549–568.2607441
*Nilsson A. 1970. Pathologic effects of different doses of radiostrontium in mice. Acta Radiol Ther Phys Biol 9(6):528–544.5493035
*Nilsson A. 1971. Pathologic effects of different doses of radiostrontium in mice: Development and incidence of leukemia. Acta Radiol Ther Phys Biol 10(1):115–128.5279124
*Nilsson A. 1972. Strontium-90-induced malignancies in mice. AEC Symp Ser 25:207–241.
*Nilsson A, Henricson B. 1969. The effect of ^90^Sr on the ovaries of the fetal mouse. AEC Symp Ser 17:313–324.
Nilsson A, Rönnbäck C. 1972. Influence of oestrogenic hormones on carcinogenesis and toxicity of radiostrontium. Acta Radiol Ther Phys Biol 12:209–228.
Nilsson A, Rönnbäck C. 1973. Carcinogenic effect in bone of radiostrontium and estrogenic hormones. AEC Symp Ser 29:154–158.
*Nilsson A, Rönnbäck C. 1988. Influence of low temperature on the excretion of radiocesium and radioruthenium compared with radiostrontium. Acta Oncol 27(3):289–292.3415859
*Nilsson A, Bierke P, Haraldsson I, . 1980a. Induction of pituitary tumours by combination of oestrogenic hormones and ^90^Sr. Acta Radiol Oncol 19(5):373–385.6259892
*Nilsson A, Bierke P, Walinder G, . 1980b. Age and dose related carcinogenicity of ^90^Sr. Acta Radiol Oncol 19(3):223–228.6257041
Nilsson BE. 1969. Uptake of ^47^Ca and ^85^Sr in the tibia and the femur in rats. Calcif Tissue Res 3:96–99.5772449
*Nilsson BE, Book SA. 1987. Occurrence and distribution of bone tumors in beagle dogs exposed to ^90^Sr. Acta Oncol 26(2):133–138.3606868
Nilsson BE, Saville PD. 1968. Relations between femur density and strontium-85 uptake in bipedal rats. Acta Orthop Scand 39:433–438.5726113
*Nilsson BE, Morgan JP, Book SA. 1985. Investigations of ^90^Sr in dogs: I. Pathogenesis of radiation-induced bone tumors. Acta Radiol Oncol 24(1):95–111.2984909
*NIOSH. 1994. Elements in blood or tissue. Method 8005, issue 2. In: NIOSH manual of analytical methods. 4^th^ ed. Cincinnati, OH: U.S. Department of Health and Human Services. National Institute for Occupational Safety and Health.
*NIOSH. 2000. Online pocket guide to chemical hazards. http://www.cdc.gov/niosh/npg/npg.html.
*Nishimura Y, Nakai A, Yoshimasu T, . 2000. Long-term results of fractional strontium-90 radiation therapy for pterygia. Int J Radiat Oncol Biol Phys 1(46):137–141.
*NOES. 1983. National Occupational Exposure Survey (NOES). Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Center for Disease Control, National Institute for Occupational Safety and Health.
Nordin BEC, Smith DA, Shimmins J, . 1967. The effect of dietary calcium on the absorption and retention of radiostrontium. Clin Sci 32:39–48.6020377
Nordio S, Donath A, Macagno F, . 1971. Chronic hypomagnesemia with magnesium-dependent hypocalcemia. Acta Paediatr Scand 60:449–455.5556387
*NRC. 1993. National Research Council. Pesticides in the diets of infants and children. Washington, DC: National Academy Press.
Ochs S, Jersild RA, Breen T, . 1986. The maintenance of axoplasmic transport by strontium and its localization in nerve fibers. J Neurobiol 17(1):55–61.2425053
*O’Connor BH, Kerrigan GC, Taylor KR, . 1980. Levels and temporal trends of trace element concentrations in vertebral bone. Arch Environ Health 35(1):21–28.7362267
*O’Day PA, Newville M, Neuhoff PS, . 2000. X-ray absorption spectroscopy of strontium(II) coordination. J Colloid Interface Sci 222:184–197.10662514
*Oghiso Y, Kubota Y, Takahashi S, . 1988. Effect of ^89^Sr-induced monocytopenia on splenic and pulmonary alveolar macrophage populations in a normal steady state. J Radiat Res 29:189–202.3204540
*Olehy DA, Schmitt RA, Bethard WF. 1966. Neutron activation analysis of magnesium, calcium, strontium, barium, manganese, cobalt, copper, zinc, sodium, and potassium in human erythrocytes and plasma. J Nucl Med 7:917–927.5958071
Olsen I. 1979. ^90^Sr in maternal, fetal and embryonic tissues of mice, evaluated by whole-body auto-radiography. J Dent Res 58(special issue D):2293.
*Olsen I, Jonsen J. 1979. ^90^Sr in placentas, embryos and foetuses of mice, evaluated by whole-body autoradiography. Acta Pharmacol Toxicol (Copenh) 44:22–27.760384
*Olson EJ. 1979. Inhibition of active strontium transport from erythrocyte ghosts by internal calcium: Evidence for a specificity controlling site. J Membr Biol 48:265–284.490627
*Olson EJ, Cazort RJ. 1969. Active calcium and strontium transport in human erythrocyte ghosts. J Gen Physiol 53(3):311–322.4304202
*Omdahl JL, DeLuca HF. 1971. Strontium induced rickets: Metabolic basis. Science 174:949–951.4330835
*Omdahl JL, DeLuca HF. 1972. Rachitogenic activity of dietary strontium. J Biol Chem 247(17):5520–5526.4341346
Omdahl JL, Hunsaker LA, Aschenbrenner VA. 1977. Control of kidney 25-hydroxy vitamin D_3_ metabolism: Strontium and the involvement of parathyroid hormone. Arch Biochem Biophys 184:172–178.200180
*Ondov JM, Choquette CE, Zoller WH, . 1989. Atmospheric behavior of trace elements on particles emitted from a coal-fired power plant. Atmos Environ 23(10):2193–2204.
*Onyskowova Z, Josífko M. 1985. Strontium-85 in the fetuses of pregnant rats and mice. J Hyg Epidemiol Microbiol Immunol 29(1):1–7.
*Ootsuyama A, Tanooka H. 1986. Unscheduled DNA synthesis after β-irradiation of mouse skin in situ. Mutat Res 166:183–185.3762564
*Ootsuyama A, Tanooka H. 1988. One hundred percent tumor induction in mouse skin after repeated β irradiation in a limited dose range. Radiat Res 115:488–494.3174932
*Ootsuyama A, Tanooka H. 1989. Induction of osteosarcomas in mouse lumbar vertebrae by repeated external β-irradiation. Cancer Res 49:1562–1564.2924307
Orlowski S, Champeil P. 1993. Strontium binding to sarcoplasmic reticulum Ca^2+^-ATPase: Spectroscopic differentiation of the substeps involved. FEBS Lett 328(3):296–300.8348979
*Ortega A, Gómez M, Domingo JL, . 1989. The removal of strontium from the mouse by chelating agents. Arch Environ Contam Toxicol 18:612–616.2505695
Osanov DP, Panova VP, Arefieva SS. 1971. Evalutation of age influence on accumulation and elimination rate of radioactive strontium. Health Phys 21:205–210.5094191
*OSHA. 1996a. Toxic and hazardous substances. Ionizing radiation. U.S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1096.
*OSHA. 1996b. Safety and health regulations for construction. Ionizing radiation. U.S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.53.
*OSHA. 1999a. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000.
*OSHA. 1999b. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000.
*OSHA. 1999c. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55.
*OSHA. 2000. Ionizing radiation. Occupational Safety and Health Administration. Code of Federal Regulations. 29CFR1910.1096. http://frwebgate.access.gpo.gov/
*OSHA. 2001. Safety and health regulations for construction. Ionizing radiation. Occupational Safety and Health Administration. U.S. Department of Labor. Code of Federal Regulations. 29 CFR 1926.53. http://www.osha-slc.gov/OshStd_data/1926_0053.html. Mary 08, 2001.
Ostadalova I, Ostadal B. 1992. Effect of isoproterenol on ^85^Sr accumulation in the myocardium of the rat during postnatal ontogeny. Physiol Res 41:471–473.1299332
*OSW. 1992. Strontium (atomic absorption, direct aspiration). Method 7780. In: Test methods for evaluating solid waste, physical/chemical methods, SW-846. 3^rd^ ed. Washington, DC: Office of Solid Waste, U.S. Environmental Protection Agency. Vol. IA, Chap. 3, Sec. 3.3.
*Outridge PM, Hughes RJ, Evans RD. 1996. Determination of trace metals in teeth and bones by solution nebulization ICP-MS. Atom Spectrosc 17(1):1–8.
Overton TR, Snyder RE, Hangartner TN, . 1992. Changes in the linear attenuation coefficient of canine appendicular bone following intravenous infusion of strontium lactate, measured using gamma-ray computed tomography. Calcif Tissue Int 50:350–356.1571847
*Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Oyvin IA, Uklonskaya LI, Gaponiuk PJ. 1967. The participation of kinins in the pathogenesis of early disturbances in the skin capillary permeability in local β-ray irradiation. Experientia 23(7):555–556.4383407
*Özgür S, Sümner H, Kocoglu G. 1996. Rickets and soil strontium. Arch Dis Child 75:524–526.9014608
Palatay JL, Ragan HA, Clarke WJ, . 1966. Effects of strontium-90 in miniature swine - sixth progress report. In: Thompson RC, Swezea EG, eds. Pacific Northwest Laboratory annual report for 1965 in the biological sciences. Richland, WA: Pacific Northwest Laboratory, 24–28.
Palmer HE, Karagianes MT. 1976. Use of ^85^Sr as an indicator of bone mineral replacement in dogs after disuse demineralization. Aviat Space Environ Med 47(1):17–19.1247429
*Palmer RF, Thompson RC. 1961. Discrimination in intestinal absorption of strontium and calcium. Proc Soc Exp Biol Med 108:296–300.14483420
Palmer RF, Thompson RC. 1964. Strontium-calcium interrelationships in the growing rat. Am J Physiol 207(3):561–566.14220023
Palmer RF, Thomas JM, Watson CR, . 1970. Some aspects of dosimetry in miniature swine chronically ingesting ^90^Sr. Health Phys 19:775–783.5513692
*Palmer RF, Thompson RC, Kornberg HA. 1958. Effect of calcium on deposition of strontium-90 and calcium-45 in rats. Science 127:1505–1506.13555915
*Palmer RF, Watson CR, Beamer JL. 1969. Radiation dose to fetuses of miniature swine ingesting ^90^Sr. AEC Symp Ser 17:89–96.
Panteleev LI, Rasin IM, Sarapultsev IA. 1972. Animal-man extrapolation of strontium-90 accumulative regularities. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 239–246.
Pany JE. 1966. Die wirking von calciumsalzen auf die resorption con Ca und Sr dunndarm. Naturwissenschaften 53(18):480.
Papatheofanis FJ. 2000. Decreased serum E-selectin concentration after ^89^Sr-chloride therapy for metastatic prostate cancer bone pain. J Nucl Med 41:1021–1024.10855628
Papavasiliou C, Kostamis P, Angelakis P, . 1971. Localization of ^87m^Sr in extra-osseous tumors. J Nucl Med 12(5):265–268.5580843
*Papworth DG, Patrick G. 1970. The kinetics of influx of calcium and strontium into rat intestine in vitro. J Physiol 210:999–1020.5501493
*Papworth DG, Vennart J. 1984. The uptake and turnover of ^90^Sr in the human skeleton. Phys Med Biol 29(9):1045–1061.6483971
*Parkman RH, Charnock JM, Livens FR, . 1998. A study of the interaction of strontium ions in aqueous solution with the surfaces of calcite and kaolinite. Geochim Cosmochim Acta 62(9):1481–1492.
Parks NJ. 1985. Dynamics of lifespan strontium-90 distribution in beagles with uniformly labelled skeletons acquired by radionuclide ingestion from in utero to adulthood. EUR 9250:107–115.
Parks NJ. 1991. Radionuclide distribution dynamics in skeletons of beagles fed ^90^Sr: Correlation with injected ^226^Ra and ^239^Pu. Health Phys 60(3):343–351.1995507
Patrick G. 1967. Inhibition of strontium and calcium uptake by rat duodenal slices: Comparison of polyuronides and related substances. Nature 216:815–816.6074956
Patrick G, Carr TEF, Humphreys ER. 1967. Inhibition by alginates of strontium absorption studied in vivo and in vitro. Int J Radiat Biol 12(5):427–434.
Patten BC, Iverson RL. 1966. Radiobiology: Photosynthesis and uptake of strontium-85 in freshwater plankton. Nature 211(5044):96–97.5967484
Paul TM, Skoryna SC, Waldron-Edward D. 1966. Studies on the inhibition of intestinal absorption of radioactive strontium: V. The effect of administration of calcium alginate. Can Med Assoc J 95:957–960.5922911
Payton PH, Hild SB, Oertti CU, . 1977. Strontium-90 in the western Gulf of Mexico. Health Phys 33(2):143–145.20425
*Peel DM, Hopewell JW, Wells J, . 1984. Nonstochastic effects of different energy beta emitters on pig skin. Radiat Res 99:372–382.6463213
Pérez-Jordán MY, Salvador A, de la Guardia M. 1998. Determination of Sr, K, Mg and Na in human teeth by atomic spectrometry using a microwave-assisted digestion in a closed flow system. Anal Lett 31(5):867–877.
*Perry KD. 1999. Effects of outdoor pyrotechnic displays on the regional air quality of western Washington State. J Air Waste Manage Assoc 49:146–155.
Peters CJ, Walser M. 1966. Transport of cations by rabbit gall bladder: Evidence suggesting a common cation pump. Am J Physiol 210:677–683.5906794
*Petkau A, Pleskach SD. 1972. A case of accidental aspiration of ^90^SrCl_2_. Health Phys 22:87–90.4622228
Pezzi L. 1984. Effect of ruthenium red on the Ca^2+^ and Sr^2+^ efflux from rat liver mitochondria: Influence of nupercaine. Biosci Rep 4:231–237.6202338
Pfeiffer DR, Kauffman RF, Lardy HA. 1978. Effects of N-ethylmaleimide on the limited uptake of Ca^2+^, Mn^2+^, and Sr^2+^ by rat liver mitochrondria. J Biol Chem 253(12):4165–4171.26681
*Pfleger H, Wolf HU. 1975. Activation of membrane-bound high-affinity calcium ion-sensitive adenosine triphosphatase of human erythrocytes by bivalent metal ions. Biochem J 147:359–361.126684
*Phalen RF, Oldham HJ, Beaucage CB, . 1985. Postnatal enlargement of human tracheobronchial airways and implications for particle deposition. Anat Rec 212:368–380.4073554
Pietrzak-Flis Z, Grabowski D. 1972. Long-term study of the urinary strontium-90 and calcium in children. Health Phys 23:215–221.4644587
*Piette M, Desmet B, Dams R. 1994. Determination of strontium in human whole blood by ICP-AES. Sci Total Environ 141:269–273.8178121
*Piffanelli A, Dafermou A, Giganti M, . 2001. Radionuclide therapy for painful bone metastases. An Italian multicentre observational study. 45(1):100–107.
Pinchouk VG, Serkiz YI, Goldshmid BJ, . 1990. Peculiarities of spontaneous carcinogenesis in rats under the continuous influence of low intensity ionizing radiation. Anticancer Res 10(5 pt B):1386.
*Pivnick EK, Kerr NC, Kaufman RA, . 1995. Rickets secondary to phosphate depletion. Clin Pediatr 34:73–74.
Plishker GA. 1984. Effects of cadmium and zinc on calcium uptake in human red blood cells. Am J Physiol 247(16):C143–C149.6089571
*Poggi M, Aterini S, Nicastro L, . 1999. Lack of association between body weight, bone mineral density and vitamin D receptor gene polymorphism in normal and osteoporotic women. Disease Markers 15(4):221–227.10689545
Polachek I, Krejci I, Rudinger J. 1967. The action of oxytocin and synthetic analogues on the isolated mammary-gland myoepithelium of the lactating rat; effect of some ions. J Endocrinol 38:13–24.6067251
Poll B, Beddoe AH, Aspden PJ, . 1972. Thermoluminescence dosimetry of beta emitters in bone. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59^th^ ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 67–78.
*Pool RR, Williams RJR, Goldman M. 1972. Strontium-90 toxicity in adult beagles after continuous ingestion. AEC Symp Ser 25:277–284.
Pool RR, Williams JR, Goldman M, . 1973a. Comparison of bone-tumor sites in beagles continually fed ^90^Sr or injected with ^226^Ra as a means of scaling risk to humans. AEC Symp Ser 29:475–486.
*Pool RR, Williams R, Goldman M. 1973b. Induction of tumors involving bone in beagles fed toxic levels of strontium 90. Am J Roentgenol Radium Ther Nucl Med 18(4):900–908.
Porter VL, Marcus CS, Stahl SS. 1975. Use of solid state miniature detectors for study of alkaline earth metabolism in rat oral bone. Int J Nucl Med Biol 2:5–12.1109376
*Porzig H. 1973. Calcium-calcium and calcium-strontium exchange across the membrane of human red cell ghosts. J Membr Biol 11:21–46.4705662
Pott F. 1994. Asbestos use and carcinogenicity in Germany and a comparison with animal studies. Ann Occup Hyg 38(4):589–600.7978982
*Prange A, Böddeker H, Michaelis W. 1989. Multi-element determination of trace elements in whole blood and blood serum by TXRF. Fresenius Z Anal Chem 335:914–918.
Puhakainen M, Riekkinen I, Heikkinen T, . 2001. Effect of chemical pollution on forms of ^137^Cs, ^90^Sr and ^239,240^Pu in Arctic soul studied by sequential extraction. J Environ Radioact 52:17–29.11202683
*Pujol Li, Sanchez-Cabeza JA. 2000. Natural and artifical radioactivity in surface waters of the Ebro River basin (Northeast Spain). J Environ Radioact 51:181–210.
Qian G, Wu MB, Wu G, . 1998. Strontium ion-selective electrodes based on the diamides with pyridine ring as ionophores. Talanta 47:1149–1155.18967420
*Que Hee SS, Finelli VN, Fricke FL, . 1982. Metal content of stack emissions, coal and fly ash from some eastern and western power plants in the U.S.A. as obtained by ICP-AES. Int J Environ Anal Chem 13:1–18.
Que Hee SS, Igwe OJ, Boyle JR. 1988. Elemental alterations during the exposure of 1,2-dichloroethane (EDC), disulfiram (DSF), and EDC-DSF to male sprague-dawley rats. Biol Trace Elem Res 18:9–28.2484573
Raabe OG, Parks NJ. 1993. Skeletal uptake and lifetime retention of ^90^Sr and ^226^Ra in beagle dogs. Radiat Res 133:204–218.8438062
*Raabe OG, Book SA, Parks NJ, . 1981a. Lifetime studies of ^226^Ra and ^90^Sr toxicity in beagles -- A statis report. Radiat Res 86:515–528.7244126
*Raabe OG, Book SA, Parks NJ. 1983. Lifetime bone cancer dose-response relationships in beagles and people from skeletal burdens of ^226^Ra and ^90^Sr. Health Phys 44(Suppl. 1):33–48.6862910
*Raabe OG, Culbertson MR, White RG, . 1994. Comparative toxicity of strontium-90 and radium-226 in beagle dogs. U.S. Department of Energy. Davis, CA: University of California. DOE DE-FG03-89ER60914/92. NTIS/DE94006408.
*Raabe OG, Parks NJ, Book SA. 1981b. Dose-response relationships for bone tumors in beagles exposed to ^226^Ra and ^90^Sr. Health Phys 40:863–880.7251361
*Ragan HA, Hackett PL, McClanahan BJ, . 1973. Pathologic effects of chronic ^90^Sr ingestion in miniature swine. In: Harrison LT, ed. Research animals in medicine, [National conference on research animals in medicine], Washington, D.C. Jan. 28-30, 1972. Washington, DC: U.S.Department of Health, Education, and Welfare, 919–929.
Ragna HA, Buschbom RL, Clarke WL, . 1972. Late effects of chronic ^90^Sr ingestion in miniature swine. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59^th^ ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 145–154.
*Randall K, Coggle JE. 1995. Expression of transforming growth factor-β1 in mouse skin during the acute phase of radiation damage. Int J Radiat Biol 68(3):301–309.7561390
*Randall K, Coggle JE. 1996. Long-term expression of transforming growth factor TGFβ1 in mouse skin after localized β-irradiation. Int J Radiat Biol 70(3):351–360.8800206
*Rasgado-Flores H, Sanchez-Armass S, Blaustein MP, . 1987. Strontium, barium, and manganese metabolism in isolated presynaptic nerve terminals. Am J Physiol 252(21):C604–C610.3591930
Rashed MN, Awadallah RM. 1998. Trace elements in faba bean (Vicia faba L) plant and soil as determined by atomic absorption spectroscopy and ion selective electrode. J Sci Food Agric 77:18–24.
Ravaglia G, Forti P, Maioli F, . 1994. Calcium regulating hormones in healthy elderly men: Relation to intestinal calcium absorption. Boll Soc Ital Biol Sper 70(12):323–328.7748532
*Raven KP, Loeppert RH. 1997. Heavy metals in the environment: Trace element composition of fertilizers and soil amendments. J Environ Qual. 26:551–557.
*Ray RD, Stedman DE, Wolff NK. 1956. Bone Metabolism: III. The effect of various diets on the mobilization of strontium from the rat skeleton. J Bone Jt Surg Am 38A:637–654.
*Reddi OS. 1971. Long term genetic effects of strontium-90 in mice. Indian J Med Res 59(11):1754–1757.5143166
Reeve J, Arlot ME, Chavassieux PM, . 1987. The assessment of bone formation and bone resorption in osteoporosis: A comparison between tetracycline-based iliac histomorphometry and whole body ^85^Sr kinetics. J Bone Miner Res 2(6):479–489.3455632
Reeve J, Wootton R, Edouard C, . 1988. Skeletal blood flow, iliac histomorphometry, and strontium kinetics in osteoporosis: A relationship between blood flow and corrected apposition rate. J Clin Endocrinol Metab 66(5):1124–1131.3372678
*Reginster JY, Deroisy R, Dougados M, . 2002. Prevention of early postmenopausal bone loss by strontium ranelate: the randomized, two-year, double-masked, dose-ranging, placebo-controlled PREVOS trial. Osteoporosis Int 13:925–931.
*Reginster JY. 2002. Strontium ranelate in osteoporosis. Curr Pharmaceut Design 8(21):1917–1928. [Abstract]
*Reginster JY. 2003. Strontium ranelate—a new paradigm in the treatment of osteoporosis. Bus Briefing: Eur Pharmacother 2003. http://www.bbriefing.com/pdf/26/ept032_r_25_reginster.pdf.
*Reid IR, Pybus J, Lim TMT, . 1986. The assessment of intestinal calcium absorption using stable strontium. Calcif Tissue Int 38:303–305.3087605
*Reif AE, Triest WE. 1982. Effects of strontium-90 plus external irradiation in C57Bl/6J mice. Health Phys 43(6):891–904.6759466
*Reinholt FP, Engfeldt B, Heinegard D, . 1985. Proteoglycans and glycosaminoglycans of normal and strontium rachitic epiphyseal cartilage. Coll Relat Res 5:41–53.3919994
*Reinholt FP, Hjerpe A, Jansson K, . 1984. Stereological studies on the epiphyseal growth plate in strontium-induced rickets. J Bone Jt Surg Am 66-A(8):1274–1280.
Remagen W, Heitz P, Weidmann D, . 1975. Comparative kinetics of 45 Ca and 89 Sr in chronic uremic syndrome in the rat. Res Exp Med 165:271–284.
*Richard S, Potreau D, Charnet P, . 1989. Are Ba2+ and Sr2+ ions transported by the Na+-Ca2+ exchanger in frog atrial cells? J Mol Cell Cardiol 21:865–875.2810376
Risica S, Grisanti G, Tancredi F, . 1994. A study on some stable elements and radionuclides in human milk. Models Chem 131(5):651–660.
Robillard J, Loyau G, Couette JE, . 1972. A study of retention of strontium-85 by a method of integration of profile scan: Variations in miscellaneous bony diseases. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 357–368.
Romanov SA, Vasilenko EK, Khokhyankov VF, . 2002. Studies on the Mayak nuclear workers: Dosimetry. Radiat Environ Biophys 41(1):23–28.12014403
Romanyukha AA, Mitch MG, Lin Z, . 2002. Mapping the distribution of ^90^Sr in teeth with a photosimulable phosphor imaging detector. Radiat Res 157:341–349.11839097
Romanyukha AA, Seltzer SM, Desrosiers M, . 2001. Correction factors in the EPR dose reconstruction for residents of the middle and lower techa riverside. Health Phys 81(5):554–566.11669209
*Rönnbäck C. 1979. Effect of ^90^Sr on ovaries of foetal mice depending on time for administration during pregnancy. Acta Radiol Oncol 18:225–234.
*Rönnbäck C. 1980. Effect of different ^90^Sr doses on the microscopic structure of foetal mouse ovaries. Acta Radiol Oncol 19(2):145–152.6254336
*Rönnbäck C. 1981a. Disturbances of fertility in female mice ^90^Sr-contaminated as foetuses. Acta Radiol Oncol 20(5):337–343.6278855
*Rönnbäck C. 1981b. Influence of ^90^Sr-contaminated milk on the ovaries of foetal and young mice. Acta Radiol Oncol 20(2):131–135.6270965
*Rönnbäck C. 1986. Strontium retention in mouse foetuses at different intervals after contamination of the dam. Acta Radiol Oncol 25(2):155–159.3012961
Rönnbäck C, Nilsson A. 1975. Influence of estrogen on the excretion of strontium-90 and -85 in mice. Acta Radiol Ther Phys Biol 14(5):85–96.
*Rönnbäck C, Nilsson A. 1982. Neoplasms in ovaries of CBA mice ^90^Sr-treated as foetuses. Acta Radiol Oncol 21(2):121–128.6289612
*Rönnbäck C, Nelson A, Nilsson A. 1968. Influence of laktation on retention of radiostrontium in mice. Acta Radiol Ther Phys Biol 7(5):330–336.5753827
Roomans GM, Theuvenet APR, Van Den Berg PR. 1979. Kinetics of Ca^2+^ and Sr^2+^ uptake by yeast effects of pH, cations and phosphate. Biochim Biophys Acta 551:187–196.34435
Root AW, Bongiovanni AM, Eberlein WR, . 1966. Measurement of the kinetics of calcium metabolism in children and adolescents utilizing nonradioactive strontium. J Clin Endocrinol 26:537–544.
Rosenthal HL, Cochran OA. 1972. Binding of ^85^Sr to homogenate and subcellular fractions of rabbit tissues. Proc Soc Exp Biol Med 141(3):850–856.4645771
Rosenthal HL, Harbor NC. 1965. The absorption, retention, and distribution of strontium 90 from naturally contaminated food by female rabbits. J Dent Res 44(5):935–939.5213025
Rosenthal HL, Austin SA, Gilster JE, . 1967. Accumulation of strontium-90 into human fetal teeth and bone. Proc Soc Exp Biol Med 125(2):493–495.6071742
Rosenthal HL, Cochran OA, Eves MM. 1972. Strontium content of mammalian bone, diet and excreta. Environ Res 5:182–191.4624810
Rosner G, Hötzl H, Winkler R. 1990. Simultaneous radiochemical determination of plutonium, strontium, uranium, and iron nuclides and application to atmospheric deposition and aerosol samples. Fresenius J Anal Chem 338:606–609.
*Rossipal E, Krachler M, Li F, . 2000. Investigation of transport of trace elements across barriers in humans: studies of placental and mammary transfer. Acta Paediatr Suppl 89:1190–1195.11083374
Roth P, Giussani A, Werner E. 1998. Kinetics of gastrointestinal absorption. Radiat Prot Dosim 79(1–4):279–282.
*Roushdy HM, Moloukhia MK, Abdel-Fattah AT. 1980. Inhibition of radiostrontium deposition in calcium-deficient mammalian bones using certain chemical treatment. Isot Radiat Res 12(2):93–101.
*Roushdy HM, Moloukhia MK, Abdel-Fattah AT. 1981. Effect of dietary calcium level on the rate of deposition of radiostrontium in rat bones. Isot Radiat Res 13(1):19–26.
*Roy M, Becquemin H-H, Bertholon J-F, . 1994. Respiratory physiology. In: Human respiratory tract model for radiological protection. ICRP Publication 66. International Commission on Radiological Protection. Oxford: Pergamon Press, 167–201.
Rozing J, Buuraman WA, Benner R. 1976. B lymphocyte differentiation in lethally irradiated and reconstituted mice. Cell Immunol 24:79–89.1084785
Rumpel E, Behrends JC. 1999. Sr^2+^-dependent asynchronous evoked transmission at rat striatal inhibitory synapses in vitro. J Physiol 514(2):447–458.9852326
*Rundo J, Lillegraven AL. 1966. Uptake and retention of radioactive strontium in normal subjects. Br J Radiol 39:676–685.5950728
*Rundo J, Williams K. 1961. A case of accidental inhalation of ^90^SrCO_3_. Br J Radiol 34(407):734–740.14495286
*Rushton MA. 1963. Oral effects of injected strontium 90. J Dent Res 42(1):340–342.
Rutherford PM, Dudas MJ, Arocena JM. 1996. Heterogeneous distribution of radionuclides, barium and strontium in phosphogypsum by-product. Sci Total Environ 180:201–209.
*Sahai N, Carroll SA, Roberts S, . 2000. X-ray absorption spectroscopy of strontium(II) coordination: II. Sorption and precipitation at kaolinite, amorphous silica, and goethite surfaces. J Colloid Interface Sci 222:198–212.10662515
*Sairanen S, Karkkainen M, Tahtela R, . 2000. Bone mass and markers of bone and calcium metabolism in postmenopausal women treated with 1,25-dihydroxyviuamin D (calcitrol) for four years. Calcif Tissue Int 67:122–127.10920216
*Sala E, Olsen JH. 1993. Thyroid cancer in the age group 0-19: Time trends and temporal changes in radioactive fallout. Eur J Cancer 29A(10):1443–1445.8398273
*Samachson J. 1966. The gastrointestinal clearance of strontium-85 and calcium-45 in man. Radiat Res 27:64–74.
Samachson J, Schmitz A. 1969. The effects of Zn^2+^ on the uptake of Ca^2+^, Sr^2+^ and Ba^2+^ by bone powder and inorganic bone. Biochim Biophys Acta 192:238–242.5392507
Samachson J, Dennis J, Fowler R. 1968. Uptake of calcium, strontium, and barium by the surfaces of bone powder and bone mineral. J Dent Res 47(1):121–126.5237414
Sanchez AL, Singleton DL. 1996. A radioanalytical scheme for determining transuranic nuclides and ^90^Sr in environmental samples. J Radioanal Nucl Chem 209(1):41–50.
Santoliquido PM, Southwick HW, Olwin JH. 1976. Trace metal levels in cancer of the breast. Surg Gynecol Obstet 142:65–70.1244691
Sariego Muniz C, Marchante-Gayón JM, García Alonso JI, . 1999. Multi-elemental trace analysis of human serum by double-focusing ICP-MS. J Anal Atom Spectrom 14:193–198.
*Sato N, Kato T, Suzuki N. 1977. Multi-elemental determination in tobacco leaver by photon activation analysis. J Radioanal Chem 36:221–238.
*Sawyer RT, Strausbauh PH, Volkman A. 1982. Resident macrophage proliferation in mice depleted of blood monocytes by strontium-89. Lab Invest 46(2):165–170.6174824
*Scarpitta S, Odin-McCabe J, Gaschott R, . 1999. Comparison of four ^90^Sr groundwater analytical methods. Health Phys 76(6):644–656.10334581
Scasnar V. 1984. Determination of strontium-90 in urine by extraction without ashing. Anal Chem 56:605–608.6711826
Schardein JL. 1993. Metals. In: Chemically induced birth defects. New York: Marcel Dekker, Inc., 722–750.
Schell WR, Sugai S. 1980. Radionuclides at the U.S. radioactive waste disposal site near the Farallon Islands. Health Phys 39:475–496.7440160
*Schmahl W, Kollmer WE. 1981. Radiation-induced meningeal and pituitary tumors in the rat after prenatal application of strontium-90. J Cancer Res Clin Oncol 100:13–18.7240343
*Schmahl W, Kollmer WE, Berg D, . 1979. Postnatal effects on Wistar rat pituitary morphology and function after application of strontium-90 on day 18 of pregnancy. Biological Implications of Radionuclides Released from Nuclear Industries. Proceeding of an International Symposium on Biological Implications 1:329–337.
*Schoenberg HP. 1963. Extent of strontium substitution for calcium in hydroxyapatite. Biochim Biophys Acta 75:96–103.14060136
Schoeters GER, de Saint-Georges L, Van Den Heuvel R, . 1988. Mineralization of adult mouse bone marrow in vitro. Cell Tissue Kinet 21:363–374.3245957
Schroeder HA. 1971. Metals in the air. Environment 13(8):18–32.
*Schroeder HA, Tipton IH, Nason AP. 1972. Trace metals in man: Strontium and barium. J Chronic Dis 25:491–517.4647214
*Schrooten I, Cabrera W, Goodman WG, . 1998. Strontium causes osteomalacia in chronic renal failure rats. Kidney Int 54:448–456.9690211
*Schrooten I, Elseviers MM, Lamberts LV, . 1999. Increased serum strontium levels in dialysis patients: An epidemiological survey. Kidney Int 56:1886–1892.10571798
Schubert J, Brodsky A, Tyler S. 1967. The log-normal function as a stochastic model of the distribution of strontium-90 and other fission products in humans. Health Phys 13:1187–1204.6058193
*Sciuto R, Festa A, Pasqualoni R, . 2001. Metastic bone pain palliation with 89-Sr and 186-Re-HEDP in breast cancer patients. Breast Cancer Res Treat 66:101–109.11437096
*Scott BR. 1980. A model for early death caused by radiation pneumonitis and pulmonary fibrosis after inhaling insoluble radioactive particles. Bull Math Biol 42:447–459.7378613
Scott BR. 1982. Method of analysis of monotone dose-response probabilities after long-term exposure to a toxicant. Health Phys 42(3):305–315.7068392
Scuderi P, Rosse C. 1981a. The dependence of tumor neutralization on bone-marrow-derived cells. Int J Cancer 28:85–90.7309283
*Scuderi P, Rosse C. 1981b. The role of bone marrow cells in the growth inhibition of trasplanted methylcholanthrene-induced sarcoma (MCA). XIII(1):747–751.
Seaman WE, Blackman MA, Greenspan JS, . 1980. Effect of ^89^Sr on immunity and autoimmunity in NZB/NZW F_1_ mice. J Immunol 124(2):812–818.6985937
Season EH, Eyring EJ, Samuels LD. 1972. Uptake of ^87m^Sr in the knee region of children as a parameter of bone turnover. Clin Orthop Relat Res 87:281–286.5078039
Seifert MF, Marks SC. 1985. The regulation of hemopoiesis in the spleen. Experientia 41:192–199.3972067
Seltzer SM, Romanyukha AA, Nagy V. 2001. Monte Carlo calculation of the dose distribution in teeth due to internal exposure from 90Sr application to EPR tooth dosimetry. Radiat Prot Dosim 93(3):245–260.
Semb H. 1966. Plasma clearance of Sr^85^ by bone: An attempt to study the rate of blood flow through normal and immobilized bone in dogs. Acta Soc Med Ups 71(5):227–236.5965477
Semb H. 1968. Effect of immobilization on bone blood flow estimated by initial uptake of radioactive strontium. Surg Gynecol Obstet 127(2):275–281.5662847
Sherman EJ, Pfister DG, Ruchlin HS, . 2001. The collection of indirect and nonmedical direct costs (COIN) form. Cancer 91(4):841–853.11241254
*Setchell BP, Waites GMH. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society.
*Shagina NB, Kozheurov VP, Degteva MO, . 2000. Study of ^90^Sr body-burden variability for the population of the Urals region. Prague, Czech Republic: Fifth International Symposium and Exhibition of Environmental Contamination in Central and Eastern Europe, 12-14 September.
*Shaw RF, Smith AP. 1970. Strontium-90 and infant mortality in Canada. Nature 228:667–669.5474939
Shibata S, Yamashita Y. 2001. An ultrastuctural study of osteoclasts and chondroclasts in poorly calcified mandible induced by high doses of strontium diet to fetal mice. Ann Anatomie Pathol 183(4):357–361.
Shibata Y, Bautista AP, Pennington SN, . 1987. Eicosanoid production by peritoneal and splenic macrophages in mice depleted of bone marrow by ^89^Sr. Am J Physiol 127:75–82.
*Shibata Y, Dempsey WL, Morahan PS, . 1985. Selectively eliminated blood monocytes and splenic suppressor macrophages in mice depleted of bone marrow by strontium-89. J Leukoc Biol 38:659–669.3864908
Shimmins J, Smith DA. 1966. Estimation of bone mineral transfer rate by the measurement of long-term retention of SR^85^. Metabolism 15(5):436–443.5931379
Shimmins J, Smith DA. 1972. Discrimination between calcium and strontium in bone uptake and loss. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59^th^ ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 389–396.
Shine KI, Douglas AM, Ricchiuti NV. 1978. Calcium, strontium, and barium movements during ischemia and reperfusion in rabbit ventricle. Circ Res 43(5):712–720.709738
Shishkina EA, Lyubashevskii NM, Tolstykh EI, . 2001. A mathematical model for calculation of ^90^Sr absorbed dose in dental tissues: elaboration and comparison to EPR measurement. Appl Radiat Isot 55(3):363–374.11515661
*Shorr E, Carter AC. 1952. The usefulness of strontium as an adjuvant to calcium in the remineralization of the skeleton in man. Bull Hosp Joint Dis 13(1):59–66.14935450
Shutov VN, Bruk GY, Balonov MI, . 1993. Cesium and strontium radionuclide migration in the agricultural ecosystem and estimation of internal doses to the population. In: Merwin SE, Balonov MI, eds. The Chernobyl papers: Doses to the Soviet population and early health effects studies. Richland, WA: Research Enterprises, Inc, Vol. I, 167–219.
Shvedov VL, Panteleev LI, Goloschapov PV. 1972. An evaluation of the danger of impairment to the human body from a constant intake of ^90^Sr. In: International Conference on Strontium Metabolism, ed. Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59^th^ ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 173–180.
*Sigma-Aldrich. 2000. Strontium fluoride - material safety data sheet. Product number 01155. http://www.sigma-aldrich.com/sacatalog.nsf/productlookup/Riedel-de+Haen01155?OpenDocument.
Sikov MR. 1989. Tumour development following internal exposures to radionuclides during the perinatal period. In: Napalkov NP, Rice JM, Tomatis L, ., eds. Perinatal and multigeneration carcinogenisis. Lyon, France. International Agency for Research on Cancer, 403–419.
Sikov MR, Meznarich HK, Thrall KD, . 1993. Use of data from experimental animals for dosimetry of radionuclides in the human embryo/fetus. Teratology 47(5):436.
*Sikov MR, Meznarich HK, Traub RJ. 1991. Comparison of placental transfer and localization of caesium strontium and iodine in experimental animals and women. Int J Radiat Biol 60(3):553–555.1679097
*Silberstein T, Hallak M, Gonen R, . 2001. Toxic trace elements (TE) can be found in the maternal and fetal compartments. Am J Obstet Gynecol 184(1):S177.
Silva AJ, Fleshman DG, Shore B. 1970. The effects of sodium alginate on the absorption and retention of several divalent cations. Health Phys 19:245–251.4998198
Simmonds JR, Failla P. 1966. Strontium retention in mice treated with thyroid hormone. Health Phys 12:1249–1257.5970977
Simmonds JR, Linsley GS. 1982. Parameters for modelling the interception and retention of deposits from atmosphere by grain and leafy vegetables. Health Phys 43(5):679–691.7152930
Simpson LL. 1973. The interaction between divalent cations and botulinum toxin type A in the paralysis of the rat phrenic nerve-hemidiaphragm preparation. Neuropharmacology 12(2):165–176.4362622
Sims NA, White CP, Sunn KL, . 1997. Human and murine osteocalcin gene expression: Conserved tissue restricted expression and divergent responses to 1,25-dihydroxyvitamin D_3_ in vivo. Mol Endocrinol 11:1695–1797.9328351
*Sips AJAM, Barto R, Netelenbos JC, . 1997. Preclinical screening of the applicability of strontium as a marker for intestinal calcium absorption. Am J Physiol 272(PE):422–428.
*Sips AJAM, Netelenbos JC, Barto R, . 1994. One-hour test for estimating intestinal absorption of calcium by using stable strontium as a marker. Clin Chem 40(2):257–259.8313602
*Sips AJAM, van der Vijgh WJF, Barto R, . 1996. Intestinal absorption of strontium chloride in healthy volunteers: Pharmacokinetics and reproducibility. Br J Clin Pharmacol 41:543–549.8799520
*Sips AJAM, van der Vijgh WJF, Netelenbos JC. 1995. Intestinal strontium absorption: From bioavailability to validation of a simple test representative for intestinal calcium absorption. Clin Chem 41(10):1446–1450.7586515
*Skoryna SC. 1981a. Effects of oral supplementation with stable strontium. Can Med Assoc J 125:703–712.6120036
*Skoryna SC. 1981b. Handbook of stable strontium. New York, NY: Plenum Press.
*Skoryna SC. 1984. Metabolic aspects of the pharmacologic use of trace elements in human subjects with specific reference to stable strontium. Trace Subst Env Health 18:3–20.
Skoryna SC, Hong KC, Tanaka Y, . 1972. Inhibition of radiostrontium absorption by chemically and enzymatically degraded products of alginates. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59^th^ ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 297–308.
*Skoryna SC, Pivon RJ, Hakim TS, . 1986. Hemodynamic effects of stable strontium in dogs. Trace Subst Environ Health 20:17–28.
Small TD, Warren LA, Roden EE, . 1999. Sorption of strontium by bacteria, Fe(III) oxide, and bacteria - Fe(III) oxide compounds. Environ Sci Technol 33:4465–4470.
Smith DA, Aitken JM, Anderson J, . 1972. The skeletal uptake of ^85^Sr in relation to age and bone loss in women. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59^th^ ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 413–436.
Smith DA, Speirs CF, Shimmins J. 1967. The long-term skeletal retention and recirculation of ^85^Sr in man. Calcif Tissue Res 1:144–152.6060151
*Snipes MB, Boecker BB, Hahn FF, . 1974a. Toxicity of inhaled ^90^Sr fused clay particles in beagle dogs, V. In: Annual reports of the Inhalation Toxicology Research Institute. Albuquerque, NM: Inhalation Toxicology Research Institute, 126–129.
*Snipes MB, Boecker BB, Hahn FF, . 1976. Toxicity of inhaled ^90^Sr fused aluminosilicate particles in beagle dogs, VII. In: Annual reports of the Inhalation Toxicology Research Institute. Albuquerque, NM: Inhalation Toxicology Research Institute, 195–199.
*Snipes MB, Hahn FF, Muggenburg BA, . 1977. Toxicity of inhaled ^90^Sr fused aluminosilicate particles in beagle dogs, VIII. In: Annual reports of the Inhalation Toxicology Research Institute. Albuquerque, NM: Inhalation Toxicology Research Institute, 195–199.
*Snipes MB, Hahn FF, Muggenburg BA, . 1978. Toxicity of ^90^Sr inhaled in a relatively insoluble form by beagle dogs. IX. In: McClellan RO, ed. Annual report of the inhalation toxicology research institute. Albuquerque, NM: Lovelace Biomedical and Environmental Research Institute, 108–112.
*Snipes MB, Hahn FF, Muggenburg BA, . 1979. Toxicity of ^90^Sr inhaled in a relatively insoluble form by beagle dogs, X. In: Annual reports of the Inhalation Toxicology Research Institute. Albuquerque, NM: Inhalation Toxicology Research Institute, 101–106.
*Snipes MB, Runkle GE, Hulbert AJ. 1974b. Absorbed dose distribution patterns in the beagle thorax after inhalation of ^90^Sr-^90^Y fused clay particles, II. In: Annual reports of the Inhalation Toxicology Research Institute. Albuquerque, NM: Inhalation Toxicology Research Institute, 65–68.
*Snyder WS, Cook MJ, Ford MR. 1964. Estimates of (MPC)_w_ for occupational exposure to Sr^90^, Sr^89^ and Sr^85^. Health Phys 10:171–182.14126791
*Sokolik GA, Ivanova TG, Leinova SL, . 2001. Migration ability of radionuclides in soil-vegetation cover of Belarus after Chernobyl accident. Environ Int 26:183–187.11341704
Somlyo AV, Somlyo AP. 1971. Strontium accumulation by sarcoplasmic reticulum and mitochondria in vascular smooth muscle. Science 174:955–958.5123814
*Song CW, Drescher JJ, Tabachnick J. 1968. Effect of anti-inflammatory compounds on beta-irradiation-induced increase in vascular permeability. Radiat Res 34:616–625.5654012
Spalding BP, Spalding IR. 2001. Chemical equilibria of strontium adsorption and transport in soil response to dynamic conditions. Environ Sci Technol 35:365–373.11347611
Spencer CI, Berlin JR. 1997. Calcium-induced release of strontium ions from the sarcoplasmic reticulum of rat cardiac ventricular myocytes. J Phys 504(3):565–578.
Spencer H, Kramer L, Hardy EP. 1977. Effect of phosphorus on the ^90^Sr balance in man. Health Phys 33:417–423.591319
*Spencer H, Kramer L, Norris C, . 1972a. Certain aspects of radiostrontium metabolism in man. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 335–346.
Spencer H, Kramer L, Samachson J, . 1973a. Strontium-90 calcium interrelationships in man. Health Phys 24:525–533.4707667
*Spencer H, Lewin I, Belcher MJ, . 1969a. Inhibition of radiostrontium absorption by aluminum phosphate gel in man and its comparative effect on radiocalcium absorption. Int J Appl Radiat Isot 20:507–516.5803136
*Spencer H, Lewin I, Samachson J, . 1969b. Effect of aluminum phosphate gel on radiostrontium absorption in man. Radiat Res 38:307–320.5771799
*Spencer H, Lewin I, Samachson J. 1967a. Effect of magnesium on radiostrontium excretion in man. Int J Appl Radiat Isot 18:407–415.6036059
Spencer H, Lewin I, Samachson J. 1967b. Inhibition of radiostrontium absorption in man. Int J Appl Radiat Isot 18:779–782.6056784
*Spencer H, Li M, Samachson J, . 1960. Metabolism of strontoum^85^ and calcium^45^ in man. Metabolism 9:916.
Spencer H, Menczel J, Samachson J. 1967c. Effect of mercuhydrin alone and in conjunction with ammonium chloride on radiostrontium excretion in man. Proc Soc Exp Biol Med 124(4):1110–1116.6024819
*Spencer H, Samachson J, Hardy EP, . 1967d. Effect of low and high calcium intake on Sr^90^ metabolism in adult man. Int J Appl Radiat Isot 18:605–614.6055301
Spencer H, Samachson J, Hardy EP, . 1967e. Effect of stable calcium on strontium-90 absorption in man. J Nucl Med 5(5):398–399.
Spencer H, Samachson J, Hardy EP, . 1968. Some aspects of the effects of age and of calcium intake on strontium-90 metabolism in man. Health Phys 15:499–504.5688317
Spencer H, Samachson J, Hardy EP, . 1972b. Effect of orally and intravenously administered stable strontium on ^90^Sr metabolism in man. Radiat Res 51:190–203.4556670
Spencer H, Warren JM, Kramer L, . 1973b. Passage of calcium and strontium across the intestine in man. Clin Orthop Relat Res 91:225–234.
Spiers FW. 1966. Dose to bone from strontium-90: Implications for the setting of the maximum permissible body burden. Radiat Res 28:624–642.5938767
Spiers FW. 1974. Radionuclides and bone - from 226Ra to ^90^Sr. Br J Radiol 47:833–844.4434053
Spiers FW, Whitwell JR. 1972. Theoretical comparisons of dosage from ^90^Sr and ^226^Ra in human and beagle bone. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59^th^ ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 1–16.
Spreng P. 1967. Effect of parathyroid hormone and vitamin A on the retention of radiostrontium in the rat. Nature 214:513–514.6032889
*Srivastava PK, Srivastava VK, Nisra UK. 1984a. Translocation of intratracheally administered ^89^Sr enriched fly ash into extrapulmonary organs in rats. J Environ Sci Health Part A 19(8):925–941.
*Srivastava VK, Chauhan SS, Srivastava PK, . 1990. Placental transfer of metals of coal fly ash into various fetal organs of rat. Arch Toxicol 64:153–156.2350235
*Srivastava VK, Sengupta S, Kumar R, . 1984b. Distribution of metals of inhaled fly ash in various organs of rats at various periods after exposure. J Environ Sci Health Part A 19(6):663–677.
*Stanic M, Gruden N. 1974. Calcium and strontium transfer through the intestinal wall in 6- and 26-week old rats. Arh Hig Rada Toksikol 25(4):423–426.4462501
Stara JF, Nelson NS, Della Rosa RJ, . 1971. Comparative metabolism of radionuclides in mammals: A review. Health Phys 20:113–137.4996328
*Stather JW. 1972. Distribution studies on ^32^P, ^45^Ca, ^85^Sr and ^133^Ba in the mouse. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 111–123.
Stather JW, Harrison JD, Kendall GM. 1992. Radiation doses to the embryo and fetus following intakes of radionuclides by the mother. Radiat Prot Dosim 41(2/4):111–118.
Steffens W, Führ F, Mittelstaedt W. 1980a. Evaluation of small scale laboratory and pot experiments to determine the realistic transfer factors for the radionuclides ^90^Sr, ^137^Cs, ^60^Co and ^54^Mn. In: Radiation protection: A systemic approach to safety: Proceedings of the 5th congress of the International Radiation Protection Society, Jerusalem, March 1980. New York, NY: Pergamon Press, Vol. 2, 1135–1138.
Steffens W, Mittelstaedt W, Führ F. 1980b. The transfer of Sr-90, Cs-137, Co-60 and Mn-54 from soils to plants results from Lysimeter experiments. In: Radiation protection: A systemic approach to safety: Proceedings of the 5th congress of the International Radiation Protection Society, Jerusalem, March 1980. New York, NY: Pergamon Press, Vol. 2, 1139–1142.
*Steinbach I. 1968. Wirksamkeit von weiblichen Geschlechtshormonen und P-armer und Ca-reicher Diät auf die ^90^Sr-Dekorporation. Z Naturforsch B 23:820–824.4386581
Stevenson AFG. 1975. The influence of age and sex on the activity ratio of yttrium-90 to strontium-90 in the rat skeleton after incorporation of strontium-90. Health Phys 29:285–290.1193840
Stevenson AFG. 1977. Endocrine influences on the activity ration of ^90^Y to ^90^Sr in the rat skeleton after incorporation of ^90^Sr. Acta Radiol Ther Phys Biol 16(2):137–144.868580
Stevenson AFG, Daculsi R, Mönig H. 1982. Haematological studies on ^90^Sr-^90^Y-toxicity: II. Femoral CFU-s kinetics and mitogen response of spleen cells. Radiat Environ Biophys 20:275–287.7146319
Stössel R-P, Prange A. 1985. Determination of trace elements in rainwater by total-reflection x-ray fluorescence. Anal Chem 57:2880–2885.
*Storey E. 1961. Strontium “rickets”: Bone, calcium and strontium changes. Austral Ann Med 10:213–222.
*Storey E. 1962. Intermittent bone changes and multiple cartilage defects in chronic strontium rickets in rats. J Bone Jt Surg Am 44B(1):194–208.
Storey E. 1968. Calcium and strontium changes in bone associated with continuous administration of stable strontium to rats. Arch Biochem Biophys 103:575–581.
*Storm DL. 1994. Chemical monitoring of California’s public drinking water sources: Public exposures and health impacts. In: Wang RGM, ed. Water contamination and health: Integration of exposure assessment, toxicology, and risk assessment. New York, NY: Marcel Dekker, Inc., 67–124.
Strain WH, Pories WJ, Flynn A. 1972. Accumulation of radiostrontium in hair. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 247–254.
Strong AB, Porter CR, Kahn B. 1972. Stable strontium: Calcium ratios in U.S. bone and total diet samples. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory / U.S. Atomic Energy Commission, 513–520.
Stulc J, Stulcova B, Svihovec J. 1990. Transport of calcium across the dually perfused placenta of the rat. J Physiol 420:295–311.2324986
Sugihira N, Kusama T. 1992. Biokinetics of radionuclides in pregnant mice and compartment models by the system analysis methods. Radiat Prot Dosim 41(2/4):153–156.
Sugihira N, Suzuki KT. 1991. Discrimination between strontium and calcium in suckling rats. Biol Trace Elem Res 29:1–10.1711357
*Sugihira N, Aoki Y, Suzuki KT. 1992. ATP-dependent strontium uptake by basolateral membrane vesicles from rat renal cortes in the absence of presence of calcium. Biol Trace Elem Res 34:45–54.1382521
Sugihira N, Kobayashi E, Suzuki KT. 1990. Age-related change in strontium to calcium ratios in rat tissues. Biol Trace Elem Res 25:79–88.1696115
Sumerling TJ, Dodd NJ, Green N. 1984. The transfer of strontium-90 and caesium-137 to milk in a dairy herd grazing near a major nuclear installation. Sci Total Environ 34:57–72.6710139
Sundelin P, Nilsson A. 1968. Cytoplasmic ultraviolet extinction of strontium-90-induced fibroblastic osteosarcomas correlated to histologic appearance and ultrastructure. Acta Radiol 7:161–170.
Sures B, Steiner W, Rydlo M, . 1999. Concentrations of 17 elements on the zebra mussel (Dreissena polymorphia), in different tissues of perch (Perca fluviatilis), and in perch intestinal parasites (Acanthocephalus lucii) from the subalpine Lake Mondsee, Austria. Environ Toxicol Chem 18(11):2574–2579.
*Sutherland BM, Bennett PV, Sidorkina O . 2000a. Clustered DNA damages induced in isolated DNA and in human cells by low doses of ionizing radiation. Proc Natl Acad Sci 97:103–108.10618378
*Sutherland BM, Bennett PV, Sidorkina O, . 2000b. Clustered damages and total lesions induced in DNA by ionizing radiation: Oxidized bases and strand breaks. Biochemistry 39:8026–8031.10891084
Sutton A. 1967. Reduction of strontium absorption in man by the addition of alginate to the diet. Nature 216:1005–1007.6072965
*Sutton A, Harrison GE, Carr TEF. 1971a. Reduction in the absorption of dietary strontium in children by an alginate derivative. Int J Radiat Biol 19(1):79–80.
*Sutton A, Shepherd H, Harrison GE, . 1971b. Excretion and retention of stable strontium in children. Nature 230:396–397.4927736
*Svensson O, Hjerpe A, Reinholt FP, . 1985. The effect of strontium and manganese on freshly isolated chondrocytes. Acta Pathol Microbiol Immunol Scand Sect A 93:115–120.4013738
*Svensson O, Reinholt FP, Engfeldt B. 1987. The parathyroid gland in metal rickets: A stereological study. Acta Pathol Microbiol Immunol Scand Sect A 95:309–314.3687434
*Sweet CW, Vermette SJ, Landsberger S. 1993. Sources of toxic trace elements in urban air in Illinois. Environ Sci Technol 27(12):2502–2510.
*Syed IB, Hosain F. 1972. Determination of LD50 of barium chloride and allied agents. Toxicol Appl Pharmacol 22:150–152.5034984
Szymendera J, Madajewicz S. 1968. Comparative ultrafiltrability of calcium and strontium in human plasma. Nature 217:968–969.5642855
Takagi K, Takayanagi I. 1968. Electrophysical experiments on the action of some partial agonists and their application to receptor theory. Nature 218:275–276.5648227
Takahashi S, Takahashi I, Sato H, . 2001. Age-related changes in the concentrations of major and trace elements in the brain of rats and mice. Biol Trace Elem Res 80(2):145–158.11437180
Talbot V, Chang W-J. 1987. Rapid multielement analysis of oyster and cockle tissue using x-ray fluorescence spectrometry, with application to reconnaissance marine pollution investigations. Sci Total Environ 66:213–223.3685949
*Tan E-L, Williams MW, Schenley RL, . 1984. The toxicity of sixteen metallic compounds in Chinese hamster ovary cells. Toxicol Appl Pharmacol 74:330–336.6429900
*Tanaka G-I, Kawamura H, Nomura E. 1981. Reference Japanese man--II: Distribution of strontium in the skeleton and in the mass of mineralized bone. Health Phys 40:601–614.7263250
Tanaka Y, Inoue S, Skoryna SC. 1970. Studies on inhibition of intestinal absorption of radioactive strontium: IX. Relationship between biological activity and electron microscopic appearance of alginic acid components. Can Med Assoc J 103(5):484–486.5469618
Tanaka Y, Skoryna SC, Waldron-Edward D. 1968a. Studies on the inhibition of intestinal absorption of radioactive strontium: VI. Alginate degradation as potent in vivo sequestering agents of radioactive strontium. Can Med Assoc J 98:1179–1182.5657184
Tanaka Y, Waldron-Edward D, Skoryna SC. 1968b. Studies on the inhibition of intestinal absorption of radioactive strontium: VII. Relationship of biological activity to chemical composition of alginates obtained from North American seaweeds. Can Med Assoc J 99:169–175.5673223
Taniyama K, Yoshida N, Takahashi N, . 1977. Actions of Ba and Sr ions on isolated rat ileum. Jpn J Pharmacol 27:327–329.886665
Tanner TM, Young JA, Cooper JA. 1974. Multielement analysis of St. Louis aerosols by nondestructive techniques. Chemosphere 3(5):211–220.
Taylor DM. 1958. Comparative aspects of the transfer of strontium and calcium from mother to offspring in rats. Br J Radiol 31:715.
*Taylor DM. 1968. The effect of L-thyroxine on the absorption of calcium and strontium. Experientia 24(8):837–838.5683188
*Taylor DM, Bligh PH. 1992. The transfer of ^45^Ca, ^85^Sr and ^140^Ba from mother to newborn in rats. Radiat Prot Dosim 41(2/4):143–145.
*Taylor GN, Christensen WR, Jee WSS, . 1966. Intercomparison of pathological fractures in beagles injected with ^226^Ra, ^228^Ra, ^239^Pu or ^90^Sr. Health Phys 12:361–367.5916795
ten Bolscher M, de Valk-de Roo G, Barto R, . 1999. Oestrogen has no short-term effect on intestinal strontium absorption in healthy postmenopausal women. Clin Endocrinol 50:387–392.
*Teree TM, Cohn SH. 1966. The determination of strontium in human serum using neutron activation analysis. J Nucl Med 7:848–858.5955364
*Teree TM, Gusmano EA, Cohn SH. 1965. Decrement in radiostrontium retention following stable strontium prefeeding in the growing rat. J Nutr 87:399–406.5841856
Testa C. 1970. Column reversed-phase partition chromatography for the isolation of some radionuclides from biological materials. Anal Chim Acta 50:447–455.5447115
Thomas RG, Thomas RL, Wright SR. 1968. Retention of cesium-137 and strontium-90 administered in lethal doses to rats. Am Ind Hyg Assoc J 29:593–600.5703681
Thomasset M. 1982. Strontium metabolism and toxicity of strontium. In: Galle P, Masse R, eds. Radionuclide Metabolism and Toxicity: Proceedings of the Symposium organized in 1982 by the Société Francaise de Biophysique et de Médecine Nucléaire and IRU-Environnement del’Université Paris-Val de Marne. Paris; Masson, 98–121.
Thorne MC, Vennart J. 1976. The toxicity of ^90^Sr, ^226^Ra and ^239^Pu. Nature 263:555–558.1068342
Thurman GB, Mays CW, Taylor GN, . 1971. Growth dynamics of beagle osteosarcomas. Growth 35:119–125.5291157
Thurman GB, Mays CW, Taylor GN, . 1973. Skeletal location of radiation-induced and naturally occurring osteosarcomas in man and dog. Cancer Res 33:1604–1607.4516008
Timmermans R, Van Hees M, Vandecasteele CH, . 1992. Transfer of radionuclides from maternal food to the fetus and nursing infants of minipigs. Radiat Prot Dosim 41(2/4):127–130.
Tinker A, Williams AJ. 1992. Divalent cation conduction in the ryanodine receptor channel of sheep cardiac muscle sarcoplasmic reticulum. J Gen Physiol 100:479–493.1279095
*Tipton IH, Cook MJ. 1963. Trace elements in human tissue: Part II: Adult subjects from the United States. Health Phys 9:103–145.13985137
*Tipton TH. 1981. Gross and elemental content of reference man. In: Snyder WS, Cook MJ, Nassett ES, . eds. New York, NY: Pergamon Press. International Commission on Radiological Protection. 273–334.
Toda M. 1972. Modification by Ca++ removal, Mg++ and Sr++ of the membrane effect and the inotropic effect of norepinephrine in rabbit left atria. J Pharmacol Exp Ther 180(3):698–709.5012788
*Togna G, Gallozzi S, Caprino L. 1989. Influence of strontium chloride on blood platelet function. Arch Toxicol Suppl 13:366–369.2505737
*Tokareva EE, Koxheurov VP, Tolstykh EI, . 2000. Analysis of in vivo measurements of ^90^Sr in human teeth and body. Prague, Czech Republic: Fifth International Symposium and Exhibition of Environmental Contamination in Central and Eastern Europe, 12-14 September.
Toledano A, Barca MA, Moradillo I, . 1988. Mitochondrial accumulation of Sr^2+^ supported by pyruvate in the cerebellar cortex of the rat. Cellular variations during aging. Acta Histochem Cytochem 21(4):365–381.
*Tolstykh EI, Degteva MO, Kozheurov VP, . 1998. Strontium transfer from maternal skeleton to the fetus estimated on the basis of the Techa river data. Radiat Prot Dosim 79(1–4):307–310.
*Tolstykh EI, Degteva MO, Vorobiova MI, . 2001. Fetal dose assessment for the offspring of the Techa riverside residents. Radiat Environ Biophys 40(4):279–286.11820736
*Tolstykh EI, Kozheurov VP, Vyushkova OV, . 1997. Analysis of strontium metabolism in humans on the basis of the Techa river data. Radiat Environ Biophys 36:25–29.9128895
*Tong ECK, Zaret MM, Rubenfeld S. 1969. Cellular changes in the conjunctiva after strontium 90 treatment for pterygium. Am J Roentgenol Radium Ther Nucl Med 106(4):848–853.
*Toran L. 1994. Radionuclide contamination in groundwater: Is there a problem? In: Groundwater contamination and control. Environmental science pollution control series 11. New York, NY: M. Dekker, 437–455.
Toran L, Bryant S, Saunders J, . 1998. A two-tiered approach to reactive transport: Application to Sr mobility under variable pH. Ground Water 36(3):404–408.
*Torres JM, Tent J, Llaurado M, . 2002. A rapid method for ^90^Sr determination in the presence of 137 Cs in environmental samples. J Environ Radioact 59:113–125.11848148
*Toshioka T, Ishida M, Oami S, . 1974. Effects of cations on the bactericidal systems of normal rabbit serum: II. Effects of calcium and strontium ions. Nihon Univ J Med 16:5–23.
*Tothill P, Smith MA, Cohn SH. 1983. Whole-body and part-body turnover of ^85^Sr in Paget’s disease. Phys Med Biol 28(2):149–159.6867104
Travnikova IG, Shutov VN, Bruk GY, . 2002. Assessment of current exposure levels in different population groups of the Kola Peninsula. J Environ Radioact 60:235–248.11936611
Triffitt JT. 1968. Binding of calcium and strontium by alginates. Nature 217:457–458.5641759
Triffitt JT, Sutton A. 1969. Strontium and calcium contents of bone density fractions. Calcif Tissue Res 4:174–179.5363272
Triffitt JT, Jones RO, Patrick G. 1972. Uptake of ^45^calcium and ^85^strontium by bone in tissue culture. Calcif Tissue Res 8:211–216.5017728
*Tsalev DL. 1984. Atomic absorption spectrometry in occupational and environmental health practice. Boca Raton, FL: CRC Press, Inc. Volume II: Determination of individual elements
Tsutsumi S, Amagai T, Kawaguchi M, . 1980. Effects of strontium chloride (SrCl_2_) on ^3^H-thymidine uptake into rat lymphocytes. Bull Tokyo Dent Coll 21(4):253–259.6938327
Turoczy NJ, Laurenson LJB, Allinson G, . 2000. Observations on metal concentrations in three species of shark (Deania Calcea, Centroscymnus crepidater, and Centroscymnus owstoni) from Southeastern Australian waters. J Agric Food Chem 48:4357–4364.10995363
Twardock AR, Austin MK. 1970. Calcium transfer in perfused guinea pig placenta. Am J Physiol 219(2):540–545.5448088
Twardock AR, Downey HF, Kirk ES, . 1969. Comparative transfer of calcium and strontium and of potassium and cesium in the guinea pig placenta. AEC Symp Ser 17:97–104.
*Twardock AR, Kuo EY-H, Austin MK, . 1971. Protein binding of calcium and strontium in guinea pig maternal and fetal blood plasma. Am J Obstet Gynecol 110(7):1008–1014.5558962
*Uchiyama M, Tanaka G, Yabumoto E. 1973. ^85^Sr retention in Japanese after a single administration. J Radiat Res 14:169–179.4732081
*U.S. Congress. 1990. Clean Air Act. Title III. Section 112. Hazardous air pollutants. One Hundred and First Congress of the United States. Public Law 101-549. 42 USC 7412. November 15, 1990.
*USNRC. 1991. Occupational dose limits. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 20, Subpart C.
*USNRC. 1993a. Radioactive materials released from nuclear power plants: Annual report 1993. Washington, DC: U.S. Nuclear Regulatory Commission. NUREG/CR-2907. BNL-NUREG-51581.
*USNRC. 1993b. Standards for protection against radiation. Annual limits on intake (ALIs) and derived air concentrations (DACs) of radionuclides for occupational exposure; effluent concentrations; concentrations for release to sewerage. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 20, Appendix B.
*USNRC. 1995. Standards for protection against radiation. Quantities of licensed material requiring labeling. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 20, Appendix C.
*USNRC. 1996. Technical specifications on effluents from nuclear power reactors. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 50.36a. 61 FR 39299. http://www.nrc.gov/NRC/CFR/PART050/part050-0036a.html. July 29, 1996
*USNRC. 1997. Radiation dose limits for individual members of the public. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 20, Subpart D.
*USNRC. 1998a. Physical protection for spent nuclear fuel and high-level radioactive waste; final rule. U.S. Nuclear Regulatory Commission. Federal Register. 63 FR 26955. May 15, 1998.
*USNRC. 1998b. Subpart O-Enforcement. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 20 Sub O.
*USNRC. 2000a. Schedule C-Quantities of radioactive materials requiring consideration of the need for an emergency plan for responding to a release. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 30.72.
*USNRC. 2000b. Use of sources for brachytherapy. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 35.400.
*USNRC. 2001a. Byproduct material. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 30.71, Sch. B. http://www.nrc.gov/NRC/CFR/PART030/part030-0071.html. March 13, 2001
*USNRC. 2001b. Byproduct material. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 33.100, Sch. A. http://www.nrc.gov/NRC/CFR/PART033/part033-0100.html. March 13, 2001
*USNRC. 2001c. General license for strontium 90 in ice detection devices. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 31.10. http://www.nrc.gov/NRC/CFR/PART031/part031-0010.html. March 13, 2001
*USNRC. 2001d. Quantities of licensed material requiring labeling. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 30, App. B. http://www.nrc.gov/NRC/CFR/PART030/part030-appb.html. March 13, 2001
*USNRC. 2001e. Quantities of licensed material requiring labeling. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 20, App. C. http://www.nrc.gov/NRC/CFR/TABLES/ISOTOPES/PART020-APPC/index.htm. March 13, 2001
*USNRC. 2001f. Quantities of radioactive materials requiring consideration of the need for an emergency plan for responding to a release. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 30.72, Sch. C. http://www.nrc.gov/NRC/CFR/PART030/part030-0072.html.
*USNRC. 2001g. Occupational values, effluent concentrations, and releases to sewers. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 20, App. B. http://www.nrc.gov/NRC/CFR/TABLES/ISOTOPES/PART020-APPB/Strontium-80.html.
*USNRC. 2001h. Quality assurance; prohibition of transfer. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 32.62. http://www.nrc.gov/NRC/CFR/PART032/part032-0062.html.
*USNRC. 2001i. Table A-1.-A_1_ and A_2_ values for radionuclides. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 71. http://www.nrc.gov/NRC/CFR/TABLES/ISOTOPES/PART071/index.html.
*USNRC. 2001j. Use of sources for brachytherapy. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 35.400. http://www.nrc.gov/NRC/CFR/PART035/part035-0400.html.
*USNRC. 2001k. Use of unsealed byproduct material for uptake, dilution, and excretion studies. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 35.100. http://www.,nrc.gov/NRC/CFR/PART035/part035-0100.html (http://www.nrc.gov/NRC/CFR/PART035/part035-0100.html).
*USNRC. 2001l. Waste classification. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 61.55. http://www.nrc.gov/NRC/CFR/PART061/part061-0055.html.
*USNRC. 2001m. Dose to an embryo/fetus. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 20.1208. http://www.nrc.gov/NRC/CFR/PART020/part020-1208.html. May 11, 2001.
*USNRC. 2001n. Occupational dose limits for adults. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 20.1201. http://www.nrc.gov/NRC/CFR/PART020/part020-1201.html. May 11, 2001.
*USNRC. 2001o. Occupational dose limits for minors. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 20.1207. http://www.nrc.gov/NRC/CFR/PART020/part020-1207.html. May 11, 2001.
*USNRC. 2001p. Physical protection for spent nuclear fuel and high-level radioactive waste. U.S. Nuclear Regulatory Commission. Federal Register. 63 FR 26955. http://frwebgate5.access.gpo.gov/. May 11, 2001.
*USNRC. 2001q. Standards for the protection against radiation. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 20.1301. http://www.nrc.gov/NRC/CFR/PART020/part020-1301.html. May 10, 2001.
*USDA. 1997. Animal and plant health inspection service, department of agriculture. Hawaiian fruits and vegetables. U.S. Department of Agriculture. Code of Federal Regulations. 7 CFR 318.
*USGS. 1963. Occurrence and distribution of strontium in natural water: Chemistry of strontium in natural water: Geological survey water-supply paper 1496-D. Washington, DC: U.S. Atomic Energy Commission. U.S. Geological Survey.
*USGS. 1980. Elements in fruits and vegetables from areas of commercial production in the conterminous United States: Geological survey professional paper 1178: A biogeochemical study of selected food plants based on field sampling of plant material and soil. Washington, DC: U.S. Department of the Interior. U.S. Geological Survey.
*USGS. 1998. Strontium. Minerals Yearbook (Volume I. Metals and Minerals). U.S. Geological Survey, VVV1–VVV4.
*USGS. 1999. Strontium. Mineral Commodity Summaries. U.S. Geological Survey. 166–167.
*USGS. 2000a. Srontium. U.S. Geological Survey. 160–161. http//:www.usgs.gov/minerals/pubs/commodity/copper/index.html (http://www.usgs.gov/minerals/pubs/commodity/copper/index.html).
*USGS. 2000b. Strontium. U.S. Geological Survey. 74.1–74.7. http//:www.usgs.gov/minerals/pubs/commodity/copper/index.html (http://www.usgs.gov/minerals/pubs/commodity/copper/index.html).
*USGS. 2002. Strontium. U.S. Geological Survey. 74.1–74.5. http//:www.usgs.gov/minerals/pubs/commodity/copper/index.html (http://www.usgs.gov/minerals/pubs/commodity/copper/index.html).
Uvelius B, Sigurdsson SB, Johansson B. 1974. Strontium and barium as substitutes for calcium on electrical and mechanical activity in rat portal vein. Blood Vessels 11:245–259.4458830
Vaca F, Manjon G, Garcia-Leon M. 2001. The presence of some artificial and natural radionulcides in a eucalyptus forest in the south of Spain. J Environ Radioact 56:309–325.11468822
Vainio H, Mela L, Chance B. 1970. Energy dependent bivalent cation translocation in rat liver mitochondria. Eur J Biochem 12:387–391.5459576
Vajda N, Ghods-Esphahani A, Cooper E, . 1992. Determination of radiostrontium in soil samples using a crown ether. J Radioanal Nucl Chem 162(2):307–323.
vam Puymbroeck S, van der Borght O. 1971. Enhancement of strontium absorption in the nitrous oxide-acetylene flame by potassium and sodium and the determination of strontium in biological material. Anal Chim Acta 57:441–446.5132424
Van Barneveld AA, Van Puymbroeck S, Vanderborght O. 1977. The action of sodium alginate in the food on a ^85^Sr body-burden in mice. Health Phys 33:533–537.604296
Vandecasteele C, Vanhoe H, Dams R, . 1990. Determination of strontium in human serum by inductively coupled plasma mass spectrometry and neutron activation analysis: A comparison. Talanta 37(8):819–823.18965026
Vanderborght O, Keslev D, Van Puymbroeck S, . 1972. Combined influence of diet, alginate, parathyroid hormone and vitamin D on ^85^Sr and ^47^Ca mobilization from bone. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 397–402.
Vanderborght OLJ, Van Puymbroeck S, Babakova I. 1978. Effect of combined alginate treatments on the distribution and excretion of an old radiostrontium contamination. Health Phys 35:255–258.701021
*Varga LP, Sztanyik LB, Ronai E, . 1994. Mobilization of radioactive strontium from mouse and rat using dicarboxylic acid derivatives of cryptand (2.2). Int J Radiat Biol 66(4):399–405.7930843
Vasington FD. 1966. Accumulation of Ca^2+^ and Sr^2+^ by rat-liver mitochondria: Preferential loss of the adenosine triphosphate-dependent mechanism for Sr^2+^ accumulation. Biochim Biophys Acta 113:414–416.4223240
*Vaughan J, Williamson M. 1969. ^90^Sr in the rabbit: The relative risks of osteosarcoma and squamous cell carcinoma. In: Mays CW, Jee WSS, Lloyd RD, . eds. Delayed effects of bone seeking radionuclides. Salt Lake City, UT: University of Utah Press, 337–355.
*Venier P, Montaldi A, Gava C, . 1985. Effects of nitrilotracetic acid on the induction of gene mutations and sister-chromatid exchanges by insoluble chromium compounds. Mutat Res 156:219–228.3889637
Verdonck F, Carmeliet E. 1971. Isometric contractions in cardiac purkyne fibres: Characteristics in Na free Sr tyrode. Cardiovasc Res (Suppl. 1):76–83.5143803
Vereecke J, Carmeliet E. 1971. Sr action potentials in cardiac purkyne fibres: II. Dependence of the Sr conductance on the external Sr concentration and Sr-Ca antagonism. Pflugers Arch 322:73–82.5099622
Versieck J, Vanballenberghe L, Wittoek A, . 1993. The determination of strontiumin human blood serum and packed blood cells by radiochemical neutron activation analysis. J Radioanal Nucl Chem 168(1):243–248.
*Vezzoli G, Baragetti I, Zerbi S, . 1998. Strontium absorption and excretion in normoclaciuric subjects: Relation to calcium metabolism. Clin Chem 44(3):586–590.9510866
Vezzoli G, Caumo A, Baragetti I, . 1999. Study of calcium metabolism in idiopathic hypercalciuria by strontium oral load test. Clin Chem 45(2):257–261.9931049
*Vezzoli G, Soldati L, Provervio MC, . 2002. Polymorphism of vitamin D receptor gene start codon in patients with calcium kidney stones. 15(2):158–164.
*Viccellio P, ed. 1998. Emergency toxicology. 2^nd^ ed. Philadelphia, PA: Lippincott-Raven, 991–996.
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
Viglione PN, Pereyra K, Reyes-Toso CF, . 1996. Extracellular acidification related to the stimulation of catecholamines release by strontium in the bovine adrenal medulla. Arch Physiol Biochem 104(7):833–837.9127678
Voight G. 1993. Chemical methods to reduce the radioactive contamination of animals and their products in agricultural ecosystems. Sci Total Environ 137:205–225.8248768
*Volf V. 1964. Effect of sulphates on the intestinal absorption of Sr-85 in rats. Experientia 20(11):626–627.5857576
Volf V. 1965. Effect of phosphates, carbonates, and magnesium oxide upon the intestinal absorption of Sr-85 in rats. Experientia 21(10):571–572.5868483
Volf V, Roth Z. 1966a. Retention of strontium 85 in rats: II. Effect of various barium sulphate preparations as influenced by soluble sulphates, carrier strontium and by the physiologic state of animals. Acta Radiol Ther Phys Biol 4:113–128.5935911
Volf V, Roth Z. 1966b. Retention of strontium 85 in rats: III. Effect of increasing the doses of sodium and barium sulphates and role of the time factor. Acta Radiol Ther Phys Biol 4:481–493.5955694
Von Zallinger C, Tempel K. 1998. Transplacental transfer of radionuclides. A review. Vet Med (Prague) A45:581–590.
Waite BA, Blauvelt SC. 1988. Oil and gas waste fluids of Pennsylvania. Northeast Environ Sci 7(2):105–110.
Wakabayashi S, Goshima K. 1981. Kinetic studies on sodium-dependent calcium uptake by myocardial cells and neuroblastoma cells in culture. Biochim Biophys Acta 642:158–172.6784764
Waldron-Edward D. 1968. Studies on the inhibition of intestinal absorption of radioactive strontium: VIII. The effect of alginate-containing diets on water metabolism. Can Med Assoc J 99:986–992.5699842
Waldron-Edward D, Paul TM, Skoryna SC. 1965a. Suppression of intestinal absorption of radioactive strontium by naturally occurring non-absorbable polyeletrolytes. Nature 205(4976):1117–1118.5833216
Waldron-Edward D, Paul TM, Skoryna SC. 1966. Effects of counter ion and pH on intestinal absorption of calcium and strontium. Proc Soc Exp Biol Med 123(2):532–538.5924499
Waldron-Edward D, Thyvalikakath PM, Skoryna SC. 1965b. Suppression of intestinal absorption of radioactive strontium by naturally occurring non-absorbable polyelectrolytes. Nature 205:1117–1118.5833216
Walinder G, Feinstein RE, Gimeno EJ. 1986. Effect of high ^131^I doses on the bone uptake and retention of ^90^Sr and ^90^Y. Acta Radiol Oncol 25:255–260.3030053
*Wang Y, Qin J, Wu S, . 1990. Study on the relation of Se, Mn, Fe, Sr, Pb, Zn, Cu, and Ca to liver cancer mortality from analysis of scalp hair. Sci Total Environ 91:191–198.2320997
*Warren JM. 1972a. Strontium-90 in diet - 1971. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 483–488.
Warren JM. 1972b. Strontium-90 in human bone 1959-70. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 521–580.
Warren JM, Spencer H. 1971. Intestinal excretion of ^85^Sr and ^47^Ca during feeding and fasting in rats. Radiat Res 48:578–588.5137466
Warren JM, Spencer H. 1972a. Analysis of stable strontium in biological materials by atomic absorption spectrophotometry. Clin Chim Acta 38:435–439.5026360
Warren JM, Spencer H. 1972b. Passage of ^85^Sr and ^47^Ca into the intestinal tract of rats. In:. Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 347–356.
Warren JM, Spencer H. 1972c. Stable strontium balances in man. In:. Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 325–334.
Warren JM, Spencer H. 1973. Passage of ^85^Sr and ^47^Ca into the gastrointestinal tract in rats during feeding and fasting. Radiat Res 56:110–121.4774909
*Warren JM, Spencer H. 1976. Metabolic balances of strontium in man. Clin Orthop Relat Res 117:307–320.
Warren JM, Spencer H. 1978. Comparative excretions of strontium isotopes in man. Health Phys 34:67–70.621155
Washizu Y. 1968. Strontium and barium ions and guinea-pig ureter. Comp Biochem Physiol 25:367–371.5657216
Wasserman RH, Romney EM, Skougstad MW, . 1977. Strontium. In: Geochemistry and the environment. Washington, DC: National Academy of Sciences, Vol. II: The relation of other selected trace elements to health and disease, 73–87.
*Watanabe N, Yokoyama K, Kinuya S, . 1998. Radio toxicity after strontium-89 therapy for bone metastases using the micronucleus assay. J Nucl Med 39:2077–2079.9867144
Weber DA, Greenberg EJ, Dimich A, . 1969. Kinetics of radionuclides used for bone studies. J Nucl Med 10(1):8–17.5797559
*Webling DD’A, Holdsworth ES. 1966. Bile and the absorption of strontium and iron. Biochem J 100:661–663.4291038
*Wedin B. 1972. Cold - A possibility to increase the excretion of radiostrontium. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 369–378.
*Wedin B, Nilsson A, Ronnback C. 1972. Influence of cold on radiostrontium excretion. Nature (London) New Biol 236:212–213.
Weiss M. 2000. Acute myelogenous. Cancer 89(1):226–227.
Welch SP, Vocci FJ, Dewey WL. 1983. Antinociceptive and lethal effects of intraventricularly administered barium and strontium: Antagonism by atropine sulfate or naloxone hydrochlorine. Life Sci 33:359–364.6877028
Wenger P, Cosandey M. 1976. Retention and excretion of radium-226 and strontium-90 in two doubly contaminated persons. Health Phys 31:225–229.977346
*Wenger P, Soucas K. 1975. Retention and excretion curves of persons containing ^90^Sr and ^226^Ra after a chronic contamination. Health Phys 28:145–152.1110181
*Wesberry JMJ, Wesberry JMS. 1993. Optimal use of beta irradiation in the treatment of pterygia. South Med J 86(6):633–637.8506482
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
*White RG, Raabe OG, Culbertson MR, . 1993. Bone sarcoma characteristics and distribution in beagle fed strontium-90. Radiat Res 136:178–189.8248474
Widdowson EM. 1992. Absorption, excretion and storage of trace elements: Studies over 50 years. Food Chem 43:203–207.
*Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York: Academic Press.
Wigström H, Swann JW. 1980. Strontium supports synaptic transmission and long lasting potentiation in the hippocampus. Brain Res 194:181–191.6247030
*Willard DH, Snyder MD. 1966. Strontium inhalation studies. In: Thompson RC, Swezea EG, eds. Pacific Northwest Laboratory annual report for 1965 in the biological sciences. Richland, WA: Pacific Northwest Laboratory, BNWL-280, 53–55.
*Williams MW, Hoeschele JD, Turner JE, . 1982. Chemical softness and acute metal toxicity in mice and Drosophilia. Toxicol Appl Pharmacol 63:461–469.6808706
*Wiltrout RH, Gruys ME, Urias PE. 1989. Inhibition of organ-associated NK activity by ^89^Sr. In: Natural killer cells and host defense. International Natural Killer Cell Workshop. Basel, NY: Karger, 55–58.
Wing KR. 1975. Turnover of ^65^Zn and ^85^Sr in growing rats: A comparative investigation. Acta Radiol Ther Phys Biol 14(1):1–24.1166809
*Witkamp M. 1966. Biological concentrations of ^137^Cs and ^90^Sr in arctic food chains. Nuclear Safety 8(1):58–62.
*Witz S, Wood JA, Wadley MW. 1986. Toxic metal and hydrocarbon concentrations in automobile interiors during freeway transit. In: ACS Division of Environmental Chemistry 192^nd^ National Meeting. 26:302–305.
*Wolf RL, Cauley JA, Baker CE, . 2000. Factors with calcium absorption effiency in pre- and perimenopausal woman^1-3^. Am J Clin Nutr 72:466–471.10919942
Woodard HQ, Dwyer AJ. 1972. Whole-body retention of ^85^Sr in three children aged 10 to 11 years. In: Second international conference on strontium metabolism, Glasgow and Strontian, 16-19 August, 1972. TID 4500 59th ed. Health and Safety Laboratory/U.S. Atomic Energy Commission, 91–110.
Woodard HQ, Harley JH. 1965. Strontium-90 in the long bones of patients with sarcoma. Health Phys 11:991–998.5218342
*Woodson GC. 1998. An interesting case of osteomalacia due to antacid use associated with stainable bone aluminum in a patient with normal renal function. Bone 22:695–698.9626411
Wrenn ME, Taylor GN, Stevens W, . 1983. DOE life-span radiation effects studies in experimental animals at University of Utah division of radio biology. In: Thompson RC, Mahaffey JA, eds. Life-span radiation effects studies in animals: What can they tell us? Proceedings of the twenty-second Hanford life science symposium held at Richland, Washington, September 27-29, 1983. Hanford Life Sciences Symposium 22^nd^. Springfield, VA: United States Department of Energy, 32–52.
*Wykoff MH. 1971. Distribution of strontium-85 in conceptuses of the pregnant rat. Radiat Res 48:394–401.5115777
*Xu GB, Yu CP. 1986. Effects of age on deposition of inhaled particles in the human lung. Aerosol Sci Technol 5:349–357.
*Yang H-S, Hwang D-W, Lee H-P, . 2002. Distribution of ^90^Sr in coastal seawater, sediments and organisms off two atomic power stations in Korea. J Environ Radioact 59:105–112.11848147
Yasuda H, Uchida S, Muramatsu Y, . 1995. Sorption of manganese, cobalt, zinc, strontium, and cesium onto agricultural soils: Statistical analysis on effects of soil properties. Water Air Soil Pollut 83:85–96.
Yifeng G, Zhaojian H, Meiyu Q, . 1991. Suppression of radioactive strontium absorption by sodium alginate in animals and human subjects. Biomed Environ Sci 4:273–282.1764217
Yongxian W, Jinfa Q, Simin W, . 1990. Study on the relation of Se, Mn, Fe, Sr, Pb, Zn, Cu, and Ca to liver cancer mortality from analysis of scalp hair. Sci Total Environ 91:191–198.2320997
*Ysart G, Miller P, Crews H, . 1999. Dietary exposure estimates of 30 elements from the UK total diet study. Food Addit Contam 16(9):391–403.10755130
Yu KN. 1993. Monitoring ^90^Sr contamination in terms of ^131^I contamination in imported food. Health Phys 65(3):318–321.8244704
*Yu X, Inesi G. 1995. Variable stoichiometric efficiency of Ca^2+^ and Sr^2+^ transport by the sarcoplasmic reticulum ATPase. J Biol Chem 270(9):4361–4367.7876199
Yudintseva YV, Mamontova LA. 1979. Behavior of Sr^90^ in soils upon application of phosphates, lime, and peat. Sov Soil Sci 11(6):705–711.
*Zander-Principati GE, Kuzma JF. 1964. Reduction of strontium-90 bone cancer by zirconium citrate. Int J Radiat Biol 8(5):427–437.
*Zapol’Skaya NA, Borisova VV, Zhorno LY, . 1974. Comparison of the biological effect of strontium-90, cesium-137, iodine-131 and external irradiation. In: Third International Congress of the International Radiation Protection Association. Springfield, VA: U.S. Atomic Energy Commission, 147–152.
Zhai H, Hannon W, Hahn GS, . 2000. Strontium nitrate suppresses chemically-induced sensory irritation in humans. Contact Dermatitis 42:98–100.10703633
*Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
Zittermann A, Sabatschus O, Jantzen S, . 2000. Exercise-trained young men have higher calcium absorption rates and plasma calcitrol levels compared with age-matched sedentary controls. Calcif Tissue Int 67:215–219.10954775