# 4 CHEMICAL, PHYSICAL, and RADIOLOGICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Strontium is an alkaline earth element in Group IIA of the periodic table. Because of its high reactivity, elemental (or metallic) strontium is not found in nature; it exists only as molecular compounds with other elements. The chemical information for elemental strontium and some of its compounds is listed in Table 4-1. Radioactive isotopes of strontium (e.g., ^89^Sr and ^90^Sr, see Section 4.2) are the primary cause of concern with regard to human health (see Chapter 3).

## 4.2 PHYSICAL, CHEMICAL, AND RADIOLOGICAL PROPERTIES

The physical properties of strontium metal and selected strontium compounds are listed in Table 4-2. The percent occurrence of strontium isotopes and the radiologic properties of strontium isotopes are listed in Table 4-3.

Strontium can exist in two oxidation states: 0 and +2. Under normal environmental conditions, only the +2 oxidation state is stable enough to be of practical importance since it readily reacts with both water and oxygen (Cotton and Wilkenson 1980; Hibbins 1997). There are 26 isotopes of strontium, 4 of which occur naturally. The four stable isotopes, ^84^Sr, ^86^Sr, ^87^Sr, and ^88^Sr, are sometimes referred to as stable strontium. The most important radioactive isotopes, ^89^Sr and ^90^Sr, are formed during nuclear reactor operations and during nuclear explosions by the nuclear fission of ^235^U, ^238^U, or ^239^Pu. For example, ^235^U is split into smaller atomic mass fragments such as ^90^Sr by a nuclear chain reaction initiated by high energy neutrons of approximately 1 million electron volts (or 1 MeV). These smaller atomic mass fragments are referred to as fission by-products. This process is illustrated below:

235 U + 1 n → 90 Sr + 89 Sr + other fission by-products

^90^Sr is the more dangerous of the two isotopes due to its long half-life (29 years). ^90^Sr decays by emission of a beta-particle with a maximum energy of 0.546 MeV and the creation of an ^90^Y isotope, or progeny product. Unlike other radioactive isotopes that decay by beta-emission, ^90^Sr does not directly release high energy photons or gamma-ray radiation (γ). However, the progeny product of ^90^Sr, ^90^Y, is both a beta-particle (2.28 MeV maximum energy) emitter and to a minor degree for 0.02% of all disintegrations, a beta-particle and gamma-ray (2.19 keV) emitter. The decay product of ^90^Y is ^90^Zr, a stable isotope. The reaction is:

90 Sr ( t_(1)/(2)_ = 29 yrs ) → 90 Y ( t_(1)/(2)_ = 64 hrs ) + β^−^ ( 0.546 MeV ) → 90 Zr ( stable ) + β^−^ ( 2.28 MeV ) ( 99.98 % ) → 90 Zr ( stable ) + β^−^ ( 0.523 MeV ) + γ ( 1.75 MeV )

Table 4-1 Chemical Identity of Strontium and Strontium Compounds

Property | Strontium (0) | Strontium acetate | Strontium carbonate | Strontium chloride | Strontium chromate
Chemical formula | Sr | C_4_H_6_O_4_Sr | CO_3_Sr | Cl_2_Sr | CrH_2_O_4_Sr
Chemical structure | Sr | Sr(O_2_CCH3)_2_ | SrCO_3_ | SrCl_2_ | SrCrO_4_
Chemical structure | [image] | [image] | [image] | [image] | [image]
Synonyms | None | Strontium diacetate | Carbonic acid, strontium salt (1:1); strontianite | Strontium dichloride | Chromic acid, strontium salt
Trade names | No data | No data | No data | No data | No data
Identification numbers
CAS registry | 7440-24-6 | 543-94-2 | 1633-05-2 | 10476-85-4 | 7789-06-2
NIOSH RTECS | WK7849000 | AJ4725000 | No data | WK8400000 | GB3240000
EPA hazardous waste | No data | No data | No data | No data | D007
OHM/TADS | No data | No data | No data | No data | No data
DOT/UN/NA/IMO shipping | UN 1383/IMO 4.2 | No data | No data | No data | 9149/NA 9149
HSDB | 2545 | No data | 5845 | No data | 2545
NCI | No data | 75799 | 112224 | No data | No data
STCC | No data | No data | No data | No data | 49 633 77

Property | Strontium fluoride | Strontium hydroxide | Strontium nitrate | Strontium phosphate | Strontium oxide
Chemical formula | F_2_Sr | H_2_O_2_Sr | N_2_O_6_Sr | O_8_P_2_Sr3 | OSr
Chemical structure | SrF_2_ | Sr(OH)_2_ | Sr(NO_3_)_2_ | Sr_3_(PO_4_)_2_ | SrO
Chemical structure | [image] | [image] | [image] | [image] | [image]
Synonyms | Strontium difluoride | Strontium hydrate | Nitrate de strontium (French); Nitric acid, strontium salt; strontium dinitrate; strontium(II) nitrate (1:2) | No data | Strontia, strontium monoxide
Trade names | No data | No data | No data | No data | No data
Identification numbers
CAS registry | 7783-48-4 | 18480-07-4 | 10042-76-9 | 7446-28-8 | 1314-11-0
NIOSH RTECS | WK8925000 | WK9100000 | WK9800000 | No data | No data
EPA hazardous waste | No data | No data | No data | No data | No data
OHM/TADS | No data | No data | No data | No data | No data
DOT/UN/NA/IMO shipping | No data | No data | UN 1507 Oxidizer IMO 5.1 | No data | No data
HSDB | No data | No data | No data | No data | No data
NCI | No data | No data | No data | No data | No data
STCC | No data | No data | 49 187 54 | No data | No data

Property | Strontium peroxide | Strontium sulfate | Strontium sulfide | Strontium titanate
Chemical formula | O_2_Sr | O_4_SSr | SSr | O_3_SrTi
Chemical structure | SrO_2_ | SrSO_4_ | SrS | SrTiO_3_
Chemical structure | [image] | [image] | [image] | [image]
Synonyms | Strontium dioxide | Celestine, celestite | Strontium monosulfide | No data
Trade names | No data | No data | No data | No data
Identification numbers
CAS registry | 1314-18-7 | 7759-02-6 | 1314-96-1 | 12060-59-2
NIOSH RTECS | WL0100000 | No data | WL0400000 | No data
EPA hazardous waste | No data | No data | P107/D003 | No data
OHM/TADS | No data | No data | No data | No data
DOT/UN/NA/IMO shipping | UN 1509 Oxidizer IMO 5.1 | No data | No data | No data
HSDB | 788 | No data | 12 | No data
NCI | No data | No data | No data | No data
STCC | 49 187 55 | No data | No data | No data

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances; STCC = Standard Transportation Commercial Code

Source: ChemFinder 2002; HSDB 2002; Lide 2000

Table 4-2 Physical and Chemical Properties of Strontium and Strontium Compounds^a^

Property | Strontium (0) | Strontium acetate^b,c^ | Strontium carbonate^b,c^ | Strontium chloride^c^ | Strontium chromate
Molecular weight, g/mole | 87.62 | 205.71 | 147.63 | 158.53 | 203.62
Color | Pale yellow | White | White | White | Yellow
Physical state | Solid | Solid | Solid | Solid | Solid
Melting point | 777 °C | Decomposes | 1,497 °C^d^ | 875 °C | No data
Boiling point | 1,382 °C | Not applicable | Decomposes at 1,100 °C | 1,250 °C | No data
Density, g/cm^3^ | 2.64 | 2.099 | 3.5 | 3.05 | 3.90
Odor | No data | No data | Odorless | No data | No data
Odor threshold:
Water | No data | No data | No data | No data | No data
Air | No data | No data | No data | No data | No data
Solubility:
Water | Decomposes | 369 g/L (cold) | 0.11 g/L at 18 °C | 538 g/L at 20 °C | 30 g/L at 100 °C
Organic solvents(s) | Alcohol | Alcohol, slightly | No data | Alcohol, acetone | Acetic acid
Partition coefficients:
Log K_ow_ | No data | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data | No data
Vapor pressure | 5 mmHg at 847 °C | No data | No data | No data | No data
Henry’s Law constant | No data | No data | No data | No data | No data
Autoignition temperature | No data | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data | No data
Flammability limits | No data | No data | No data | No data | No data
Explosive limits | No data | No data | No data | No data | No data

Property | Strontium fluoride^e,c^ | Strontium hydroxide^c^ | Strontium nitrate^c^ | Strontium phosphate^f^ | Strontium oxide^c^
Molecular weight, g/mole | 125.62 | 121.64 | 211.63 | 452.80 | 103.62
Color | White | Colorless | Colorless | White | Yellow
Physical state | Solid | Solid | Solid | Solid | Solid
Melting point | Decomposes >100 °C | 375 °C | 570 °C | No data | 2,430 °C
Boiling point | 2,489 °C | No data | 645 °C | No data | 3,000 °C
Density, g/cm^3^ | 4.24 | 3.63 | 2.98 | No data | 4.56
Odor | No data | No data | Odorless | No data | No data
Odor threshold:
Water | No data | No data | No data | No data | No data
Air | No data | No data | No data | No data | No data
Solubility:
Water | 0.12 g/L at 18 °C | 470 g/L at 100 °C | 790 g/L at 18 °C | Insoluble | 229 g/L at 100 °C
Organic solvents(s) | Alcohol, acetone | Alcohol | Slightly in alcohol and acetone | No data | Slightly in alcohol
Partition coefficients:
Log K_ow_ | No data | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data | No data
Vapor pressure | 1 mmHg at 921 °C | No data | No data | No data | No data
Henry’s Law constant | No data | No data | No data | No data | No data
Autoignition temperature | No data | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data | No data
Flammability limits | No data | No data | No data | No data | No data
Explosive limits | No data | No data | No data | No data | No data

Property | Strontium peroxide | Strontium sulfate | Strontium sulfide | Strontium titanate
Molecular weight, g/mole | 119.63 | 183.68 | 119.70 | 183.52
Color | White | Colorless | Gray | White
Physical state | Solid | Solid | Solid | Solid
Melting point | Decomposes at 215 °C | 1,605 °C | >2,000 °C | No data
Boiling point | No applicable | No data | No data | No data
Density, g/cm^3^ | 4.56 | 3.96 | 3.70 | 4.810
Odor | Odorless | No data | Hydrogen sulfide in moist air | No data
Odor threshold:
Water | Not applicable | No data | No data | No data
Air | Not applicable | No data | No data | No data
Solubility:
Water | Decomposes | 0.14g/L at 30 °C | Decomposes | Insoluble
Organic solvents(s) | Alcohol | Slightly in alcohol | No data | No data
Partition coefficients:
Log K_ow_ | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data
Vapor pressure | No data | No data | No data | No data
Henry’s Law constant | No data | No data | No data | No data
Autoignition temperature | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data
Flammability limits | No data | No data | No data | No data
Explosive limits | No data | No data | No data | No data

a Source: HSDB 2002, unless otherwise stated

b Merck 1989

c Lide 1995

d At 69 atmospheres pressure

e Sigma-Aldrich 2000

f Lide 2000

Table 4-3 Percent Natural Occurrence and Radioactive Properties of Isotopes of Strontium

Isotope | CAS registry number | Natural abundance (by weight %) | Beta energies, MeV | Half-life | Activity, Ci/gram
^84^Sr | 15758-49-3 | 0.56 | No data | Stable | No data
^85^Sr | 13967-73-2 | No data | 1.065^a^ | 65 days | 35,400
^86^Sr | 13982-14-4 | 9.86 | No data | Stable | No data
^87^Sr | 13982-64-4 | 7.00 | No data | Stable | No data
^88^Sr | 14119-10-9 | 82.58 | No data | Stable | No data
^89^Sr | 14158-27-1 | No data | 1.495 | 51 days | 27,800
^90^Sr | 10098-97-2 | No data | 0.546 | 29 years | 143
^91^Sr | 14331-91-0 | No data | 2.707 | 10 hours | 3.4×10^6^
^92^Sr | 14928-29-1 | No data | 1.911 | 3 hours | 1.1×10^7^

a Decay mechanism by electron capture with gamma emission

Source: Lide 1995

^89^Sr, like ^90^Sr, is a fission product of ^235^U, ^238^U, or ^239^Pu. It decays to ^89^Y by emission of a beta-particle of 1.495 MeV ^89^Y. ^89^Sr has half-life of 51 days (Lide 1995).