# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-32, Atlanta, Georgia 30333.

## Strontium Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical name(s): | Strontium
CAS number(s): | 7440-24-6
Date: | March 2004
Profile status: | Third draft, post-public
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Key to figure: | 16
Species: | Rat

MRL: 2.0 [X] mg/kg/day [ ] ppm [ ] mg/m^3^

[underlined: Reference]: Storey E. 1961. Strontium ‘rickets’: Bone calcium and strontium changes. Austral Ann Med 10:213–222.

[underlined: Experimental design]: Groups of five young (40–60 g) and three adult (200–250 g) female rats were fed a diet containing 1.6% calcium, 0.9% phosphorus, and 0, 0.19, 0.38, 0.75, 1.0 (young only), 1.5, or 3% strontium as strontium carbonate for 20 days. Initial and final body weights were recorded. Terminal levels of calcium and strontium were measured in serum and in five selected ashed bones for each dose level. Both tibia from each animal were processed histologically, and the proximal epiphyseal cartilages were measured.

[underlined: Effects noted in study and corresponding doses]: The strontium intakes were calculated to be 0, 140, 550, 1,080, 1,460, 2,220, or 4,975 mg strontium/kg/day in young rats, and 0, 170, 350, 690, 1,370, or 2,750 mg strontium/kg/day in adult rats. The serum calcium levels were not significantly changed in either young or adult animals, but at the high doses, the serum calcium/strontium ratio was about 1 in young rats and 1.4 in adults. In young rats, increased strontium ingestion resulted in abnormal thickening of the epiphyseal cartilage plate, approximately doubled at the highest dose. No histological effect was noted at the lowest dose (140 mg strontium/kg/day), but alterations in the appearance of the cartilage plate (irregular, thicker, with areas of uncalcified bone matrix in the distal ends of the metaphyseal trabeculae and proximal end of the diaphysis) were observed at 550 mg strontium/kg/day. Irregularities in the organization of the cells of hypertrophic zone, in the pattern of calcification, and in the deposition of osteoid were more conspicuous with increasing dose. In tibias, the dry weight, ash weight, ash percentage, and calcium in ash were significantly reduced with increased strontium intake. Adult rats were less affected by strontium ingestion than young animals. In adult rats, the no-effect level was 690 mg strontium/kg/day. In adults, changes in tibia histology (thicker epiphyseal cartilage, increased width of metaphyseal osteoid seams) were noted at or above 1,370 mg strontium/kg/day. At 2,750 mg strontium/kg/day, osteoid tissue was deposited near vascular canals and the areas of bone resorption were reduced. In adult rat tibias, the dry weight, ash weight, ash percentage, and calcium in ash were only significantly affected at the highest dose. This study demonstrates the difference in sensitivity to strontium between young and old animals. The LOAEL for the young rats (550 mg/strontium/kg/day) is a NOAEL for the adults (<690 mg strontium/kg/day).

[underlined: Dose and end point used for MRL derivation]:

This study identifies a NOAEL of 140 mg/kg/day for skeletal toxicity in young rats.

[X] NOAEL [] LOAEL:

[underlined: Uncertainty factors used in MRL derivation]:

[ ] 1 [ ] 3 [] 10 (for use of a LOAEL)

[ ] 1 [] 3 [X] 10 (for extrapolation from animals to humans)

[ ] 1 [X ] 3 [] 10 (for human variability)

[underlined: Modifying factor used in MRL derivation]: 3

MRL = NOAEL / (UF)(MF) = 140 mg/kg/day / (30)(3) = 2 mg/kg/day

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?]

Food intake was based upon an allometric equation using the average body weight in kg (EPA 1988): F = 0.056 × bw^0.6611^.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: NA

[underlined: Was a conversion used from intermittent to continuous exposure? If so, explain]: NA

[underlined: Other additional studies or pertinent information that lend support to this MRL]: If an MRL were to be derived from the adult rat NOAEL of 690 mg/kg/day, then an uncertainty factor of 100 would be applied (10 for interspecies extrapolation and 10 for human variability), giving a value of 690/100=6.9 mg/kg/day. Because the young rats represent a sensitive population, just as juveniles would be the most sensitive human group, the selection of the NOAEL implicitly factors in human variability to some degree. Therefore, a smaller uncertainty factor is chosen for intraspecies extrapolation (3 for human variability). However, since the study duration was only 20 days, there is uncertainty whether the NOAEL would be valid for intermediate exposures extending up to 1 year. In addition, the focus of the study was skeletal effects, and no other organ system was examined. To adjust for these potential sources of uncertainty, a modifying factor of 3 is applied to the NOAEL. The MRL is derived using the young rat NOAEL of 140 mg/kg/day and a total uncertainty factor of 30 (10 for interspecies extrapolation and 3 for human variability), and a modifying factor of 3 (for short study duration and limited end point evaluation), giving a value of 140/(30× )=1.6 mg/kg/day; rounding off to whole numbers, the intermediate oral MRL is 2.0 mg/kg/day.

Abnormal bone mineralization (rickets) resulting from ingestion of excess strontium has been observed in many rodent studies. Several studies identified a similar NOAEL (110–168 mg strontium/kg/day) in weanling rats (Grynpas et al. 1996; Kroes et al. 1977; Morohashi et al. 1994). Similar LOAELs (500–565 mg strontium/kg/day) for abnormal bone mineralization in weanling rats have been reported (Johnson et al. 1968; Morohashi et al. 1994; Neufeld and Boskey 1994). Slight skeletal effects were noted in mice at 350 mg/kg/day (Marie and Hott 1986). The relevance of the rodent studies to humans is suggested by a Turkish epidemiological study indicating that excess oral exposure to strontium may contribute to the development of rickets in children (Ögzür et al. 1996).

The skeletal effects of excess strontium are known to be related to its chemical similarity to calcium. Excess strontium adversely affects bone development in several ways. In chickens and rats, excess strontium suppresses the activation of vitamin D3 in the kidney, which severely reduces the expression of calbindin D mRNA and the translation of calbindin D protein in the duodenum (Armbrecht et al. 1979, 1998; Omdahl and DeLuca 1972). As a result, duodenal absorption of calcium is reduced. Strontium also binds directly to hydroxyapatite crystals, which may interfere with the normal crystalline structure of bone in rats (Storey 1961). In addition, excess strontium may prevent the normal maturation of chondrocytes in the epiphyseal plates of long bones of rats (Matsumoto 1976). Excess strontium apparently interferes with the mineralization of complexed acidic phospholipids that is thought to help initiate the formation of hydroxyapatite crystals in developing bone (Neufeld and Boskey 1994). As a result, affected bone contains an excess of complexed acidic phospholipid and a significantly lower ash weight, reducing its strength.