# 8 REFERENCES

*Cited in text

*ACGIH. 1990. Threshold limit values and biological exposure indices for 1990-1991. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*ACGIH. 1991. Documentation of the threshold limit values and biological exposure indices. Sixth edition Vol. III. American Conference of Government Industrial Hygienists. Cincinnati, OH, 1428–1430.
*Air Force. 1989a. JP-4 (Jet Fuel 4). In: The installation restoration program toxicology guide. Volume 4. Contract no. DE-AC05840R21400. Wright-Patterson Air Force Base, OH: Air Force Systems Command, Aerospace Medical Division, Harry G. Armstrong Aerospace Medical Research Laboratory. DOE interagency agreement no. 1891-A076-Al. 64-1 - 64-46.
*Air Force. 1989b. Stoddard solvent. In: The installation restoration program toxicology guide. Volume 4. Contract no. DE-AC05840R21400. Wright-Patterson Air Force Base, OH: Air Force Systems Command, Aerospace Medical Division, Harry G. Armstrong Aerospace Medical Research Laboratory. DOE interagency agreement no. 891-A076-Al. 67-1 - 67-25.
*Alden CL. 1986. A review of unique male rat hydrocarbon nephropathy. Toxicol Pathol 14:109–11.2424069
*Alexander M. 1994. Biodegradation and bioremediation. San Diego, CA: Academic Press, 177–195.
*Anderson C, Sundberg K, Groth O. 1986. Animal model for assessment of skin irritancy. Contact Dermatitis 15:143–151.3780215
*Andrews LS, Snyder R. 1991. Toxic effects of solvents and vapors. In: Amdur MO, Doull J, Klaassen CD, eds. Casarett and Doull’s Toxicology: The basic science of poisons. 4th ed. New York NY: Pergamon Press, 681–685.
*Annobil SH. 1988. Skin bullae following kerosene poisoning. Ann Trop Pediatr 8(1):45–47.
*APHA. 1985. Standard methods for the examination of water and wastewater. 16th ed. Washington, DC: American Public Health Association.
*API. 1976. Detectability and irritability of hydrocarbons in human subjects. Final report to American Petroleum Institute. Contract no. U-15-14-PS-5. Department of Environmental Health, College of Medicine, University of Cincinnati, Cincinnati, OH.
*API. 1977. Teratology study in rats. Stoddard solvent final report. Washington, DC: American Petroleum Institute. FYI-AX-01 83-0232 IN.
*API. 1978a. Mutagenicity evaluation of Stoddard solvent. API Medical Research Publication: 26-60010. Washington, DC: American Petroleum Institute. FYI-OTS-0684-0313 SU.
*API. 1978b. Teratology study in rats: Unleaded gasoline. Washington, DC: American Petroleum Institute. EBI. Project no. 20698-6.
*API. 1979a. Inhalation/teratology study in rats: Fuel oil. Washington, DC: American Petroleum Institute. Document no. FYI-AX-0183-0230.
*API. 1979b. Teratology study in rats: Diesel fuel. Washington, DC: American Petroleum Institute. Document no. FYI-AX-01 83-0230.
*API. 1982. Mutagenicity study of thirteen petroleum fractions. Project no. U-150-14 (EA-1). Washington, DC: American Petroleum Institute.
*API. 1987a. Acute inhalation toxicity evaluation of a petroleum derived hydrocarbon in rats - API 84-02 and API 85-01 with heavy thermal cracked naphtha, with cover letter dated 05/19/87. Project no. 22235-14. Washington, DC: American Petroleum Institute.
*API. 1987b. Mutagenicity of API 8501, Stoddard solvent (CAS 8052-41-3) in a mouse lymphoma mutation assay. Final report. Washington, DC: American Petroleum Institute.
*Arlien-Soborg P, Bruhn P, Gyldensted C, . 1979. Chronic painters’ syndrome: Chronic toxic encephalopathy in house painters. Acta Neurol Stand 60: 149–156.
*ASTM. 1988. 1988 Annual book of ASTM standards: volume 6.03. Paints - Fatty oils and acids, solvents, miscellaneous; aromatic hydrocarbons. Philadelphia, PA: American Society for Testing and Materials. Designation:D 235–87.
*ASTM. 1992. Standard speciation for mineral spirits (petroleum spirits) (hydrocarbon dry cleaning solvent). Philadelphia, PA: American Society for Testing and Materials, Designation: D 235-92, 2p.
*Astrand I, Kilbom A, Ovrum P. 1975. Exposure to white spirit: I. Concentration in alveolar air and blood during rest and exercise. Stand J Work Environ Health 12: 15–30.
*ATSDR. 1989. Toxicological profile for benzene. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1990. Toxicological profile for toluene. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1991. Toxicological profile for naphthalene and 2-methylnaphthalene. Atlanta, GA: U.S Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1993. Draft toxicological profile for gasoline; Draft toxicological profile for jet fuels JP-4 and JP-7; Draft toxicological profile for fuel oils. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
Baker EL, Fine LJ. 1986. Solvent neurotoxicity. The current evidence. J Occup Med 28:126–129.3512803
Baker RW, Yoshioka N, Mohr JM, . 1987. Separation of organic vapors from air. J Membr Sci 31:259–272.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
*Beck LS, Hepler DI, Hansen KL. 1983. The acute toxicology of selected petroleum hydrocarbons. In: MacFarland HN, Holdsworth LE, MacGregor JA, . eds. Proceedings on the 1st Symposium on the Toxicology of Petroleum Hydrocarbons Washington, DC, May 1982. Washington, DC: American Petroleum Institute, 1–12.
Beime GJ, Brennan JT. 1972. Glomemlonephritis associated with hydrocarbon solvents. Arch Environ Health 25.365–369.4568564
*Beliles RP, Mecler FJ. 1983. Inhalation teratology of jet fuel A: fuel oil and petroleum naphtha in rats. In: MacFarland HN, Holdsworth LE, MacGregor JA, . eds. Proceedings of the Ist Symposium on the Toxicology of Petroleum Hydrocarbons Washington, DC, May 1982. Washington, DC: American Petroleum Institute, 233–238.
Bernard A, Lauwerys R. 1991. Proteinuria changes and mechanisms in toxic nephropathies. Crit Rev Toxicol 21(5):373–405.1741950
Beving H, Malmgren R, Olsson P. 1988. Changed fatty acid composition in platelets from workers with long term exposure to organic solvents. Br J Ind Med 45:565–567.3415924
*Beving H, Tomling G, Olsson P. 1991. Increased erythrocyte volume in car repair painters and car mechanics. Br J Ind Med 48:499–501.1854652
*Bianchi AP, Varney MS, Phillips J. 1991. Analysis of industrial solvent mixtures in water using a miniature purge-and-trap device with thermal desorption and capillary gas chromatography-mass spectrometry. J Chromatogr 557(1–2):429–439.
Biles RW, McKee RH. 1983. Toxicological testing for hazard identification in synthetic fuel technology. Dev Toxicol Environ Sci 11:13–21.6677449
*Bingham E, Falk HL. 1969. Environmental carcinogens: The modifying effect of carcinogens on the threshold response. Arch Environ Health 19:779–783.4187174
*Birmingham DJ. 1988. 9. Contact dermatitis and related dermatoses associated with petroleum recovery and use: Occupational Medicine: State of the Art Reviews 3(3):511.
Bjerre A. 1989. Assessing exposure to solvent vapour during the application of paints, etc.-model calculations versus common sense. Ann Occup Hyg 33:507–517.2604316
Blair A, DeCoufle P, Grauman D. 1979. Cause of death among laundry and cleaning workers. Am J Public Health 69(5):508–511.434285
*Bocskei Z, Groom CR, Flower DR, . 1992. Pheromone binding to two rodent urinary proteins revealed by X-ray crystallography. Nature 360: 186–188.1279439
*Bombassei GJ, Kaplan AA. 1992. The association between hydrocarbon exposure and anti-glomerular basement membrane antibody-mediated disease (Goodpasture’s Syndrome). Am J Ind Med 21:141–153.1536151
*Borghoff SJ, Short BG, Swenberg JA. 1990. Biochemical mechanism and pathobiology of α_2μ_- globulin nephropathy. Annu Rev Pharmacol Toxicol 30:349–367.1693054
Bottomley WW, Sheehan-Dare RA, Hughes P, . 1993. A sclerodermatous syndrome with unusual features following prolonged occupational exposure to organic solvents. Br J Dermatol 128:203–206.8457454
*Bradley A, Bodsworth PL. 1983. Environmental control of a large paint booth. Ann Occup Hyg 27:223–224.
Bratton L, Haddow JE. 1975. Ingestion of charcoal lighter fluid. J Pediatr 87:633–636.1159594
Braunstein LE. 1940. Subacute yellow atrophy of the liver due to solvent. JAMA 114: 136–138.
Brown D, Kaplan S. 1987. Retrospective cohort mortality study of dry cleaner workers using perchloroethylene. J Occup Med 29(6):535–541.3612328
*Bruhn P, Arlien-Soborg P, Gyldensted C, . 1981. Prognosis in toxic encephalopathy: A two-year follow-up study in 26 house painters with occupational encephalopathy. Acta Neurol Stand 64:259–272.
Buckley JD, Robison LL, Swotinsky R, . 1989. Occupational exposures of parents of children with acute nonlymphocytic leukemia: A report from the children’s cancer study group. Cancer Res 49:4030–4037.2736544
*Budavari S, O’Neil MJ, Smith A, . eds. 1989. The Merck index: An encyclopedia of chemicals drugs, and biologicals. Eleventh edition. Rahway, NJ: Merck & Co., Inc., 976.
*Carpenter CP, Kinkead ER, Geary DL Jr., . 1975a. Petroleum hydrocarbon toxicity studies: I. Methodology. Toxicol Appl Pharmacol 32:246–262.1154392
*Carpenter CP, Kinkead ER, Geary DL Jr., . 1975b. Petroleum hydrocarbon toxicity studies: III. Animal and human response to vapors of Stoddard solvent. Toxicol Appl Pharmacol 32:282–297.1154394
Carpenter CP, Kinkead ER, Geary DL Jr., . 1975c. Petroleum hydrocarbon toxicity studies. VIII. Animal and human response to vapors of “140° flash aliphatic solvent.” Toxicol Appl Pharmacol 413–429.
*CELDS. 1991. Army Corps of Engineers Construction Engineering Research Laboratory and University of Illinois, Department of Urban and Regional Planning. Computer-aided Environmental Legislative Data Systems [database]. June 1991.
Chelton CF, Zakraysek N, Lautner GM, . 1983. Evaluation of the performance and response of the Bacharach TLV sniffer and H-nu photoionization gas analyzer to common hydrocarbon solvents. Am Ind Hyg Assoc J 44:710–715.6650391
Cherry N, Waldron HA. 1983. The neuropsychological effects of solvent exposure. The Colt Foundation, New Lane, Havant, Hampshire, PO9 2LY, United Kingdom, 205.
Churchill DN, Fine A, Gault MH. 1983. Association between hydrocarbon exposure and glomerulonephritis: An appraisal of the evidence. Nephron 33: 169–172.6843743
Clark CR, Walter MK, Ferguson PW, . 1988. Comparative dermal carcinogenesis of shale and petroleum-derived distillates. Toxicol Ind Health 4: 11–22.3388444
Clark CR, Ferguson PW, Katchen MA, . 1989a. Comparative acute toxicity of shale and petroleum derived distillates. Toxicol Ind Health 5:1005–1016.2626753
*Clark DG, Butterworth ST, Martin JG, . 1989b. Inhalation toxicity of high flash aromatic naphtha. Toxicol Ind Health 51415–28.
*Clean Air Act. 1990. Washington, DC The Bureau of National Affairs, Inc. PL 101-549. 71:1159.1175–1188.
*CLPSD. 1989. Contract Laboratories Program Statistical Database. U.S. Environmental Protection Agency, Washington, DC. July, 1989.
*Commonwealth of Massachusetts. 1990. Massachusetts Surface Water Quality Standards. Boston, MA: Massachusetts Surface Water Quality Standards, Division of Water Pollution Control. Massachusetts 314 CMR 4.00.
*Commonwealth of Virginia. 1990. Commonwealth of Virginia State Water Control Board Regulations. Richmond, VA: Commonwealth of Virginia State Water Control Board Regulations, Water Quality Standards.
*Conaway CC, Schreiner CA, Cragg ST. 1984. Mutagenicity evaluation of petroleum hydrocarbons. In: MacFarland HN, Holdsworth CE, MacGregor JA, . eds. Advances in modem environmental toxicology. Vol. 6: Applied toxicology of petroleum hydrocarbons. Princeton NJ: Princeton Scientific Publishers, Inc., 89–107.
*Coruh M, Inal H. 1966. Kerosene poisoning in children with special reference to lung complication. Turk J Pediatr 8(1):36–42.5915005
*Coyle JJ, Potenta EJ. 1983. Population exposure to hazardous air pollutants from waste combustion in industrial boilers and RCRA regulated incinerators. In: Frederick ER, ed. Proceedings, measurement, and monitoring of non-criteria (toxic) contaminants in air specialty conference, 1983. Chicago, IL: Air Pollution Control Association, 138–149.
*Daniel1 WE, Couser WG, Rosenstock L. 1988. Occupational solvent exposure and glomerulonephritis: A case report and review of the literature. JAMA 259:2280–2283.3280843
Delzell E, Austin H, Cole P. 1988. 6. Epidemiologic studies of the petroleum institute. Occupational Medicine: State of the Art Reviews 3(3):455–474.
*Dice WH, Ward G, Kelley J, . 1982. Pulmonary toxicity following gastrointestinal ingestion of kerosene. Ann Emerg Med 11: 138–142.7065488
Dick RB. 1988. Short duration exposures to organic solvents: The relationship between neurobehavioral test results and other indicators Neurotoxicol Teratol 10:39–50.3352568
*Dossing M, Arlien-Soborg P, Petersen LM. 1983. Liver damage associated with occupational exposure to organic solvents in house painters. Eur J Clin Invest 13:151–158.6409638
*DOT. 1989a. Hazardous materials table. Department of Transportation. Code of Federal Regulations. 49 CPR 172.101 Appendix A.
*DOT. 1989b. Hazardous materials table and hazardous materials communications regulations. Department of Transportation Federal Register 54:39501–39505.
Duh R-W, Asal NR. 1984. Mortality among laundry and dry cleaning workers in Oklahoma. Am J Public Health 74:1278–1280.6496825
Edelfors S, Ravn-Jonsen A. 1992. Effect of organic solvents on nervous cell membrane as measured by changes in the (Ca2+/Mg2+) ATPase activity and fluidity of synaptosomal membrane. Pharmacol Toxicol 70:181–187.1533717
*Edgerton SA, Coutant RW, Henley MV. 1987. Hydrocarbon fuel spill dispersion on water: A literature review. Chemosphere 16(7):1475–1487.
*Ellenhorn MJ, Barceloux DG, eds. 1988. Medical toxicology: Diagnosis and treatment of humans poisoning. New York NY: Elsevier.
Enzminger JD, Ahlert RC. 1987. Environmental fate of polynuclear aromatic hydrocarbons in coal tar. Environmental Technology Letters 8:269–278.
*EPA. 1980. Demonstration of carbon adsorption technology for petroleum dry cleaning plants. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. ISS EPA-600/2-80-145, order no. PB80-221039.
EPA. 1981. Reevaluation of kidney sections from animals used in various solvent inhalation toxicity studies, with attachments, cover sheets, and letter dated 01/28/81. Washington, DC: U.S. Environmental Protection Agency. Documents no. 8EHQ-0281-0312; 88-8100181. OTS0200630.
EPA. 1982a. Mixed solvent vapor exposure, with cover letter. Washington, DC: U.S. Environmental Protection Agency. U.S. EPA/OPTS public files 878210808. Microfiche no. OTS0206238.
EPA. 1982b. Product environmental data. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. NTIS/OTS0206107.
EPA. 1982c. Product environmental data. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. NTIS/OTS0206116.
EPA. 1984a. Response to EPA document SEHQ-05840517 with attached summary of histopathological findings of a lifetime skin painting study in mice. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. NTIS/OTS0509708.
EPA. 1984b. Review of toxicity information on Varsol 40 (Varsol 1). Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. NTIS/OTS00003 13-0.
*EPA. 1984c. Summary of histopathology findings for dermal carcinogenesis lifetime skin painting study of solvent-cutback type rust preventative. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances” Document no. 88-8400629.
*EPA. 1984d. Follow up to TSCA Section 8(e) report on Isopar C and Varsol 40, with cover letter dated 01/18/84. Washington, DC: U.S. Environmental Protection Agency. Document no. SEHQ-0184-0312; 88-8400586. OTS0200630.
EPA. 1986a. A copy of a study on the genetic toxicity of Rust-Ban 392 and excerpts from the final report, with cover letter dated 06/20/86. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. NTIS/OTS0509708-1.
EPA. 1986b. Oral toxicity, dermal toxicity, dermal irritation, eye irritation and dermal sensitization studies performed with API 83-15, 85-01 & 83-20 (final report) with letter. Washington, DC: US. Environmental Protection Agency, Office of Toxic Substances. NTIS/OTS00OO37l-5.
*EPA. 1986c. Quality criteria for water. Washington, DC: U.S. Environmental Protection Agency. EPA 440/5-86-001.
EPA. 1987. 28-Day dermal toxicity study of API 85-01 in the rabbit (draft final report) with cover letter dated 02/25/87. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. NTISIOTS0000533-0.
EPA. 1989. Pesticides required to be reregistered: List C. U.S. Environmental Protection Agency. Federal Register 54 (104): 30846–30855.
*EPA 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency. EPA/600/8-90/066A.
*EPA. 1991a. α_2μ_- globulin: Association with chemically-induced renal toxicity and neoplasia in the male rat. Review draft. Washington, DC: U.S. Environmental Protection Agency. EPA/624/3-91/019A.
EPA. 1991b. C9 aromatic hydrocarbon fraction. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 799.2175.
*EPA. 1991~. Method 602 - Purgeable aromatics; Method 610 - Polynuclear aromatic hydrocarbons; Method 625 - Base/neutrals and acids. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136, Appendix A.
*EPA. 1992a. Toxic Substances Control Act Inventory 1990 [Chemical Update System Database]. Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics, Information Management Division.
EPA. 1992b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 300. Federal Register 57(26):4824–4830.
*ERNS. 1993. Emergency Response Notification System. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response. June, 1993.
*Farrington JW, Davis AC, Frew NM, . 1982. No. 2 fuel oil components in Mytilis edulis: Retention and release after an oil spill. Marine Biology 66:15–26.
*Fidler AT, Baker EL, Letz RE. 1987. Estimation of long term exposure to mixed solvents from questionnaire data: A tool for epidemiological investigations. Br J Ind Med 44:133–141.3814546
*Finn R, Fennerty A, Ahmad R. 1980. Hydrocarbon exposure and glomerulonephritis. Clin Nephrol 14:173–175.7428191
*Flodin U, Edling C, Axelson O. 1984. Clinical studies with psychoorganic syndromes among workers with exposure to solvents. Am J Ind Med 5:287–295.6720692
Franchini I, Cavatora A, Falzoi M, . 1983. Early indicators of renal damage in workers exposed to organic solvents. Int Arch Occup Environ Health 52:1–9.6603422
*Fukaya Y, Saito I, Matsumoto T, . 1994. Determination of 3,4-dimethylhippuric acid as a biological monitoring index for trimethylbenzene exposure in transfer printing workers. Int Arch Occup Environ Health 65:295–297.8175183
*Galin T, Gerstl Z, Yaron B. 1990. Soil pollution by petroleum products: III. Kerosene stability in soil columns as affected by volatilization. J Contam Hydrol 5(4):375–385.
*Gamberale F, Annwall G, Hultengren M. 1975. Exposure to white spirit: II. Psychological functions. Stand J Work Environ Health 1:31–39.
*Gearing PJ, Gearing JN, Pruell RJ, . 1980. Partitioning of no. 2 fuel oil in controlled estuarine ecosystems: Sediments and suspended particulate matter. Environmental Science and Technology 14(9):1129–1136.
Gill R, Warner HE, Broster CG, . 1991. The response of evidential breath alcohol testing instruments with subj.ects exposed to organic solvents and gases. II. White spirit and nonane. Medicine, Science, and the Law 31:201–13.1822581
*Gochet B, de Meester C, Leonard A, . 1984. Lack of mutagenic activity of white spirit. Int Arch Occup Environ Health 53:359–364.6370871
Goodfield MJ, Saihan EM. 1988. Contact urticaria to naphtha present in a solvent. Contact Dermatitis 18:187.2966720
Grasso P. 1988. Neurotoxic and neurobehavioral effects of organic solvents on the nervous system. State Art Rev Occup Med 3525539.
*Gregersen P. 1988. Neurotoxic effects of organic solvents in exposed workers: Two controlled follow-up studies after 5.5 and 10.6 years. Am J Ind Med 14:681–702.2852897
*Gregersen P, Angelsoe B, Nielson TE, . 1984. Neurotoxic effects of organic solvents in exposed workers: An occupational, neuropsychological, and neurological investigation. Am J Ind Med 5:201–225.6322581
*Haddad LM, Winchester JF, eds. 1990. Clinical management of poisoning and drug overdose. 2nd ed. Philadelphia PA: W.B. Saunders Company, 1177–1183.
Hagmar L, Bellander T, Hoegstedt B, . 1988. Biological effects in a chemical factory with mutagenic exposure: I. Cytogenetic and hematological parameters. Int Arch Occup Environ Health 60:437–444.3410554
Halder CA, Holdsworth CE, Cockre11 BY, . 1985. Hydrocarbon nephropathy in male rats: Identification of the nephrotoxic components of unleaded gasoline. Toxicol Ind Health 1:67–88.3842552
*Hane M, Axelson O, Blume J, . 1977. Psychological function changes among house painters. Stand J Work Environ Health 3:91–99.
Hansen MK, Larsen M, Cohr K-H. 1987. Waterborne paints: A review of their chemistry and toxicology and the results of determinations made during their use. Stand J Work Environ Health 13:473–485.
*Hara K, Kageura M, Hieda Y, . 1988. Application of wide-bore capillary gas chromatography to analyze volatile compounds in body fluids. Jpn J Legal Med 42(2):142–146.
Harrington JM, Whitby H, Gray CN, . 1989. Renal disease and occupational exposure to organic solvents: A case referent approach. Br J Ind Med 46:643–650.2789968
Hashimoto DM, Kelsey KT, Seitz T, . 1991. The presence of urinary cellular sediment and albuminuria in newspaper pressworkers exposed to solvents. J Occup Med 33:516–526.2037907
*Hastings L, Cooper GP, Burg W. 1984. Human sensory response to selected petroleum hydrocarbons. In: MacFarland HN, Holdsworth CE, MacGregor JA, . eds. Advances in modern environmental toxicology. Vol. VI: Applied toxicology of petroleum hydrocarbons. Princeton NJ: Princeton Scientific Publishers, Inc., 255–270.
Hauser SP. 1988. [Naphtha-B 100 to 140-petroleum. Documentation no. 12.1 Schweiz Rundsch Med Prax 77:152–154. (German)
*Haydon DA, Hendry BM, Levinson SR. 1977. The molecular mechanisms of anaesthesia. Nature 268:356–358.69993
*HAZDAT. 1994. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
Hegewisch-Becker S, Szudra A, Hossfeld DK. 1993. Exposure to lipophilic industrial solvents leads to increased P-glycoprotein expression in peripheral blood cells. Br J Haematol 85:220–222.7902735
Heineman EF, Olsen JH, Pottem EM, . 1992. Occupational risk factors for multiple myeloma among Danish men. Cancer Causes Control 3:555–568.1420859
*Henningsen GM, Yu KO, Salomon RA, . 1987. The metabolism of t-butylcyclohexane in Fischer-344 male rats with hyaline droplet nephropathy. Toxicol Lett 39:313–318.3686558
Holmberg PC 1979. Central-nervous-system defects in children born to mothers exposed to organic solvents during pregnancy. Lancet 2: 177–179.89284
Holmberg PC, Nurminen M. 1980. Congenital defects of the central nervous system and occupational factors during pregnancy: Case-referent study. Am J Ind Med 1:167–176.7342764
*Horton AW, Denman DT, Trosset RP. 1957. Carcinogenesis of the skin. II. The accelerating properties of aliphatic and related hydrocarbons. Cancer Research 17:758–766.13460980
*Horton AW, Van Dreal PA, Bingham EL. 1966. Physicochemical mechanisms of acceleration of skin carcinogenesis. In: Advances in Biology of the Skin (Montagna W; Dobson R; editors). Vol. 7. Oxford, Pergamon Press. pp. 165–181.
*Horton AW, Eshleman DN, Schuff AR, Penman WH. 1976. Correlation of cocarcinogenic activity among n-alkanes with their physical effects on phospholipid micelles. J Nat1 Cancer Inst. 56:387–91.
*Hunter D, Kislin AH, Kiesche E, . eds. 1992. Buyer’s guide: Special issue. Chemical Week 149:500, 589.
*IARC. 1989. Occupational exposures in petroleum refining. IARC monographs on the evaluation of carcinogenic risks to humans. Occupational exposures in petroleum refining. Vol. 45: Crude oil and major petroleum fuels, Lyon, France: World Health Organization, International Agency for Research on Cancer, 39–117.
Iregren A, Gamberale F. 1990. Human behavioral toxicology central nervous effects of low-dose exposure to neurotoxic substances in the work environment. Stand J Work Environ Health 16: 17–25.
*IRPTC. 1985. Treatment and disposal methods for waste chemicals: IRPTC file. Geneva, Switzerland: United Nations Environment Programme, International Register of Potentially Toxic Chemicals, 222.
Jakobsen BM, Hass U, Juul F, . 1986. Prenatal toxicity of white spirits inhalation inthe rat [Abstract]. Teratology 34:415.
*Jenkins LJ Jr, Coon RA, Lyon JP, . 1971. Effect on experimental animals of long-term inhalation exposure to mineral spirits: II. Dietary, sex and strain influences in guinea pigs. Toxicol Appl Pharmacol 18:53–59..5542833
*Jones CJ, McGugan PJ. 1978. An investigation of the evaporation of some volatile solvents from domestic waste. Journal of Hazardous Materials 2:235–252.
*Kainz RJ, White LE. 1984. Depressant effects associated with the inhalation of uncombusted diesel vapor. In: MacFarland HN, Holdsworth CE, MacGregor JA, . eds. Advances in modem environmental toxicology. Volume VI: Applied toxicology of petroleum hydrocarbons Princeton NJ: Princeton Scientific Publishers, Inc.
Kastl J, Horacek J. 1982. [Primary myogenic skin tumours (multiple piloleiomyoma, subcutaneous leiomyosarcoma).] Cesk Dermatol 57:205–207. (Czech)7139730
Katz RM, Jowett D. 1981. Female laundry and dry cleaning workers in Wisconsin: A mortality analysis. Am J Public Health 71(3):305–307.7468868
*Kimura K, Nagata T, Hara K, . 1988. Gasoline and kerosene components in blood: A forensic analysis. Hum Toxic01 7(4):299–305.
*Kimura H, Odani S, Nishi S, . 1991a. Primary structure and cellular distribution of two fatty acid-binding proteins in adult rat kidneys. J Biol Chem 266:5963–5972.2005132
Kimura K, Nagata T, Kudo K, . 1991b. Determination of kerosene and light oil components in blood. Biol Mass Spectrom 20(8):493–497.1768706
*Klaassen CD, Rozman K. 1991. Distribution, excretion, and absorption of toxicants. In: Amdur MO, Doull J, Klaassen CD, eds. Casarett and Doull’s Toxicology: The basic science of poisons. 4th ed. New York NY: Pergamon Press, 50–57.
*Klein BL, Simon JE. 1986. Hydrocarbon poisonings. Pediatr Clin North Am 33(2):411–419.2870464
*Knave B, Olson BA, Elofson S, . 1978. Long term exposure to jet fuel: II. A cross-sectional epidemiologic investigation on occupationally exposed industrial workers with special reference to the nervous system. Stand J Work Environ Health 4:19–45.
Koh D, Foulds IS, Aw TC. 1990. Dermatological hazards in the electronics industry. Contact Dermatitis 22: 1–7.2138951
Kopecni MM, Tarana MV, Cupic SD, . 1989. Gas chromatographic determination of phenols in waste water-oil emulsions. J Chromatogr 462:392–397.
Kumar A, Sparks BD, Majid A. 1986. Recovery of organics from tailings pond sludge using coke for agglomeration. Separation Science and Technology 21:315–326.
Kunkel DB, Sullivan JB, Jr. 1992. Carbon disulfide and select miscellaneous solvents. In: Sullivan, JB Jr., Krieger, GR, eds. Hazardous materials toxicology: Clinical principles of environmental health. Baltimore MD: Williams & Wilkins, p.1117–1123.
Kurppa K, Vainio H. 1983. Study design liver disease and house painters exposure to organic solvents. Eur J Clin Invest 13:113–114.6409633
Kurppa K, Holmberg PC, Hemberg S, . 1983. Screening for occupational exposures and congenital malformations: Preliminary results from a nationwide case-referent study. Scand J Work Environ Health 9:89–93.6648425
Kyvik K, Brattebo G, Tysnes O-B, . 1992. Activation of blood platelets in workers exposed to organic solvents. J Occup Med 34(7):687–692.1494960
Kyyronen P, Taskinen H, Lindbohm ML, . 1989. Spontaneous abortions and congenital malformations among women exposed to tetrachloroethylene in dry cleaning. J Epidemiol Community Health 43:346–351.2614324
*Lam HR, Lof A, Ladefoged O. 1992. Brain concentrations of white spirit components and neurotransmitters following a three week inhalation exposure of rats. Pharmacol Toxicol 70:394–396.1351674
*Lam HR, Ostergaard G, Guo SX, . 1994. Three weeks’ exposure of rats to dearomatized white spirit modifies indices of oxidative stress in brain, kidney, and liver. Biochem Pharmacol 47(4):651–657.7907472
*Lankas GR, Baxter CS, Christian RT. 1978. Effect of alkane tumor-promoting agents on chemically induced mutagenesis in cultured V79 Chinese hamster cells. J Toxicol Environ Health 4:37–41.633409
*Larsen LB, Schmunes E. 1974. OccupationaI health case report-no. 6: Stoddard solvent. J Occup Med 16:276–278.4274324
Lauwerys R, Bernard A, Viau C, . 1985. Kidney disorders and hematotoxicity from organic solvent exposure. Stand J Work Environ Health 11(1):83–90.
Lebowitz H, Brusick D, Matheson D, . 1979. Commonly used fuels and solvents evaluated in a battery of short-term bioassays [Abstract]. Environ Mutagen 1: 172–173.
*Lehman-McKeeman LD. 1993. Male rat-specific light hydrocarbon nephropathy. In: Target organ toxicology series: Toxicology of the kidney. 2nd edition. New York: Raven Press, 477–494.
Linz DH, de Garmo PL, Morton WE, . 1986. Organic solvent-induced encephalopathy in industrial painters. J Occup Med 28:119–125.3950785
*Litovitz T, Greene AE. 1988. Health implications of petroleum distillate ingestion. Occupational Medicine: State of the Art Review 3:555–567.
Litt IF, Cohen MI. 1969. “Danger…vapor harmful”: Spot-remover sniffing. N Engl J Med, Sept 4:543–544.
*Lovley DR, Woodward JC, Chapelle FH. 1994. Stimulated anoxic biodegradation of aromatic hydrocarbons using Fe (III) ligands [letter]. Nature 370:128–131.8022480
Lundberg I. 1986. Mortality and cancer incidence among Swedish paint industry workers with long-term exposure to organic solvents. Stand J Work Environ Health 12:108–113.
*Majeed HA, Bassyouni H, Kalaawy M, . 1981. Kerosene poisoning in children: A clinicoradiological study of 205 cases. Ann Trop Pediatr 12:123–130.
*Mann MD, Pirie DJ, Wolfsdorf J. 1977. Kerosene absorption in primates. J Pediatr 91(3):495–498.408472
*Mattel CJ, Nadeau JM. 1994. Snow as an expedient sorbent for hazardous materials. J Environ Sci Health A29(1):237–247.
*Martin JH, Siebert AJ, Loehr RC. 1991. Estimating oil and grease content of petroleum-contaminated soil. Journal of Environmental Engineering 117(3):291–299.
*McDermott HJ. 1975. Hygienic guide series: Stoddard solvent (mineral spirits, white spirits). Am Ind Hyg Assoc J 36553–558.
McGovern JL. 1992. Four methods for predicting the flash point of alkyd paints containing VM&P naphtha and mineral spirits-Part I. Journal of Coatings Technology 64(810):33–38.
McKee RH, Hinz JP. 1987. Evaluation of the subacute and subchronic toxicity of inhaled hydrotreated naphtha in the rat. Fundam Appl Toxicol 9: 120–130.3622956
McKee RH, Biles RW, Kapp RW, . 1984. The acute toxicity of coal liquefaction-derived materials. J Appl Toxicol 4:198–205.6491150
McKee RH, Hinz JP, Traul KA. 1986. Evaluation of the teratogenic potential and reproductive toxicity of coal-derived naphtha. Toxicol Appl Pharmacol 84: 149–158.3715861
McKee RH, Schmitt S, Wong Z, . 1990a. The reproductive and developmental toxicity of high flash aromatic naphtha. Toxicologist 10:41.
McKee RH, Wong ZA, Schmitt S, . 1990b. The reproductive and developmental toxicity of high flash aromatic naphtha. Toxicol Ind Health 6:441–460.2237929
*Mehlman MA, Smart CL. 1982. A comparative toxicological evaluation of paint solvents. In: Englund A, Ringen K, Mehlman MA, eds. Occupational health hazards of solvents. Princeton NJ: Princeton Scientific Publishers, 53–67.
Melke D. 1987. [Measuring chemical pollutants in the air at the work site of watchmakers.] Z Gesamte Hyg 33:640–641. (German)3442062
Mellgren SI, Formoe T, Sundby R. 1988. Vibratory threshold in workers exposed to organic solvents [Abstract]. Neurology 38(Suppl. 1):222.
*Mergler D, Belanger S, de Grosbois S, . 1988. Chromal focus of acquired chromatic discrimination loss and solvent exposure among printshop workers. Toxicology 49:341–348.3376138
*Menzer R. 1991. Water and Soil Pollutants. In: Amdur MO, Doull J, Klaassen CD, eds. Casarett and Doull’s Toxicology: The basic science of poisons. 4th ed. New York NY: Pergamon Press, 872–878.
*Midkiff CR Jr, Washington WD. 1972. Gas chromatographic determination of traces of accelerants in physical evidence. J Assoc Off Anal Chem 55(4):840–845.
Mikkelsen S. 1980. A cohort study of disability pension and death among painters with special regard to disabling presenile dementia as an occupational disease. Stand J Soc Med Suppl 16:34–43.
*Mikkelsen S, Jorgensen M, Browne E, . 1988. Mixed solvent exposure and organic brain damage: A study of painters. Acta Neurol Stand Suppl 78:1–143.
*Mosconi G, Migliori M, Greco V, . 1988. Kerosene “burns”: A new case. Contact Dermatitis 19(4):314–315.3219847
*MSDS-CCOHS. 1992. Mineral spirits. Material Safety and Data Sheet-Canadian Center for Occupational Health and Safety. May 13, 1992.
*Narvarte J, Saba SR, Ramirez G. 1989. Occupational exposure to organic solvents causing chronic tubulointerstitial nephritis Arch Intern Med 149:154–158.2638566
*NBS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
*NATICH. 1991. National Air Toxics Information Clearinghouse. Data base report on state, local, and EPA air toxics activities. U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards, Washington, D.C.: August 13, 199%.
*NESCAUM. 1989. Evaluation of the health effects from exposure to gasoline and gasoline vapors. Final report. Northeast States for Coordinated Air Use Management.
*Nethercott J, Pierce JM, Likwornick G, . 1980. Genital ulceration due to Stoddard solvent. J Occup Med 22:549–552.7400868
Niemela R, Pfaffli P, Harkonen H. 1987. Ventilation and organic solvent exposure during car washing. Scand J Work Environ Health 13:424–430.3433044
Nierenberg DW, Horowitz MB, Harris KM, . 1991. Mineral spirits inhalation associated with hemolysis, pulmonary edema, and ventricular fibrillation. Arch Intern Med 151: 1437–1440.2064497
NIOSH. 1977. Criteria for a recommended standard. Occupational exposure to refined petroleum products. Washington DC: U.S. Department of Health, Education, and Welfare, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health. DHEW (NIOSH) publication no. 77-192.
*NIOSH. 1984. Manual of analytical methods. 3rd ed. Eller PM, ed. Cincinnati, OH: National Institute for Occupational Safety and Health. Publication no. 84-100, method 1550.
NIOSH. 1987. Current Intelligence Bulletin #48: Organic solvent neurotoxicity. Cincinnati, OH: National Institute for-Occupational Safety and Health. DHHS (NIOSH) publication no. 87-104.
*NIOSH. 1990. NIOSH pocket guide to chemical hazards. Washington, DC: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health. DHHS (NIOSH) publication no. 90-117.
*NIOSH. 1992a. NIOSH recommendations for occupational safety and health: Compendium of policy documents and statements. Cincinnati, OH: National Institute for Occupational Safety and Health. DHHS(NIOSH) publication no. 92-100.
NIOSH. 1992b. Health hazard evaluation report HETA 91-051-2177, AVX Corporation, Myrtle Beach, South Carolina. Cincinnati, OH: National Institute for Occupational Safety and Health, Hazard Evaluations and Technical Assistance Branch. Report no. 91-051.
*NOES. 1992. National Occupational Exposure Survey. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, Division of Surveillance, Hazard Evaluations and Field Studies.
*Nouri L, Al-Rahim K. 1970. Kerosene poisoning in children. Postgrad Med J 46(532):71–75.5416507
*Olson BA. 1982. Effects of organic solvents on behavioral performance of workers in the paint industry. Neurobehav Toxicol Teratol 4:703–708.7170031
*Olson MJ, Johnson JT, Reidy CA. 1990. A comparison of male rat and human urinary proteins: Implications for human resistance to hyaline droplet nephropathy. Toxicol Appl Pharmacol 102:524–536.1690459
Ono Y, Takeuchi Y, Hisanaga N, . 1982. Neurotoxicity of petroleum benzine compared with n-hexane. Int Arch Occup Environ Health 501219–229.
Orbaek P, Risberg J, Rosen I, . 1985. Effects of long-term exposure to solvents in the paint industry. Stand J Work Environ Health 11: 1–28.
OSHA. 1989a. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000.
OSHA. 1989b. Air contaminants. Occupational Safety and Health Administration. Federal Register 54:2920–2960.
*OSHA. 1993. Air contaminants. Occupational Safety and Health Administration. Federal Register 58(124):35338–35351.
*Ostergaard G, Lam H, Ladefoged O, . 1993. Effects of six months’ white spirit inhalation exposure in adult and old rats. Pharmacol Toxic01 72:34–39.
*Otson R, Williams DT, Bothwell PD. 1983. Charcoal-tube technique for simultaneous determination of selected organics in air. Am Ind Hyg Assoc J 44~489–494.
Overby ST, DeBano LF. 1990. New technique for measuring volumetric shrinkage in soils. Soil Science Society of America Journal 54: 1797–1799.
*Pedersen LM, Cohr’ K-H. 1984a. Biochemical pattern in experimental exposure of humans to white spirit: 1. The effects of a 6 hours single dose. Acta Pharmacol Toxicol 55:317–324.
*Pedersen LM, Cohr K-H. 1984b. Biochemical pattern in experimental exposure of humans to white spirit: 2. The effects of repetitive exposures. Acta Pharmacol Toxicol 55:325–330.
Pedersen LM, Rasmussen JM. 1982. The hematological and biochemical pattern in occupational organic solvent poisoning and exposure. Int Arch Occup Environ Health 51: 113–126.7160912
*Pedersen LM, Larsen K, Cohr C-H. 1984. Kinetics of white spirits in human fat and blood during short-term experimental exposure. Acta Pharmacol Toxicol 55:308–316.
*Pedersen LM, Rasmussen S, Cohr C-H. 1987. Further evaluation of the kinetics of white spirits in human volunteers. Pharmacol Toxicol 60: 135–B39.3575247
*Persidsky DJ, Wilde SA. 1956. Effect of eradicants on the microbiological properties of nursery soils. Wisconsin Academy of Sciences, Arts and Letters 44:65–73.
Persson B, Dahlander A-M, Frediksson M, . 1989. Malignant lymphomas and occupational exposure. Br J Ind Med 46:516–520.2775671
*Persson B, Fredriksson M, Olsen K, . 1993. Some occupational exposures as risk factors for malignant lymphomas. Cancer 72:1773–1778.8348507
Petrone RL. 1988. Cancer mortality among petroleum solvent exposed Oklahoma dry cleaners. Diss Abstr Int [B] 48:1955.
*Pfaffli P, Harkonen H, Savolainen H. 1985. IJrinary dimethylbenzoic-acid excretion as an indicator of occupational exposure to white spirit. Journal of Chromatography, Biomedical Applications 337:146–150.3980645
*Phillips RD. 1983. Effect of Stoddard solvent on kidney function and structure of Fischer 344 and Sprague-Dawley rats. In: Proceedings of the 13th Conference on Environmental Toxicology, Wright-Patterson Air Force Base, Nov. 16–18, 1982. Springfield, VA: Air Force Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command, 328–336.
*Phillips SC. 1984. A review of the human kidney effects of hydrocarbon exposure. In: Mehlman MA, Hemstreet GP, Thorpe JJ, . eds. Renal effects of petroleum hydrocarbons: Advances in modem environmental toxicology. Vol. VII. Princeton NJ: Princeton Scientific Publishers, Inc., 185–202.
*Phillips RD, Cockrell BY. 1984. Kidney structural changes in rats following inhalation exposure to Cl0-Cl1 isoparaffinic solvent. Toxicology 331261–273.
Phillips RD, Egan GF. 1981. Teratogenic and dominant lethal investigation of two hydrocarbon solvents [Abstract]. Toxicologist 1: 15.
*Phillips RD, Egan GF. 1984a. Effect of C10-C11 isoparaffinic solvent on kidney function in Fischer 344 rats during eight weeks of inhalation. Toxicol Appl Pharmacol 73:500–510.6719465
*Phillips RD, Egan GF. 1984b. Subchronic inhalation exposure of dearomatized white spirits and Cl0-Cl1 isoparaffinic hydrocarbon in Sprague-Dawley rats. Fundam Appl Toxicol 4:808–818.6510613
Poklis A, Burkett CD. 1977. Gasoline sniffing: A review. Clin Toxicol 11:35–41.872539
Polakowska B. 1986. [Functional disorders of the nervous system of female workers in the rubber industry exposed to benzine vapors.] Med Pr 37:42–46. (Polish)3724438
*Porter HO. 1990. Aviators intoxicated by inhalation of JP-5 fuel vapors. Aviat Space Environ Med 61(7):654–656.2386453
Pottern LM, Heineman EF, Olsen JH, . 1992, Multiple myeloma among Danish women Employment history and workplace exposures. Cancer Causes and Control 3:427–432.1525323
*Prager D, Peters C. 1970. Development of aplastic anemia and the exposure to Stoddard solvent. Blood 35:286–287.5437679
Quinet B, Begue P, Baron S. 1987. [Specificities of pediatric poisoning.] J Pharm Clin 6:421–428.
(French) Radujkov Z, Ristic L, Mihajlov A, . 1982. [The incidence of hyperlipoproteinemia in workers involved in the manufacture of naphtha and gas.] Med Pregl 35:27–31. (Serbo-Croatian)7121412
*Rambausek MH, Waldherr R, Ritz E. 1993. Immunogenetic findings in glomernlonephritis. Kidney International Vol. 43, Supp. 39, pp. S-3–S-8.7902466
Ramirez G. 1990. Occupational exposure to organic solvents [letter; comment]. Arch Intern Med. 150:919.
Ratnoff WD, Gress RE. 1980. Familial occurrence of polycythemia Vera: Report of a father and son, with consideration of the possible etiologic role of exposure to organic solvents, including tetrachloroethylene. Blood 56:233–236.7397379
Ravnskov U, Forsberg B, Skerfving S. 1979. Glomerulonephritis and exposure to organic solvents. Acta Med Scan 205:575–579.
*Raymond RL, Hudson JO, Jamison VW. 1975. Assimilation of oil by soil bacteria. Proceeding of the American Petroleum Institute, Refining Department, 40th Mid-Year Meeting, Volume 54. Washington, DC: American Petroleum Institute, 429–455.
*Raymond RL, Hudson JO, Jamison VW. 1976. Oil degradation in soil. Appl Environ Microbial 31(4):522–535.
*Rector DE, Steadman BL, Jones RA, . 1966. Effects on experimental animals of long-term inhalation exposure to mineral spirits. Toxicol Appl Pharmacol 9:257–268.4961358
*Riley AJ, Collings AJ, Browne NA, . 1984. Responses of the upper respiratory tract of the rat to white spirits vapor. Toxicol Lett 22: 125–132.6474504
*Rothman N, Emmett EA. 1988. The carcinogenic potential of selected petroleum-derived products. Occupational Medicine: State of the Art Review 3:475–494.
*Saffioti U, Shubik P. 1963. Studies on promoting action in skin carcinogenesis. Monogr Natl. Cancer Inst 10:489–507.
*Sato A, Nakajima T. 1987. Pharmacokinetics of organic solvent vapors in relation to their toxicity. Scand J Work Environ Health 13:81–93.3299685
Savolainen H, Pfaffli P. 1982. Neurochemical effects of extended exposure to white spirits vapour at three concentration levels. Chem Biol Interact 39:101.7060217
*Sax NI, Lewis RJ. 1989. Dangerous properties of industrial materials. Seventh edition” Volume III. New York, NY: Van Nostrand Reinhold Co., 3117.
*Scheffers TML, Jongeneelen FJ, Bragt PC. 1985. Development of effect-specific limit values (ESLVs) for solvent mixtures in painting. Ann Occup Hyg 29:191–199.
Schreiner CA. 1983, Petroleum and petroleum products: A brief review of studies to evaluate reproductive effects. In: Christian MS, Galbraith WM, Voytek P, . eds. Advances in modern environmental toxicology. Vol. 3: Assessment of reproductive and teratogenic hazards. Princeton NJ: Princeton Scientific Publishers, Inc., 29–45.
*Schreiner CA, Edwards DA, McKee RH, . 1989. The mutagenic potential of high flash aromatic naphtha. Cell Biol Toxicol 5:169–188.2670086
*Scott JL, Cartwright GE, Wintrobe MM. 1959. Acquired aplastic anemia - an analysis of thirty-nine cases and review of the pertinent literature. Medicine 38:119–172.13656164
Seppalainen AM, Husman K, Martenson C. 1978. Neurophysiological effects of long-term exposure to a mixture of organic solvents. Stand J Work Environ Health 4:304–314.
*Shapiro LE, Sachchidananda J. 1982. Regulation of proteins by thyroid hormone and glucocorticoid: The responses of hepatic α_2μ_- globulin and pituitary growth hormone differ in adult male hypothyroid rats. Endocrinology 8:653–660.
Shirkey HC. 1971. Treatment of petroleum distillate ingestion. Mod Treat 8:580–592.4941270
*Short BG, Burnett VL, Cox MG, . 1987. Site-specific renal cytotoxicity and cell proliferation in male rats exposed to petroleum hydrocarbons. Lab Invest 57:564–577.3682766
*Sice J. 1966. Tumor-promoting activity of n-alkanes and 1-alkanols. Toxic01 Appl Pharmacol 9:70–74.
*Siemiatycki J, Dewar R, Nadon L, . 1987. Associations between several sites of cancer and twelve petroleum-derived liquids: Results from a case-referent study in Montreal. Scand J Work Environ Health 13:493–504.3433051
Spencer PS, Schaumburg HH. 1985. Organic solvent neurotoxicity facts and research needs. Stand J Work Environ Health 11(Suppl. 1):53–60.
*Spirtas R, Stewart PA, Lee JS, . 1991. Retrospective cohort mortality study of workers at an aircraft maintenance facility: I. Epidemiological results. Br J Ind Med 48:515–530.1878308
Starek A, Golba W. 1984. [Analysis of naphtha vapors in the air by gas chromatography.] Med Pr 35:373–8. (Polish)6530955
*State of Alaska. 1989. Alaska water quality standards. Juneau, AL: Alaska Administrative Code, Water Quality Standards, Amended 12/89. Alaska Title 18, Chapter 70.
*State of Arkansas. 1991. Regulation no. 2 as amended water quality standards for surface waters of the State of Arkansas Little Rock, AK: Water Quality Standards for Surface Waters of the State of Arkansas.
*State of Florida. 1992. Florida Water Quality Standards 1992. Tallahassee, FL: Florida Water Quality Standards 17.-3.
*State of Nebraska. 1990. Nebraska water quality standards 1990. Lincoln, NE: Nebraska Water Quality Standards for Surface Waters of the State, revised effective 1 l/90. Nebraska State, Title 117.
*State of South Dakota. 1992. South Dakota water quality standards 1992. Bismarck, SD: South Dakota Surface Water Quality Standards, 10/92. Chapter 74:03:17.
*State of Wyoming. 1990. Wyoming water quality rules and regulations. Cheyenne, WY: Wyoming Water Quality Standards. Cheyenne, WY: Wyoming Department of Environmental Quality, Water Quality Standards for Wyoming Surface Waters, Chapter I.
Stewart PA, Lee JS, Marano DE, . 1991. Retrospective cohort mortality study of workers at an aircraft maintenance facility: 2. Exposures and their assessment. Br J Ind Med 48:531–537.1878309
Stewart RD, Erley DS, Schaffer AW, . 1961. Accidental vapor exposure to anesthetic concentrations of a solvent containing tetrachloroethylene. Industrial Medicine and Surgery 30(8):327–330.
Strassner HT, Amolds CW. 1992. Environment and pregnancy. In: Elkayam U, Galbraith RM, Gall SA, . eds. Principles and practice of medical therapy in pregnancy. 2nd ed. Norwalk CT: Appleton & Lange, 89–105.
Stricoff RS. 1983. Control of occupational health hazards in the dry cleaning industry. Instructor’s guide. Washington, DC.: U.S. Department of Health and Human Services, Division of Training and Manpower Development, National Institute for Occupational Safety and Health, 68.
Stubblefield WA, McKee RH, Kapp RW Jr, . 1989. An evaluation of the acute toxic properties of liquids derived from oil sands. J Appl Toxicol 9:59–65.2926098
*Stutz DR, Janusz SJ. 1988. Hazardous materials injuries: A handbook for pre-hospital care. 2nd ed. Beltsville, MD: Bradford Communications Corporation, 360–361.
*Suntech Group. 1978. Written communication (February 23) to C. E. Holdworth, American Petroleum Institute, regarding Stoddard solvent analysis. American Petroleum Institute, Washington, DC.
*Swenberg JA, Short B, Borghoff S, . 1989. The comparative pathobiology of α_2μ_- globulin nephropathy. Toxicol Appl Pharmacol 97:35–46.2464861
*Tagami H, Ogino A. 1973. Kerosine dermatitis: Factors affecting skin irritability to kerosine. Dermatologica 146(2): 123–131.4711878
*Takeuchi Y, Mabuchi C, Takagi S. 1975. Polyneuropathy caused by petroleum benzine. Int Arch Arbeitsmed 34:185–198.1184199
*Tegeris JS, Balster RL. 1994. A comparison of the acute behavioral effects of alkylbenzenes using a functional observational battery in mice. Fund Appl Toxicol 22:240–250.
*Tenenbein M, deGroot W, Rajani KR. 1984. Peripheral neuropathy following intentional inhalation of naphtha fumes. Can Med Assoc J 131:1077–1079.6093978
*Thomas DH, Delfino JJ. 1991. A gas-chromatographic/chemical indicator approach to assessing ground water contamination by petroleum products. Ground Water Monitoring Review 11(4):90–100.
Thorpe JJ. 1988. 1. Occupational medicine in the petroleum industry: An historical perspective. Occupational Medicine: State of the Art Reviews 3(3):371–390.
*TRI90. 1992. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
Triebig G. 1989. Occupational neurotoxicology of organic solvents and solvent mixtures. Neurotox Teratol 11:575–578.
*Tuohimaa P, Wichmann L. 1981. Sperm production of men working under heavy-metal or organic-solvent exposure. In: Hemminki K, Sorsa M, Vainio H, eds. Occupational hazards and reproduction. Washington DC: Hemisphere Publishing Corp., 73–79.
Valciukas JA, Lilis R, Singer R, . 1985. Neurobehavioral changes among shipyard painters exposed to solvents. Arch Environ Health 40:47–52.3994417
*Van H, Deyrup CA, eds. 1992. OPD chemical buyers directory. 79th annual edition. New York NY: Schnell Publishing Company, Inc., 746.
*van der Laan G. 1980. Chronic glomerulonephritis and organic solvents. Int Arch Occup Environ Health 47:1–8.7429643
van der Wal JF, Moerkerken A. 1984. The performance of passive diffusion monitors for organic vapours for personal sampling of painters. Ann Occup Hyg 28:39–47.6721337
*Van Doren G, Mertens B, Heyns W, . 1983. Different forms of α_2μ_- globulin in male and female rat urine. Eur J Biochem 134:175–181.6190651
*Van Duuren BL, Goldschmidt BM. 1976. Carcinogenic and tumor-promoting agents in tobacco carcinogenesis. J Nat1 Cancer Inst 56(6):1237–1242.
van Ert MD, Harris RL, Symons MJ, . 1980. Worker exposures to chemical agents in the manufacture of rubber tires: Solvent vapor studies. Am Ind Hyg Assoc J 41:212–219.7395732
Vaziri ND, Smith PJ, Wilson A. 1980. Toxicity with intravenous injection of naphtha in man Clin Toxicol 16:335–343.7398221
*Verkkala E, Pfaffli P, Savolainen H. 1984. Comparison of local neurotoxicity of three white spirits formulations by percutaneous exposure of rat tail nerve. Toxicol Lett 21:293–299.6740717
*Vernot EH, Drew RT, Kane ML. 1990. Acute toxicologic evaluation of unleaded motor gasoline. Acute Toxic Data 1:28. [Abstract]
*Viau C, Bernard A, Gueret F, . 1986. Isoparaffinic solvent-induced nephrotoxicity in the rat. Toxicology 38:227–240.2418536
*Viau C, Bernard A, Lauwerys R. 1984. Distal tubular dysfunction in rats chronically exposed to a ‘white spirit’ solvent. Toxicol Lett 21:49–52.6719487
WHO. 1982. Environmental health criteria 20: Selected petroleum products. Geneva, Switzerland: United Nations Environment Programme, International Labour Organization, World Health Organization.
*WHO. 1991. Environmental health criteria 119: Principles and methods for the assessment of nephrotoxicity associated with exposure to chemicals. Geneva, Switzerland: United Nations Environment Programme, International Labour Organization, World Health Organization.
Wilcosky TC, Checkoway H, Marshall EG, . 1984. Cancer mortality and solvent exposures in the rubber industry. Am Ind Hyg Assoc J 45(12):809–811.6549104
*Wolfsdorf J, Kundig H. 1972. Kerosene poisoning in primates. S Afr Med J 46(20):619–621.4625017
Wright J, Shen Z, Rizkalla S. 1993. A three-year field and laboratory evaluation of linseed oil as a concrete sealer. Can J Civ Eng 20:844–854.
*Yaqoob M, Bell GM, Percy DF, . 1992. Primary glomerulonephritis and hydrocarbon exposure: A case-control study and literature review. Quarterly Journal of Medicine, New Series 83(301):409–418.
*Zahlsen K, Eide I, Nilsen AM, . 1992. Inhalation kinetics of C6 and C10 aliphatic, aromatic and naphthenic hydrocarbons in rat after repeated exposures. Pharmacol Toxic01 71: 144–149.
*Zahlsen K, Nilsen AM, Eide I, . 1990. Accumulation and distribution of aliphatic (n-nonane), aromatic (1,2,4-trimethylbenzene) and naphthenic (1,2,4-trimethylcyclohexane) hydrocarbons in the rat after repeated inhalation. Pharmacol Toxicol 67:436–440.2096387
Zimmerman SW, Groehlerk, Beime GJ. 1975. Hydrocarbon exposure and chronic glomemlonephritis. Lancet: Aug 2, 1975.