# 7 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding Stoddard solvent in air, water, and other media are summarized in Table 7-1.

There is no EPA reference dose (RfD) or reference concentration (RfC) for Stoddard solvent. Stoddard solvent contains volatile organic compounds (VOC) and may be regulated under the Clean Air Act guidelines for reduction of VOC emissions from solvents (Clean Air Act 1990).

Under the Hazardous Materials Transportation Act, Stoddard solvent is designated as a hazardous substance subject to special requirements for packaging, labeling, and transportation (DOT 1989a, 1989b).

TABLE 7-1 Regulations and Guidelines Applicable to Stoddard Solvent

Agency | Description | Information | References
[underlined: INTERNATIONAL]
IARC | Carcinogenic classification for occupational exposures in petroleum refining | Group 2A^a^ | IARC 1989
[underlined: NATIONAL]
Regulations:
a. Air:
OSHA | PEL TWA | 500 ppm (2900 mg/m^3^)^b^ | OSHA 1993
b. Other:
DOT | Hazardous Material Transportation Act: Stoddard solvent is designated as a hazardous material which is subject to requirements for packaging, shipping, and transporting. | Yes | DOT 1989a (49 CFR 172.101; Appendix A); DOT 1989b
[underlined: Guidelines:]
a. Air:
ACGIH | TLV TWA | 100 ppm (525 mg/m^3^)^b^ | ACGIH 1991
AFOSH | PEL TWA | 100 ppm (577 mg/m^3^)^c^ | Air Force 1989b
AFOSH | STEL (15 minutes) | 150 ppm (866 mg/m^3^)^c^ | Air Force 1989b
NIOSH | REL TWA | 60 ppm (350 mg/m^3^)^b^ | ACGIH 1991; NIOSH 1992a
NIOSH | Ceiling REL (15 minutes) | 310 ppm (1,800 mg/m^3^)^b^ | ACGIH 1991; NIOSH 1992a
b. Other:
EPA | Clean Air Act: Reduction in emissions of volatile organic compounds from solvents | Yes | Clean Air Act 1990
[underlined: STATE:]
Regulations and Guidelines:
a. Air: | Acceptable Ambient Air Concentrations | | NATICH 1991
Connecticut | (8 hours) | 7.00 mg/m^3^
Florida-Pinellas | (8 hours) | 5.25 mg/m^3^
Florida-Pinellas | (24 hours) | 1.26 mg/m^3^
Nevada | (8 hours) | 12.5 mg/m^3^
North Dakota | (8 hours) | 5.25 mg/m^3^
Oklahoma | (24 hour) | 35.0 mg/m^3^
Texas | (30 minutes) | 3.50 mg/m^3^
Texas | (Annual) | 0.35 mg/m^3^
Vermont | (Annual) | 12.5 mg/m^3^
Virginia | (24 hours) | 8.80 mg/m^3^
| Regulations on hydrocarbon emissions (petroleum distillates) | Yes | CELDS 1991
Connecticut
Kansas
Wisconsin
| Regulations on VOC emissions | Yes | CELDS 1991
Alabama
Arizona
Florida
Maine
Maryland
Michigan
New Jersey
South Carolina
Texas
Virginia
Washington, D.C.
b. Water:
Alaska | Aquatic life criterion for total hydrocarbons in marine and surface waters | 15 μg/L | State of Alaska 1989
| Aquatic life criterion for aromatic hydrocarbons in marine and surface waters | 10 mg/L | State of Alaska 1989
Arkansas | Average or maximum allowable quantity of oil or grease discharged into surface waters | 10 mg/L (average); 15 mg/L (maximum) | State of Arkansas 1991
Florida | Average or maximum allowable quantity of oil or grease discharged into Class V waters (navigation, industrial use) | 10 mg/L | State of Florida 1992
Florida | Average or maximum allowable quantity of oil or grease discharged into all other surface waters | 5 mg/L | State of Florida 1992
Massachusetts | Maximum discharge concentration of oil or grease of petroleum origin in surface waters | 15 mg/L | Commonwealth of Massachusetts 1990
Nebraska | Maximum petroleum oil concentration in surface waters | 10 mg/L | State of Nebraska 1990
South Dakota | Water quality standard for all petroleum products in surface waters | 10 mg/L | State of South Dakota 1992
Virginia | Water quality standard for petroleum hydrocarbons in groundwater | 1 mg/L | Commonwealth of Virginia 1990
Wyoming | Water quality standard for all surface water classes | 10 mg/L | State of Wyoming 1990
c. Other:
| Regulations on the transport of flammable/hazardous liquids (petroleum distillates or VOCs) | Yes | CELDS 1991
Colorado
Maryland
Massachusetts
Wisconsin
Maine | Regulations on the disposal of special wastes including diesel fuels | Yes | CELDS 1991
California | Regulations on leaking underground fuel tanks | Yes | CELDS 1991

a Group 2A = probably carcinogenic to humans; this classification applies only to occupational exposures in petroleum refining.

b Values were provided in both ppm and mg/m^3^ in the reference.

c Values were provided in ppm in the reference; values in mg/m^3^ were calculated using a conversion factor provided in the reference.

ACGIH = American Conference of Governmental Industrial Hygienists; AFOSH = Air Force Office of Safety and Health; CELDS = Computer-Environmental Legislative Data Systems; DOT = Department of Transportation; EPA = Environmental Protection Agency; IARC = International Agency for Research on Cancer; NIOSH = National Institute for Occupational Safety and Health; OSHA = Occupational Safety and Health Administration; PEL = Permissible Exposure Limit; REL = Recommended Exposure Limit; STEL = Short-Term Exposure Limit; TLV = Threshold Limit Value; TWA = Time-Weighted Average; VOC = volatile organic compound