# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Information regarding the chemical identity of Stoddard solvent is located in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of Stoddard solvent is located in Table 3-2.

Stoddard solvent is a petroleum distillate mixture of C_7_-C_12_ hydrocarbons. The mixture consists of three major groups of components: linear and branched alkanes, also known as paraffins (30-50% of the total mixture); cycloalkanes, also called cycloparaffins or naphthenes (not to be confused with naphthalenes which are bicyclic aromatics) (30-40%), and aromatic hydrocarbons (10-20%) (Air Force 1989b; McDermott 1975). Stoddard solvent is a refinery blend of differently treated oil fractions. Its composition varies somewhat, depending on the refinery and the time of production. Table 3-3 lists some of the major components of several Stoddard solvent formulations. Petroleum distillates are often distinguished by boiling or distilling temperatures. Stoddard solvent has a boiling range of 150-200°C (Scott et al. 1959). The 140 flash Stoddard solvent is composed of C_5_-C_12_ hydrocarbons and has a boiling range of 185-207°C (Air Force 1989b). White spirits is a term somewhat synonymous with Stoddard solvent since it has a hydrocarbon range between C_7_ and C_11_. Six types of white spirits have been identified based on origin. Each type consists of the same components, but the percentages vary (Scheffers et al. 1985). Possible contaminants of Stoddard solvent include lead (<1 ppm) and sulfur (3.5 ppm) (Suntech 1978).

There are a number of related chemical mixtures with components that are different from those of Stoddard solvent. For instance, high-flash aromatic naphtha is a generic term for petroleum distillates primarily consisting of C_9_ aromatics (70-80%) with C_8_ or C_10_ aromatics comprising the rest. Stoddard solvent, in contrast, is only 10-20% aromatic (Clark et al. 1989b; Schreiner et al. 1989). Naphtha is also a general term for petroleum distillates containing predominantly C_5_-C_13_ aliphatic hydrocarbons and distilling at 30-238°C (Tenenbein et al. 1984).

TABLE 3-1 Chemical Identity of Stoddard Solvent

Characteristic | Information | Reference
Chemical name | Stoddard solvent | Sax and Lewis 1989
Synonym(s) | Dry cleaning safety solvent, naphtha safety solvent, PD-680, petroleum solvent, spotting naphtha, varnoline, white spirits | Air Force 1989b; NIOSH 1989; Sax and Lewis 1989
Registered trade name(s) | Texsolve S, Varsol 1 | Buda van et al. 1989; Hunter et al. 1992
Chemical formula | Not applicable^a^
Chemical structure | Not applicable^a^
Identification numbers:
CAS registry | 8052-41-3 | Sax and Lewis 1989
NIOSH RTECS | WJ8925000 | NIOSH 1990
EPA hazardous waste | No data
OHM/TADS | No data
DOT/UN/NA/IMCO shipping | 1268 27 | NIOSH 1990
HSDB | No data
NCI | No data

a Stoddard solvent is a mixture of C_7_-C_12_ hydrocarbons primarily containing straight and branched chain alkanes (30-50%), cycloalkanes (30-40%), and alkyl aromatic hydrocarbons (10-20%) (Air Force 1989b; McDermott 1975). See also Table 3-3.

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

TABLE 3-2 Physical and Chemical Properties of Stoddard Solvent

Property | Information | Reference
Molecular weight | 144 (mean); 135-145 (range) | Air Force 1989b; Carpenter et al. 1975b
Color | Clear, colorless | Sax and Lewis 1989
Physical state | Liquid | Sax and Lewis 1989
Melting point | No data
Boiling point | 154-202°C | Air Force 1989b
Boiling point | 160-199°C | Coast Guard 1985
Density:
at 20°C | 0.78 g/mL | NIOSH 1990
Odor | Similar to kerosene | NIOSH 1990
Odor threshold | 0.9 ppm (5.1 mg/m^3^) | Carpenter et al. 1975b
| 2 mg/m^3^ | Hastings et al. 1984
Solubility:
Water | Insoluble | McDermott 1975
Organic solvent(s) | Absolute alcohol, benzene, ether, chloroform, carbon tetrachloride, carbon disulfide | Sax and Lewis 1989
Partition coefficients:
Log K_ow_ | 3.16-7.06 | Air Force 1989b
Log K_oc_ | 2.85-6.74 | Air Force 1989b
Vapor pressure at 25°C | 4-4.5 mmHg | McDermott 1975
Henry’s law constant:
at 20°C | 4.4×10^−4^-7.4×10° atm-m^3^/mol | Air Force 1989b
Autoignition temperature | 232°C | Sax and Lewis 1989
Flashpoint | 37.8-60.0°C | Air Force 1989b
Flashpoint | 38-43°C | Sax and Lewis 1989
Flammability limits:
% volume in air at 25°C | 0.9-6.0 | Carpenter et al. 1975b
Conversion factors:
at 25°C and 760 mm | 1 mg/L = 174.6 ppm; 1 ppm = 5.73 mg/m^3^ | Carpenter et al. 1975b
at 25°C | 1 ppm = 5.77 mg/m^3^ | Air Force 1989b
Explosive limits | | McDermott 1975
Lower limit | 0.9%
Upper limit | 6%

TABLE 3-3 Possible Formulations of Stoddard Solvent (Percent)

Hydrocarbons | White Spirits 1^a^ | White Spirits 2^a^ | White Spirits 3^a^ | Stoddard solvent^b^ (regular) | Stoddard solvent^b^ (140 flash) | Stoddard solvent^c^ | Stoddard solvent^d^ | Stoddard solvent^e^
Alkanes (paraffins) | 60.0 | 61.0 | 62.8 | 30-50 (48 average) | 60.8 | 34.9 | 41.6 | 47.7
n-nonane | 11.3 | 13.3 | 1.9
n-decane | 7.6 | 10.0 | 9.1
methylnonanes | 4.9 | 7.9
2,6-dimethyloctane | 2.7 | 4.1
n-undecane | 2.7 | 2.4 | 17.5
dodecanes | | | 11.6
terdecanes | | | 2.7
others | 30.8 | 23.3
Cycloalkanes (cycloparaffins) | 39.7 | 27.3 | | 30-40 (38 average) | 35.7 | | 39.5 | 37.6
monocycloparaffms | 16.3 | 13.7 | | | 24.5 | 34.9 | 27.9 | 26.0
trimethylcyclohexane | 4.7 | 7.2
tert-butylcyclohexane | 4.5 | 4.0
n-butylcyclopentane | 5.0 | 1.3
n-butylcyclohexane | 2.1 | 1.2
other cycloparaffins | 23.4 | 13.1
dicycloparaffms | | | | | 11.2 | 5.0 | 11.6 | 11.6
tricycloparaffins | | | | | | 0.4 | 0.0
acenaphthenes | | | | | | 0.4
Aromatics | 0.3 | 11.7 | 17.0 | 10-20 (14.1 average) | 3.40 | | 18.9
alkylbenzenes | | | | 14.0 | 3.03 | 22.0 | 17.6 | 14.1
dimethylethylbenzenes | 0 | 3.0
n-propylbenzene | 0 | 2.0
ethyltoluenes | 0 | 1.2
1,2,4-trimethylbenzene | 0 | 0.9
other aromatics | 0.3 | 4.6 | | | | 1.1
other benzenes | | | | 0.1 | 0.07 | | | 0.1
indans/tetralins | | | | <1 | 0.3 | 1.8 | 1.3 | 0.5
indenes | | | | | | 0.1
naphthalenes | | | | | | 0.2
acenaphthalenes | | | | | | 0.3
tricyclicaromatics | | | | | | 0.1

a Adapted from Verkkala et al. (1984)

b Adapted from Air Force (1989b)

c Adapted from American Petroleum Institute (1976)

d Adapted from Suntech Group (1978); API 1978a

e Adapted from Carpenter et al. (1975b); this paper also includes a mass spectral analysis of components by carbon number within a hydrocarbon class, e.g.C_8_ alkanes.

Benzine and mineral spirits (other associated mixtures) are similar to but not exactly the same as Stoddard solvent. Benzine consists of C_5_-C_9_ hydrocarbons (Takeuchi et al. 1975) and boils, on average, at between 154°C and 204°C (Navarte et al. 1989). Benzine and Stoddard solvent distill at about the same temperature range, but their hydrocarbon compositions differ. Mineral spirits have a distillation range of 136-277°C. The distillation range of Stoddard solvent falls within that of mineral spirits (Mehlman and Smart 1982). Therefore, Stoddard solvent may be considered a subset of mineral spirits, but mineral spirits as a whole are not described in this profile.