# 8 REFERENCES

*Cited in text.

*Aaseth J, Olsen A, Halse J, . 1981. Argyria-tissue deposition of silver as selenide. Stand J Clin Lab Invest 41:247–251.
Abdel Rahim AG. 1985. The effects of dietary L-ascorbic acid on the absorption and utilization of Na75Se03 of silver-treated rats. Comp Biochem Physiol 81C:131–132.
*ACGIH. 1986. Documentation of the threshold limit values and biological exposure indices. 5th ed. American Conference of Governmental Industrial Hygienists, Inc., Cincinnati, OH, 529.
*Alexander J, Aaseth J. 1981. Hepatobiliary transport and organ distribution of silver in the rat as influenced by selenite. Toxicology 21:179–186.7292506
*Alexander J, Aaseth J, Refsvik T. 1980. Biliary excretion of glutathione in the rat-significance for the biliary excretion of heavy metals [Abstract]. Naunyn-Schmiedeberg Arch Pharmacol 313:R66.
Andelman JB. 1973. Incidence, variability and controlling factors for trace elements in natural, fresh waters. In: Singer PC, ed. Trace metals and metal-organic interactions in natural waters. Ann Arbor, MI: Ann Arbor Science Publishers Inc., 57–88.
*Anderson JB, Jenne EA, Chao TT. 1973. The sorption of silver by poorly crystallized manganese oxides. Gebchimica et Cosmochimica Acta 37:611–622.
Anghileri LJ. 1968. In vivo and in vitro deiodination of silver iodide. Experientia 24:895.5709023
Anghileri LJ. 1969. Studies on the in vivo breakdown of insoluble halides. Acta Isotope 9:347–356.
Aoki K, Hori J, Kawashima K. 1967. Effect of metallic cations on human serum: Study by starch-gel electrophoresis. II Effect of Hg++, Cr+++, Ag+, Ni++, Cd++, Zn++, Ba++, Mg++, Al+++ and Fe+++. Arch Biochem Biophys 120:255–267.4167044
Aronstam RS, Eldefrawi ME. 1979. Transition and heavy metal inhibition of ligand binding to muscarinic acetylcholine receptors from rat brain. Toxicol Appl Pharmacol 48:489–496.473192
Baba S, Shinohara Y, Sano H, . 1984. Application of high-performance liquid chromatography with synchronized accumulating radioisotope detector to analysis of glyceryl trinitrate and its metabolites in rat plasma. J Chromatog 305:119–126.6423655
*Bader KF. 1966. Organ deposition of silver following silver nitrate therapy of burns. Plast Reconstr Surg 37:550–551.5932415
*Baes CF III, Sharp RD. 1983. A proposal for estimation of soil leaching and leaching constants for use in assessment models. J Environ Qual 12:17–28.
Bailey JA, Jones AM, Roy DR. 1973. Effects of silver from cloud seeding on microflora of animal digestive systems. Report to US Bureau of Reclamation, Division of Atmospheric Water Resources Management, Denver, CO, by Department of Fishery and Wildlife Biology, Colorado State University, Fort Collins, CO. NTIS PB226-062.
Ballinger PM, Brown BS, Griffin MM, . 1982. Evidence for carriage of silver by sulphadimidine: Hemolysis of human erythrocytes. Br J Pharmacol 77:141–145.6751451
*Bard CC, Murphy JJ, Stone DL, . 1976. Silver in photoprocessing effluents. Water Pollut Cont Fed 48:389–394.
*Barnes D, Bellin J, DeRosa C, . 1987. Reference dose (RfD): Description and use in health risk assessments. Appendix A: Integrated risk information system supportive documentation. Washington, DC: US Environmental Protection Agency, Office of Health and Environmental Assessment. EPA/600/8-86-032a.
Barrie HJ, Harding HE. 1947. Argyro-siderosis of the lungs in silver finishers. Brit J Industr Med 4:225–232.
*Becker RO. 1987. The effect of electrically generated silver ions on human cells. In: Proceedings of the First International Conference on Gold and Silver in Medicine, Bethesda, Maryland, May 13-14, 1987. Washington, DC: The Gold and Silver Institutes, 227–243.
*Becker RO, Spadaro & 1978. Treatment of orthopedic infections with electrically generated silver ions. The Journal of Bone and Joint Surgery 60-A:871–881.
Bergmann M, Engel C. 1968. [Silver deposits in the gastric mucosa and liver in universal argyrosis due to treatment with tragesine]. Dtsch Gesundheitsw 23:629–31. (German).5682406
*Berry JP, Galle P. 1982. Selenium and kidney deposits in experimental argyria. Electron microscopy and microanalysis. Pathol Biol (Paris) 30:136–140.7048214
Bertine KK, Goldberg ED. 1971. Fossil fuel combustion and the major sedimentary cycle. Science 173 1233–235.
Bertine KK, Goldberg ED. 1972. Trace elements in clams, mussels, and shrimp. Limnology Oceanography 17:877–884.
Bessing C, Kallus T. 1987. Evaluation of tissue response to dental alloys by subcutaneous implantation. Acta Odontol Stand 45:247–255.
Biddinger GR, Gloss SP. 1984. The importance of trophic transfer in the bioaccumulation of chemical contaminants in aquatic ecosystems. Resi Rev 91:103–145.
Blaha K Jr, Havrdova J, Rosina J, . 1987. The effect of 110mAg on ceruloplasmin oxidase activity in rats. J Hyg Epidemiol Microbial Immunol 31139–43.
*Bleehen SS, Gould DJ, Harrington CI, . 1981. Occupational argyria; light and electron microscopic studies and x-ray microanalysis. Br J Dermatol 104:19–26.7459266
*Blumberg H, Carey TN. 1934. Argyremia: Detection of unsuspected and obscure argyria by the spectrographic demonstration of high blood silver. J Am Med Assoc 103:1521–1524.
*Bogen J. 1973. Trace elements in atmospheric aerosol in the Heidelberg area, measured by instrumental neutron activation analysis. Atmos Environ 7:1117–1125.
Boissevain CH, Drea WF. 1936. Relation between the occurrence of endemic goiter and the presence of traces of silver and barium in drinking water. Endocrinology 26:686–687.
Bourdon-Ranisteano S, Bourdon R, Prouillet F. 1977. [Determination of silver in biological materials]. Ann Biol Clin 35:397–400. (French).
*Boyle RW. 1968. Geochemistry of silver and its deposit notes on geochemical prospecting for the element. Geological Survey of Canada. Ottawa, Ont: Canada, Department of Energy, Mines and Resources. 160., 1–96.
Bradford GR, Bair FL, Hunsaker V. 1968. Trace and major element content of 170 High Sierra Lakes in California. Limnology and Oceanography 13:526–530.
Braidech MM, Emery FH. 1935. The spectrographic determination of minor chemical constituents in various water supplies in the United States. J Amer Water Works Assoc 27:557–580.
Brar SS, Nelson DM, Kline JR, . 1970. Instrument analysis for trace elements present in Chicago area surface air. Journal of Geophysics Research 75:2939–2945.
Braunstein HM, Pack DJ, Oakes TW. 1982. Intercomparison of stable element content of foods by statistical methods. Proc Univ MO Annu Conf Trace Subst Environ Health. 16:377–390.
Breton J, Foncin JF, Caroff J, . 1971. [Argyria and argyrism: Two unusual cases. Value of electron microscopy and derived methods]. Med Leg Dommage Corp 4:245–248. (French).
*Brody AR, Vallyathan NV, Craighead JE. 1978. Use of scanning electron microscopy and x-ray energy spectrometry to determine the elemental content of inclusions in human tissue lesions. Scanning Microsc 2:615–622.
Brooks SM. 1981. Lung disorders resulting from the inhalation of metals. Clin Chest Med 2:235–254.7030604
Brooks SM. 1986. Pulmonary reactions to miscellaneous mineral dusts, man-made mineral fibers, and miscellaneous pneumoconioses. In: Merchant JA, ed. Occupational respiratory diseases. Morgantown, WV: US Department of Health and Human Services, Division of Respiratory Disease Studies, 401–458.
Brozman M, Chorvath D, Jakubovsky J. 1976. [Localization of silver in glomerular basement membranes in experimental argyrosis]. Bratisl Lek Listy 66:253–263. (Polish).
Bruevich TS, Bogomolets NN, Berezovskii AD. 1980. [Sensitizing.action of precious metal compounds: Gold, platinum, ruthenium, rhodium and silver]. Gig Tr Prof Zabol:42–44. (Russian).
Brulaud KW, Bertine K, Koide M, . 1974. History of metal pollution in the Southern California coastal zone. Environ Sci Technol 8:425–432.
Brune D, Beltesbrekke H. 1979. Levels of mercury and silver in dust from the trimming of amalgam dies. Scand J Dent Res 87:462–465.296569
Brune D, Nordberg G, Wester PO. 1980. Distribution of 23 elements in the kidney, liver and lungs of workers from a smeltery and refinery in north Sweden exposed to a number of elements and of a control group. The Science of the Total Environment 16:13–35.7433969
*Buckley WR. 1963. Localized argyria. Arch Dermatol 88:531–539.14060065
Buckley WR, Terhaar CJ. 1973. The skin as an excretory organ in argyria. Trans St John’s Hosp Dermatol Sot 59:39–44.
*Buckley WR, Oster CF, Fassett DW. 1965. Localized argyria: II. Chemical nature of the silver containing particles. Arch Dermatol 92:697–705.5846327
*Bunch RL. 1982. Sewage sludge dilemma of the eighties. In: Pawlowski L, ed. Physiochemical methods for water and wastewater treatment. Amsterdam: Elsevier. 69–81.
*Bunyan J, Diplock AT, Cawthorne MA, . 1968. Vitamin E and stress. 8. Nutritional effects of dietary stress with silver. Br J Nutr 22:165–182.5673539
Butt EM, Nusbaum RE, Gilmour TC, . 1964. Trace metal levels in human serum and blood. Arch Environ Health 8:60–65.
*Byrne CJ, DeLeon JR. 1986. Trace metal residues in biota and sediments from Lake Pontchartrain, Louisiana. Bull Environ Contam Toxicol 37:151–158.3719140
Cabe PA, Carmichael NG, Tilson HA. 1979. Effects of selenium, alone and in combination with silver or arsenic, in rats. Neurobeh Toxicol 1:275–278.
Caffee HH, Bingham HG. 1982. Leukopenia and silver sulfadiazine. J Trauma 22:586–587.7097818
*Calabrese A, MacInnes JR, Nelson DA, . 1984. Effects of long-term exposure to silver or copper on growth, bioaccumulation and histopathology in the blue mussel Mytilus edulis. Marine Environmental Research 11:253–274.
*Callahan MA, Slimak MW, Gabel NW, . R; 1979. Water-related environmental fate of 129 priority pollutants. EPA-440/4-79-029a,b.
Camner P, Lundborg M, Hellstrom P. 1974. Alveolar macrophages and 5 pm particles coated with different metals. Arch Environ Health 29:211–213.
Camner P, Hellstrom PA, Lundborg M, . 1977. Lung clearance of 4-µm particles coated with silver, carbon, or beryllium. Arch Environ Health 32:58–62.849011
Carson BL, Ellis HV III, McCann JL. 1986. Toxicology and biological monitoring of metals in humans. Chelsea, MI: Lewis Publishers, Inc., 219–225.
*Casto BC, Meyers J, DiPaolo JA. 1979. Enhancement of viral transformation for evaluation of the carcinogenic or mutagenic potential of inorganic metal salts. Cancer Res 39:193–198.570089
*Catsakis LH, Sulica VI. 1978. Allergy to silver amalgams. Oral Surg 46:371–375.278935
CELDS. 1989. Computer-Environment Legislative Data Systems. The Environmental Technical Information System (ETIS). Department of Urban and Regional Planning, Planning Information Program, University of Illinois, Urbana-Champaign, IL. January 6, 1989.
Cerrai E, Ghersini G. 1966. Reversed-phase paper chromatography of some cations with two nitrophenylthiophosphate derivatives as stationary phases. Chromatogr 22:425–430.
Charley RC, Bull AT. 1979. Bioaccumulation of silver by a multispecies community of bacteria. Arch Microbial 123:239–244.
*CHEMLINE 1988. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. December 5, 1988.
Cherian MG, Goyer RA, 1978. Role of metallothioneins in disease. Ann Clin Lab Sci 8:91–94.637518
Chien PT. 1979. Metallic copper and silver dust hazards … [editorial]. Am Ind Hyg Assoc J 40:747–748.495480
*CHMR 1989. Hazardous waste minimalization manual for small quantity generators. Center for Hazardous Materials Research, University of Pittsburgh Applied Research Center, Pittsburgh, PA.
Chorvath D, Brozman M, Jakubosky J. 1976. [Morphology of experimental argyrosis in kidneys]. Cesk Patol 4:161–165. (Czech).
CCRIS. 1988. Chemical Carcinogenesis Research Information System. Chemical Information System (CIS). December 5, 1988.
Clemente GF, Cigna Rossi L, Santaroni GP. 1977. Trace element intake and excretion in the Italian population. J of Radioanal Chem
*Coffin DL, Palekar LD. 1985. Bioassays for asbestos and other solid materials. In: Milman HA and Weisburger EK, ed. Handbook of Carcinogen Testing. Park Ridge, NJ: Noyes Publications, 384–419.
Coglianese MP, Martin M. 1981. Individual and interactive effects of environmental stress on the embryonic development of the pacific oyster, Crassostrea gigas. I. The toxicity of copper and silver. Mar Environ Res 5:13–27.
*Cole RJ, Frederick RE, Healy RP, . 1984. Preliminary findings of the priority pollutant monitoring project of the nationwide urban runoff program. Water Pollut Cont Fed 56:898–908.
*Coleman RL, Cearley JE. 1974. Silver toxicity and accumulation in largemouth bass and bluegill. Bull Environ Contam Toxicol 12:53–61.4433854
Connors RC, Daniels F Jr. 1973. Generalized argyria. Cutis 11:796–801.
*Constable J, Morris P, Burke J. 1967. Absorption pattern of silver nitrate from open wounds. Plast Reconst Surg 39:342–348.6022675
*Contract Laboratory Program Statistical Database. 1988. US Environmental Protection Agency, Contract Laboratory Program, Washington, DC.
*Cooper CF, Jolly WC. 1970. Ecological effects of silver iodide and other weather modification agents. Water Resource Research 6:88–98.
Costello J. 1983. Mortality of metal miners a retrospective cohort and case control- study. In: Wagner WL, Rom WN, Merchant JA, eds. Health issues related to metal and nonmetallic mining. Boston, MA: Butterworth Publishers, 227–240.
*Creasey M, Moffat DB. 1973. The deposition of ingested silver in the rat kidney at different ages. Experientia 29:326–327.4708716
Creason JP, Hinners TA, Bumgarner JE, . 1975. Trace elements in hair, as related to exposure in metropolitan New York. Clin Chem 21:603–612.1116297
*Creason JP, Svendsgaard D, Bumgarner J, . 1976. Maternal-fetal tissue levels of 16 trace elements in 8 selected continental United States communities. Proc Univ MO Annu Conf Trace Subst Environ Health. 10:53–62.
*Cunningham WC, Stroube WB Jr. 1987. Application of an instrumental neutron activation analysis procedure to analysis of food. Sci Total Environ 63:29–43.3589654
Curtin GC, King HD, Mosier EL. 1974. Movement of elements into the atmosphere from coniferous trees in subalpine forests of Colorado and Idaho. Journal of Geochemical Exploration 3:245–263.
*Dams R, Robbins JA, Rahn KA, . 1970. Non destructive neutron activation analysis of air pollution particulates. Anal Chem 42:861–867.5431523
*Dams R, Billet J, Hoste J. 1975. Neutron activation analysis of F, SC, Se, Ag, and Hf, in aerosols using short-lived isotopes. Int J Environ Anal Chem 4:141–153.
*Danscher G. 1981. Light and electron microscopic localization of silver in biological tissue. Histochemistry 71:177–186.7239944
*Davidson CI, Goold WD, Mathison TP, . 1985. Airborne trace elements in Great Smoky Mountains, Olympic, and Glacier National Parks. Environ Sci Technol 19:27–35.
Davies PH, Goettl JP Jr, Sinley JR. 1978. Toxicity of silver to rainbow trout (Salmo gairdneri). Water Research 12:113–117.
*Day WA, Hunt JS, McGiven AP. 1976. Silver deposition in mouse glomeruli. Pathology 8:201–204.63934
Deby C, Bacq ZM, Simon D. 1973. In vitro inhibition of the biosynthesis of a prostaglandin by gold and silver. Biochem Pharmacol 22:3141–3143.4202583
*Demerec M, Bertani G, Flint J. 1951. A survey of chemicals for mutagenic action on E. coli. The American Naturalist 85:119–136.
*Dequidt J, Vasseur P, Gromez-Potentier J. 1974. [Experimental toxicological study of some silver derivatives]. Bulletin de la Societe de Pharmacie de Lille 1:23–35. (French).
*Devi YP, Kumar NV. 1981. Simple paper and micro thin layer chromatographic method for separation and detection of mercuric chloride, copper sulfate, cadmium sulfate, and silver nitrate in fresh water. J Assoc Off Anal Chem 64:1301–1304.
Dick WA, Bonta JV, Haghiri F, . 1983. Stream water quality of two small watersheds as affected by surface coal mining. J Environ Qual 12:351–358.
Dillard CJ, Tappel AL. 1986. Mercury, silver, and gold inhibition of selenium-accelerated cysteine oxidation. J Inorg Biochem 28:13–20.3760861
Diplock AT, Green J, Bunyan J, . 1967. Vitamin E and stress. 3. The metabolism of D-alpha-tocopherol in the rat under dietary stress with silver. Br J Nutr 21:115–125.6022756
Diplock AT, Baum H, Lucy JA. 1971. The effect of vitamin E on the oxidation state of selenium in rat liver. Biochem J 123:721–729.5124381
Dissanayake CB, Tobschall HJ, Palme H, . 1983. The abundance of some major and trace elements in highly polluted sediments from the Rhine river near Mainz, West Germany. Sci Total Environ 29:243–260.
*DiVincenzo GD, Giordano CJ, Schriever LS. 1985. Biologic monitoring of workers exposed to silver. Int Arch Occup Environ Health 56:207–215.4066049
*Domsch KH. 1984. Effects of pesticides and heavy metals on biological processes in soil. Plant Soil 76:367–378.
*Douglas WJ. 1968. Toxic properties of materials used in weather modification. Proceedings of the first national conference on weather modification. Boston, MA: American Meteorological Society, 351–360.
*Drake HJ. 1980. Silver. Mineral facts and problems. Washington, DC: U.S. Department of the Interior, Bureau of Mines. Preprint from Bulletin 671.
Dreisback RH, Robertson WO, ed. 1977. Handbook of poisoning: Prevention, diagnosis and treatment. 12th ed. Los Altos, CA: Lang Medical Publications, 373–376.
*Dubin NH, Parmley TH, Cox RT, . 1981. Effect of silver nitrate on pregnancy termination in cynomolgus monkeys. Fertil Steril 36:106–109.7250398
Dunn JA, Holland KB, Jezorek JR. 1987. Argentation liquid chromatography of polynuclear aromatic hydrocarbons on a silver(I)-loaded mercaptopropyl silica gel stationary phase. J Chromatog 394:375–381.3040789
DuPont T, Gomez J, Cuvillier P, . 1984. [Drug-induced generalized argyria. Value of blood and urine analysis. Apropos of 2 cases]. IARC Medical 4:103–105. (French).
*Dutkiewicz T, Paprotny W, Sokolowska D, . 1978. Trace element content of human hair determined using neutron activation analysis as monitor of exposure effects to environmental metals. Chemia Analityczna 23:261–272.
Dyck W. 1967. Adsorption and coprecipitation of silver on hydrous ferric oxides. Can J Chem 46:1441–1444.
Dymond AM, Kaechele LE, Jurist JM, . 1970. Brain tissue reactions to some chronically implanted metals. J Neurosurg 33:574–580.5479495
*East BW, Boddy K, Williams ED, . 1980. Silver retention, total body silver and tissue silver concentrations in argyria associated with exposure to an anti-smoking remedy containing silver acetate. Clin Exp Dermatol 5:305–311.7438526
Eaton DL. 1985. Effects of various trace metals on the binding of cadmium to rat hepatic metallothionein determined by the cd/hemoglobin affinity assay. Toxicol Appl Pharmacol 78:158–162.4035667
Eaton DL, Stacey NH, Wong K-L, . 1980. Dose-response effects of various metal ions on rat liver metallothionein, glutathione, heme oxygenase and cytochrome P-450. Toxicol Appl Pharmacol 55:393–402.6893504
*Eckel WP, Jacob TA. 1988. Ambient levels of 24 dissolved metals in US surface and ground waters. American Chemical Society, Annual Meeting, Los Angeles, CA, September 25-30, 1988. Preprint Extended Abstract.
Eley BM, Garrett JR. 1983. Tissue reactions to the separate implantation of individual constituent phases of dental amalgam, including assessment by energy dispersive x-ray microanalysis. Biomaterials 4:73–80.6860760
El-Yazigi A, Al-Saleh I, Al-Mefty O. 1984. Concentrations of Ag, Al, Au, Bi, Cd, Cu, Pb, Sb, and Se in cerebrospinal fluid of patients with cerebral neoplasms. Clin Chem 30:1358–1360.6744584
EPA. 1977. Heavy metals in gardens near the ASARCO Smelter, Tacoma, Washington. US EPA/OTS Public Files. 40-7748027.
EPA. 1979. US Environmental Protection Agency. Federal Register 44:15926–15981.
*EPA. 1980a. Ambient water quality criteria for silver. Cincinnati, OH: US Environmental Protection Agency, Environmental Criteria and Assessment Office. PB81-117822.
*EPA. 1980b. U.S. Environmental Protection Agency. Federal Register 45:79318–79319.
EPA. 1982. Mortality in employees of the ASARCO Lead Refinery, Omaha, Nebraska with cover letter. US EPA/OTS Public Files.
*EPA. 1985a. Drinking water criteria document for silver. Cincinnati, OH: US Environmental Protection Agency, Environmental Criteria and Assessment Office. PB86-118288.
*EPA. 1985b. Silver. Chemical, physical and biological properties of compounds present at hazardous waste sites. Washington, DC: US Environmental Protection Agency, Office of Waste Programs and Enforcement. PB89-132203.
*EPA 1986. Reference values for risk assessment. Final draft. Cincinnati, OH: US Environmental Protection Agency, Office of Solid Waste. ECAO-CIN-477
*EPA. 1987a. US Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136.1.
*EPA. 1987b. US Environmental Protection Agency. Federal Register 52:21152.
*EPA. 1987c. US Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4.
*EPA. 1987d. US Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.
EPA. 1987. US Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3.
*EPA. 1988a. Health Advisory Draft for Silver. US Environmental Protection Agency, Office of Drinking Water, Washington, DC. (Prepublication draft).
*EPA. 1988b. US Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
EPA. 1988. Drinking water criteria document for silver (final draft). Cincinnati, OH: US Environmental Protection Agency, Environmental Criteria and Assessment Office. ECAO-CIN-026.
*EPA. 1989a. Interim Methods for Development of Inhalation Reference Doses. US Environmental Protection Agency, Office of Health and Environmental Assessment. Washington, DC. EPA 600/8-88/066F.
*EPA. 1989b. US Environmental Protection Agency. Federal Register 54:22062.
Eturska M, Obreshkova E. 1979. [Argyria in the prolonged use of adsorgan]. Vutr Boles 18:121–3.462932
Evans WH, Read JI, Caughlin D. 1985. Quantifications of results for estimating elemental dietary intakes of lithium, rubidium, strontium, molybdenum, vanadium and silver. Analyst 110:873–877.4037365
Fallon ME, Horvath FJ. 1985. Preliminary assessment of contaminants in soft sediments of the Detroit River. J Great Lakes Res 11:373–378.
Farhan FM, Hibibi N, Mofidi J, . 1979. Direct determination of traces of heavy metals in canned vegetables by arc spectrography. J Agric Food Chem 27:637–638.447937
*FDA. 1988a. US Food and Drug Administration. Code of Federal Regulations. 21 CFR 103.35.
*Fisher NS, Bohe M, Teyssie J-L. 1984. Accumulation and toxicity of Cd, Zn, Ag, and Hg in four marine phytoplankters. Mar Ecol Prog Ser 18:201–213.
Flessel CP, Furst A, Radding SB. 1980. A comparison of carcinogenic metals. In: Sigel H, ed. Metal ions in biological systems. Vol. 10, New York, NY: M. Dekker, 23–54.
*Forycki Z, Zegarski W, Bardzik J, . 1983. Acute silver poisoning through inhalation. Bulletin of the Institute of Maritime ,and Tropical Medicine in Gdynia 34:199–203.6681363
Fowler BA, Nordberg PF. 1986. Specific metals. In: Friberg L, Nordberg GF, Vouk VB, eds. Handbook on the toxicology of metals. Vol. 2, 2nd ed. New York, NY: Elsevier Science Publishing Co., Inc., 521–531.
*Fox CL, Rappole BW, Stanford W. 1969. Control of Pseudomonas infection in rats. Surg Gynecol and Obstet 128:1021–1026.5779733
Frank R, Stonefield KI, Luyken H, . 1986. Survey of elemental contents in two organs of slaughtered bovine, porcine and avian specimens, Ontario, Canada 1980-83. Environmental Monitoring and Assessment 6:259–265.24254735
Franz H. 1968. [Demonstration of small amounts of tissue-bound silver]. Histochemie 12:227–229.5742689
*Freeman RA. 1979. Ecological kinetics of silver in an alpine lake ecosystem. In: Marking LL, Kimerle RA, eds. Aquatic toxicology. Philadelphia, PA: American Society for Testing and Materials, 342–358.
Frei JV, Stephens P. 1968. The correlation of promotion of tumor growth and of induction of hyperplasia in epidermal two-stage carcinogenesis. Br J Cancer 22:83–92.5643005
Fujita S. 1971. Silver-palladium-gold alloys carcinogenicity and acid mucopolysacharides in the induced tumors. Chem Abstracts 77:136075a.
*Furchner JE, Richmond CR, Drake GA. 1968. Comparative metabolism of radionuclides in mammals-IV. Retention of silver-110m in the mouse, rat, monkey, and dog, Health Physics 15:505–514.4972147
Furst A. 1981. Bioassay of metals for carcinogenesis: Whole animals. Environ Health Perspect 40:83–91.7274189
Furst A, Schlauder MC. 1977. Inactivity of two noble metals as carcinogens. J Environ Path01 Toxicol 1:51–57.
Galloway JN, Likens GE. 1979. Atmospheric enhancement of metal deposition in Adirondack lake sediments. Limnology Oceanography 24:427–433.
Gallyas F. 1979. Factors affecting the formation of metallic silver and the binding of silver ions by tissue components. Histochemistry 64:97–109.93097
Gammill JC, Wheeler B, Carothers EL, . 1950. Distribution of radioactive silver colloids in tissues of rodents following injection by various routes. Proc Sot Exp Biol Med 74:691–695.
Ganther HE. 1980. Interactions of vitamin E and selenium with mercury and silver. Ann NY Acad Sci 355:212–226.6940477
Ganther HE, Wagner PA, Sunde ML, . 1973. Protective effects of selenium against heavy metal toxicities. Proc Univ MO Annu Conf Trace Subst Environ Health. 7:247–252.
*Gaul LE, Staud AH. 1935. Clinical spectroscopy. Seventy cases of generalized argyrosis following organic and colloidal silver medication, including a biospectrometric analysis. J Am Med Assoc 104:1387–1390.
George SG, Pirie BJS, Calabrese A, . 1986. Biochemical and ultrastructural observations of long-term silver accumulation in the mussel, Mytilus edulis. Marine Environmental Research 18:255–265.
Gerritse RG, Vriesema R, Dalenberg JW, . 1982. Effect of sewage sludge on trace element mobility in soils. J Environ Qual 11:359–364.
Gjerdet NR, Kallus T, Hensten-Pettersen A. 1987. Tissue reactions to implanted orthodontic wires in rabbits. Acta Odontol Stand 45:163–169.
Goebel HH, Muller J. 1973. Ultrastructural observations on silver deposition in the choroid plexus of a patient with argyria. Acta Neuropathol (Berl) 26:247–251.4769154
Goff H, Powers EL. 1975. Effects of X-rays on Ag-DNA complexes. Int J Radiat Biol 27:503–507.
Goldberg ED. 1986. The mussel watch concept. Environmental Monitoring and Assessment 7:91–103.24254800
Goldberg RL, Kaplan SR, Fuller GC. 1983. Effect of heavy metals on human rheumatoid synovial cell proliferation and collagen synthesis. Biochem Pharmacol 32:2763–2766.6626246
Goldschmidt PR, Cogen RB, Taubman SB. 1976. Effects of amalgam corrosion products on human cells. J Periodontal Res 11:108–115.132516
Goodman Gilman A, Goodman LS, Rall TW, ., ed. 1985. Goodman and Gilman’s the pharmacological basis of therapeutics. New York, NY: Macmillan Publishing Company, 951; 966–967; 1107.
Gould GW, Colyer J, East JM, . 1987. Silver ions trigger Ca2+ release by interaction with the (Ca2+-Mg2+)-ATPase. J Biol Chem 262:7676–7679.2953723
Grabowski BF, Haney WG Jr. 1972. Characterization of silver deposits in tissue resulting from dermal application of a silver-containing pharmaceutical. J Pharm Sci 61:1488–1490.5068962
Granati A, Lenzi R, Poggini G, . 1982. [Evaluation of the impact of silver on human health]. Difesa Sociale 61:90–112. (Italian).
*Grass0 P, Abraham R, Hendy R, . 1969. The role of dietary silver in the production of liver necrosis in vitamin E-deficient rats. Exp Mol Pathol 11:186–199.5344068
Grasso P, Abraham R, Hendy R, . 1973. Hepatocellular necrosis from dietary silver in vitamin E-deficient rats [Abstract]. J Pathol 100:ix.
*Grayson M, ed. 1978. Silver and silver alloys; Silver and compounds. Kirk-Othmer encyclopedia of chemical technology. Vol. 21, 3rd ed. 1–32.
Green B. 1967. Effects of silver ions on deoxyribonucleic acid-polycyclic hydrocarbon complexes. Biochem J 104:63–64.
Greenberg RR, Zoller WH, Gordon GE. 1978. Composition and size distributions of particles released in refuse incineration. Environ Sci Technol 12:566–573.
Greene RM, Su WPD. 1987. Argyria. American Family Physician 36:151–154.3687674
Gregus Z, Klaassen CD. 1986. Disposition of metals in rats: A comparative study of fecal, urinary, and biliary excretion and tissue distribution of eighteen metals. Toxicol Appl Pharmacol 85:24–38.3726885
Greig RA, Wenzloff DR, Adams A, . 1977. Trace metals in organisms from ocean disposal sites of the middle eastern United States. Arch Environ Contam Toxicol 6:395–409.318549
Greig RA, Schurman S, Pereira J, . 1983. Metals and PCB concentrations in Windowpane Flounder from Long Island Sound. Bull Environ Contam Toxicol 31:257–262.6414558
Habu T. 1968. Histopathological effects of silver-palladium-gold alloy implantation on the oral submucous membranes and other organs [Abstract]. Shika Igaku 31:17–48.
*Ham KN, Tange JD. 1972. Silver deposition in rat glomerular basement membrane. Aust J Exp Bio Med Sci 50:423–434.4640748
Hamilton A, Hardy HL. 1974. Silver. Industrial toxicology. 3rd ed. Acton, MA: Publishing Sciences Group, Inc., 171–172.
Hamilton EI, Minski MJ. 1972/1973. Abundance of the chemical elements in man’s diet and possible relations with environmental factors. Sci Total Environ 1:375–394.
Hamilton EI, Minski MJ, Cleary JJ. 1972/1973. The concentrations and distribution of some stable elements in healthy tissues from the United Kingdom. An environmental study. Sci Total Environ 1:341–374.
Hanna C, Fraunfelder FT, Sanchez J. 1974. Ultrastructural study of the cornea and conjunctiva. Arch Ophthalmol 92:18–22.4835972
Hanzlik PJ, Presho E. 1923. Comparative toxicity of metallic lead and other heavy metals for pigeons. J Pharmacol Exp Ther 21:145–150.
Harding HE. 1951. Fibrosis in the lungs of a silver finisher. Br J Ind Med 8:256–263.14878960
Harker JM, Hunter D. 1935. Occupational argyria. Br J Dermatol Syph 47:441–455.
*Harrison PR, Rahn KA, Dams R, . 1971. Areawide trace metal concentrations measured by multielement neutron activation analysis. Journal of the Air Pollution Control Association 21:563–570.
Harvey RW, Luoma SN. 1985. Effect of adherent bacteria and bacterial extracellular polymers upon assimilation by Macoma balthica of sediment-bound cadmium, zinc and silver. Mar Ecol Prog Ser 22:281–289.
Hauser TR, Bromberg SM. 1982. EPA’s monitoring program at Love Canal 1980. Environmental Monitoring and Assessment 2:249–272.24264296
Heit M. 1979. Variability of the concentrations of seventeen trace elements in the muscle and liver of a single striped bass, Marone saxatilis. Bull Environ Contam Toxicol 23:1–5.497410
Heit M, Tan Y, Klusek C, . 1981. Anthropogenic trace elements and polycyclic aromatic hydrocarbon levels in sediment cores from two lakes in the Adirondack acid lake region. Water Air Soil Pollut 15:441–464.
*Hem JD. 1970. Study and interpretation of the chemical characteristics of natural waters. US Geological Survey Paper 1473. Washington, DC: US Geological Service., 202–203.
Henry SA. 1950. Cutaneous cancer in relation to occupation. Annals of the Royal College of Surgeons of England 7:425–454.14790563
Henry WM, Knapp KT. 1980. Compound forms of fossil fuel fly ash emissions. Environmental Science and Technology 14:450–456.22288634
Hershelman GP, Schafer HA, Jan T-K, . 1981. Metals in marine sediments near a large California municipal outfall. Marine Pollution Bulletin 12:131–134.
*Hey1 T. 1979. Contact dermatitis from silver coat. Contact Dermatitis 5:197.
Hildebrand SG, Cushman RM, Carter JA. 1976. The potential toxicity and bioaccumulation in aquatic systems of trace elements present in aqueous coal conversion effluents. Proc Univ MO Annu Conf Trace Subst Environ Health. 10:305–313.
*Hill WR, Pillsbury DM. 1939. Argyria, the pharmacology of silver. Baltimore, MD: The Williams and Wilkins Co.
Hill CH, Matrone G. 1970. Chemical parameters in the study of in vivo and in vitro interactions of transition elements. Fed Proc 29:1474–1481.5459894
Hirakawa K. 1983. Determination of silver and cerium in the liver and the kidney from a severely burned infant treated with silver sulfadiazine and cerium nitrate. Radioisotopes 32:59–65. (Japanese).6867381
Hodge VF, Folson TR. 1972. Estimate of the world budget of fallout silver nuclides. Nature 237:98–99.4555448
Hoekstra WG. 1975. Biochemical function of selenium and its relation to vitamin E. Fed Proc 34:2083–2089.1100437
*Hoey MJ. 1966. The effects of metallic salts on the histology and functioning of the rat testis. J Reprod Fertil 12:461–471.5928268
*Holland MK, White IG. 1980. Heavy metals and spermatozoa. 1. Inhibition of the motility and metabolism of spermatozoa by metals related to copper. Fertil Steril 34:483–489.7439413
Holland MK, Suter DAI, White IG. 1976. Possible mechanisms involved in the reduction in motility of human spermatozoa by copper zinc and silver. J Reprod Fertil 46:507–508.1255601
Housley M, Heckingbottom R, Todd CJ. 1977. The interaction of Ag with Si(II1). Surface Science 68:179–188.
*Howlett C, Taylor A. 1978. Measurement of silver in blood by atomic-absorption spectrophotometry using the micro-cup technique. Analyst 103:916–920.707813
*HSDB. 1988. Hazardous Substances Databank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. December 5, 1988.
Hudson E. 1970. A survey of silver recovery. Part I. The mechanics of silver recovery. Radiography 36:263–269.5496763
Huff B, ed. 1988. Physicians desk reference. 42nd ed. Oradell, NJ: Medical Economics Co., 122, 409, 416, 961.
Huggins HA. 1983. Mercury--a factor in mental disease? Part 1. Can mercury-silver amalgams cause psychiatric symptoms. Oral Health 73:42–45.6584812
*Hung S-C, Qu C-L, Wu S-S. 1982. Spectrophotometric determination of silver with 2-(3,5-dibromo-2-pyridylazo)-5-diethylaminophenol in the presence of anionic surfactant. Talanta 29:85–88.18963088
Hunt JS, McGiven AR, Day WA. 1976. Immune complex glomerular disease in argyric mice. Pathology 8:205–210.137381
Hunter D. 1983. Silver and compounds. In: Parmeggiani L, ed. Encyclopaedia of occupational health and safety. Vol. 2, 3rd ed. Geneva: International Labour Office, 2047–2048.
Indraprasit S, Alexander GV, Gonick HC. 1974. Tissue composition of major and trace elements in uremia and hypertension. J Chronic Dis 27:135–161.4830842
Ireland MP. 1988. A comparative study of the uptake and distribution of silver in a slug, Arion water and a snail, Achatina fulica. Comp Biochem Physiol 9OC:189–194.
*IRIS. 1989. Integrated Risk Information System. US Environmental Protection Agency, Cincinnati, OH.
*Iyengar GV, Tanner JT, Wolf WR, . 1987. Preparation of a mixed human diet material for the determination of nutrient elements, selected toxic elements and organic nutrients: A preliminary report. Sci Total Environ 235–252.
Jensen LS. 1975. Modification of a selenium toxicity in chicks by dietary silver and copper. 3 Nutr 105:769–775.
Jensen LS, Peterson RP, Falen L. 1974. Inducement of enlarged hearts and muscular dystrophy in turkey poults with dietary silver. Poultry Science 53:57–64.
John W, Kaifer R, Rahn K, . 1973. Trace element concentrations in aerosols from the San Francisco Bay area. Atmospheric Environment 7:107–118.4685063
*Johnson CA. 1976. The determination of some toxic metals in human liver as a guide to normal levels in New Zealand. Part I. Determination of Bi, Cd, Cr, Co, Cu, Pb, Mn, Ni, Ag, Ti and Zn. Analytica Chemica Acta 81:69–74.
Johnson JS, Kilburn KH. 1983. Cadmium induced metal fume fever: Results of inhalation challenge. Am J Ind Med 4:533–540.6869378
*Jones AM, Bailey JA. 1974. Effect of silver from cloud seeding on cecal flora of rabbits. Water Air Soil Pollut 3:353–363.4456882
Jones CJ, McGugan PJ, Lawrence PF. 1978. An investigation of the degradation of some dry cell batteries under domestic waste landfill conditions. Journal of Hazardous Material 2:259–290.
Just J, Szniolis A. 1938. Germicidal properties of silver in water. Journal American Water Works Association 28:492–506.
*Kaczmar SW, D’Itri FM, Zabik MJ. 1984. Volatilization rates of selected haloforms from aqueous environments. Environmental Toxicology and Chemistry 3:31–35.
Kalistratova VS, Kogan AG, Kozlova MD. 1966. [Behavior of 111Ag in animals]. In: Moskalev I, ed. Raspredel Biol Deistria Radioacktiv Izotop, Sb Statei. Moscow, Russia: Atomizdat, 146–151. (Russian).
Kallus T, Hensten-Pettersen A, Mjor I A. 1983. Tissue response to allergenic leachables from dental material. J Biomed Mater Res 17:741–755.6619174
*Kanematsu N, Hara M, Kada T. 1980. Ret assay and mutagenicity studies on metal compounds. Mutation Research 77:109–116.6769036
Kargov SI, Korolev NI, Stanislavskii OB, . 1986. [Interaction of immobilized DNA with silver ions]. Mol Biol (Mosk) 20:1499–1505. (Russian),3807907
Kehoe JC. 1984. Intracanal corrosion of a silver cone producing a localized argyria: Scanning electron microscope and energy dispersive x-ray analyzer analyses. Journal of Endodontics 10:199–201.6589349
*Kehoe RA, Cholak J, Story RV. 1940. A spectrochemical study of the normal ranges of concentrations of certain trace metals in biological materials. J Nutr 19:579–592.
Kempton S, Sterritt RM, Lester JN. 1987. Heavy metal removal in primary sedimentation. I. The influence of metal solubility. Sci Total Environ 63:231–247.
Kempton S, Sterritt RM, Lester JN. 1987. Heavy metal removal in primary sedimentation II. The influence of metal speciation and particle size distribution. Sci Total Environ 63:247–258.
Kent NL, McCance RA. 1941. The absorption and excretion of ‘minor’ elements by man. I. Silver, gold, lithium, boron and vanadium. Biochemical Journal 35:837–844.16747371
Kesseru E, Leon F. 1974. Effect of different solid metals and metallic pairs on human sperm motility. Int J Fertil 19:81–84.4370767
Kesseru E, Hurtado H, Muhe B. 1974. Copper IUD: Enhancement of its efficacy by the addition of silver and nickel. Contraception 9:141–151.4608032
Kettner VW, Vogel K, Kruger G. 1970. Contribution to the clinical picture of argyrosis. Deut Gesundheitsw 25:1746–1747.
Kharchenko PD, Stepanenko PZ. 1972. [Peculiarities of disturbances of albino rat higher nervous activity during the action of silver electrolytic solutions]. Fiziol Zh (Kiev) 18:596–600. (Ukranian).4656678
Kharchenko PD, Berdyshev GD, Stepanenko PZ, . 1973. [Change in the nucleic acid level in rat brain and liver during long-term introduction of silver ions in drinking water]. Fiziol Zh (Kiev) 19:362–368. (Ukranian).4762510
*Kharkar DP, Turekian KK, Bertine KK. 1968. Stream supply of dissolved silver, molybdenum, antimony, selenium, chromium, cobalt, rubidium and cesium to the oceans. Geochimica et Cosmochimica Acta 32:285–298.
King JS. 1966. A comparative investigation of neuroglia in representative vertebrates: A silver carbonate study. J Morphol 119:435–465.4165380
Klaassen CD. 1978. Effect of metallothionein on hepatic disposition of metals. Am J Physiol 234:E47–E53.623248
*Klaassen CD. 1979a. Effect of spironolactone on the biliary excretion and distribution of metals. Toxicol Appl Pharmacol 50:41–48.494299
*Klaassen CD. 1979b. Biliary excretion of silver in the rat, rabbit and dog. Toxicol Appl Pharmacol 50:49–56.494300
*Klein DH. 1972. Mercury and other metals in urban soils. Environmental Science and Technology 6:560–562.
Klein DH, Russell P. 1973. Heavy metals: Fallout around a power plant. Environmental Science and Technology 7:357–358.
*Klusek CS, Miller KM, Heit M. 1983. Trace element and radionuclide mass balances at a coal-fired electric generating station. Environ Int 9:139–144.
Kober GM. 1916. The gold, silver, jewelry and allied industries. In: Kober GM, Hanson WC, eds. Diseases of occupation and vocational hygiene. Philadelphia, PA: P. Blakiston’s Son and Co., 580–585.
Kojo T, Kaneko T, Ito A, . 1986. [Experimental studies of the effect of metal cores (silver alloy) on the gingival tissue. 2nd report. Extensive investigation of gingival discoloration]. J Jpn Prosthoclort Sot 30:1278–1286. (Japanese).
Kone BC, Kaleta M, Gullans SR. 1988. Silver ion (Ag+)-induced increases in cell membrane potassium and sodium permeability in the renal proximal tubule: Reversal by thiol reagents. J Membr Biol 102:11–19.2456393
Konga M, Nakamura T, Jyoyama T, . 1982. Industrial hygienic approach to the workers exposed to inorganic silver. Proceedings of the tenth Asian conference on occupational health, 2:584–587. September 5-10, Singapore.
*Konradova V. 1968. The ultrastructure of the tracheal epithelium in rabbits following inhalation of aerosols of colloidal solutions of heavy metals. II. Signs of cell alteration in the epithelium after 8 hour inhalation of colloidal solutions of iron and silver. Folia Morph01 (Praha) 16:265–271.
Konradova V. 1968. The ultrastructure of the tracheal epithelium in rabbits following the inhalation of aerosols of colloidal solutions of heavy metals. 1. Changes in the ultrastructure of the tracheal epithelium after 2-hour inhalation of colloidal solutions of iron and silver. Folia Morphol (Praha) 16:258–264.5667788
*Kopp JF. 1969. The occurrence of trace elements in water. Proc Univ MO Annu Conf Trace Subst Environ Health. 3:59–73.
Kopp JF, Kroner RC. 1967. Tracing water pollution with an emission spectrograph. J Water Pollut Cont Fed 39:1659–1668.
Kosarek W. 1981. Removal of various toxic heavy metals and cyanide from water by membrane processes. In: Cooper WJ, ed. Chemistry in water reuse. Vol. 1, Ann Arbor, MI: Ann Arbor Science Publishers, Inc., 261–280.
Krebs A. 1983. [Drug induced nail disorders]. Deutsch Apotheker Zeitung 123:557–561. (German).
Kroner RC, Kopp JF. 1965. Trace elements in six water systems of the United States. Journal American Water Works Association 57:150–156.
Kulskii LA, Kharchenko PD, Stepanenko PZ. 1972. [Dynamics of cortical activity changes in albino rats after chronic silver intoxication]. Dopov Akad Nauk Ukr RSR Ser B 34:660–662. (Ukranian).
*Landas S, Fischer J, Wilkin LD, . 1985. Demonstration of regional blood-brain barrier permeability in human brain. Neurosci Lett 57:251–256.4034094
Larsen PF, Zdanowicz V, Johnson AC. 1983. Trace metal distribution in the surficial sediments of Penobscat Bay, Maine. Bull Environ Contam Toxicol 31:566–573.6640154
La Torraca F. 1962. [Anatomic, histopathological, and histochemical aspects of acute experimental intoxication with silver salts]. Folia Medica 45:1065–1069. (Italian).
*Law SL, Gordon GE. 1979. Sources of metals in municipal incinerator emissions. Environmental Science and Technology 13:432–438.
Lee RE Jr, Von Lehmden DJ. 1973. Trace metal pollution in the environment. Journal of the Air Pollution Control Association 23:853–857.4746266
Leirskar J. 1974. On the mechanism of cytotoxicity of silver and copper amalgams in a cell culture system. Scand J Dent Res 82:74–81.4522965
Leirskar J, Heigeland K. 1972. A methodologic study of the effect of dental materials on growth and adhesion of animal cells in-vitro. Stand J Dent Res 80:120–133.
Leirskar J, Helgeland K. 1981. Mechanism of toxicity of dental materials. International Endodontic Journal 14:42–48.6944281
Lemez L. 1980. Sites for experimental production of tracheal and/or oesophageal malformations in 4-day-old chick embryos. Folia Morphol (Praha) 28:52–55.6993311
Leroux-Robert C, Benevent J, Benevent D, . 1982. [Renal argyria discovered in nephrotic syndrome]. Nephrologie 3:101. (French).
Lester JN. 1983. Significance and behavior of heavy metals in waste water treatment processes 1. Sewage treatment and effluent discharge. Sci Total Environ 30:1–44.
*Lester JN, Sterritt RM, Kirk PWW. 1983. Significance and behavior of heavy metals in waste water treatment processes II. Sludge treatment and disposal. Sci Total Environ 30:45–83.
*Letkiewicz F, Spooner C, Macaluso C, . 1984. Occurrence of silver in drinking water, food, and air. Report to US Environmental Protection Agency, Office of Drinking Water, Criteria and Standards Division, Washington, DC, by JRB Associates, McLean, VA.
Lindh U, Brune D, Nordberg G, . 1980. Levels of antimony, arsenic, cadmium, copper, lead, mercury, selenium, silver, tin and zinc in bone tissue of industrially exposed workers. Sci Total Environ 16:109–116.7455679
*Lindsay WL, Sadiq M. 1979. Theoretical solubility relationships of silver in soils. In: Klein DA, ed. Environmental impacts of artificial ice nucleating agents. Dowden, Hutchinson, and Ross, Inc.
Lockhart SP, Rushworth A, Azmy AAF, . 1983. Topical silver sulphadiazine: Side effects and urinary excretion. Burns 10:9–12.
*Loeb IA, Sirover MA, Weymouth LA, .’ 1977. Infidelity of DNA synthesis as related to mutagenesis and carcinogenesis. J Toxicol Environ Health 2:1297–1304.886629
*Loeffler KU, Lee WR. 1987. Argyrosis of the lacrimal sac. Graefe’s Arch Clin Exp Ophthalmol 225:146–150.3582997
Luis AS, Duarte CS. 1960. Experimental study on the pathogenesis of acute pulmonary edema. I. Pulmonary edema induced by silver nitrate [Abstract]. Ma1 Cardiovasc 56:39–49.
*Luk KFS, Maki AH, Hoover RJ. 1975. Studies of heavy metal binding with polynucleotides using optical detection. J Am Chem Sot 97:1241–1242.
Lukanov J, Atmadjov P. 1979. Investigating the effect of silver ions on the contractile function of smooth-muscle preparations from guinea pig stomach, in vitro. Folia Med (Plovdiv) 21:11–19.116926
Luoma SN, Jenne EA. 1977. The availability of sediment-bound cobalt, silver and zinc to a deposit-feeding clam. In: Drucker H, Wilding RE, eds. Biological implications of metals in the environment. Springfield, VA: National Technical Information Service.
Lyons WMB, Fitzgerald WMF. 1980. Trace metal fluxes to nearshore Long Island Sound sediments. Mar Pollut Bull 11:157–161.
Lytle PE. 1984. Fate and speciation of silver in publicly owned treatment works. Environmental Toxicology and Chemistry 3:21–30.
MacIntyre EH, McClatchy JK, Rudolph H, . 1973. Identification of silver in a periapical lesion of a tooth. Am J Clin Pathol 60:613–615.4751706
*MacIntyre D, McLay ALC, East BW, . 1978. Silver poisoning associated with an antismoking lozenge. Br Med J 2:1749–1750.
Mackison FW, Stricoff RS, Partridge LJ Jr. 1980. Pocket guidelines to chemical hazards. Washington, DC: US Government Printing Office, 1661.
Magos L, Webb M. 1978. Theoretical and practical considerations on the problem of metal-metal interaction. Environ Health Perspect 25:151–154.363406
*Malcolm R, Currey HS, Mitchell MA, . 1986. Silver acetate gum as a deterrent to smoking. Chest 90:107–111.3522114
Malins DC, McCain BB, Brown DW, . Chemical pollutants in sediments and diseases of bottom-dwelling fish in Puget Sound, Washington. Environmental Science and Technology 18:705–713.
Mangal PC, Verma KB. 1979. Effect of induced skin cancer on the concentration of some trace elements. Indian J Med Res 69:290–295.429036
Marie J, Leveque B, Watchi JM, . 1966. [Argyria in a child following pharyngeal spracy of silver salts repeated for 6 years]. Ann Pediatr 13:2657–2659. (French).
Marino AA, Berger TJ, Becker RO, . 1974. The effect of selected metals on marrow cells in culture. Chem Biol Interact 9:217–223.4426110
*Marks R. 1966. Contact dermatitis due to silver. Br J Dermatol 78:606–607.5921986
*Marshall JP II, Schneider RP. 1977. Systemic argyria: Secondary to topical silver nitrate. Arch Dermatol 113:1077–1079.889335
Martin M, Castle W. 1984. Petrowatch: Petroleum hydrocarbons, synthetic organic compounds and heavy metals in mussels from the Monterey Bay area of central California. Marine Pollution Bulletin 15:259–266.
Masiak M, Owczarek H, Skowron S, . 1982. Serum levels of certain trace elements (Ag, Co, Cr) in healthy subjects (part II). Acta Physiol Pol 33 165–73.
Maslenko AA. 1976. [Effects of “silver water” and drinking water treated with silver on the digestive organs]. Vrach Delo, Issue 5, 88–90. (Russian).
*Massa V. 1969. [Analysis of silver, in the presence of other metals, by means of dithizonate chromatography and photodensitometry. Drug control applications]. Trav Sot Pharm Montpellier 29:221–224. (French).
Matuk Y. 1983. Distribution of radioactive silver in the subcellular fractions of various tissues of the rat and its binding to low molecular weight proteins. Can J Physiol Pharmacol 61:1391–1395.6661691
*Matuk Y, Ghosh M, McCulloch C. 1981. Distribution of silver in the eyes and plasma proteins of the albino rat. Can J Ophthalmol 16:145–150.7296363
*Mauss Y, Poulet P, Steibel J, . 1980. Interaction of proflavine-calf thymus DNA complexes with Ag+ and Hg++ ions. Studia Biophysics 81:95–96.
McCabe LJ, Symons JM, Lee RD, . 1970. A survey of community water supply systems. Journal of the American Water Works Association 62:670–687.
*McCoy EC, Rosenkranz HS. 1978. Silver sulfadiazine: Lack of mutagenic activity. Chemotherapy (Basel) 24:87–91.340170
McDermot DJ, Alexander GV, Young DR, . 1976. Metal contamination of flatfish around a large submarine outfall. Journal of the Water Pollution Control Federation 48:1913–1918.966356
McDowell LR, Forseth JA, Piper RC. 1978. Influence of arsenic, sulfur, cadmium, tellurium, silver and selenium on the selenium-vitamin E deficiency in the pig. Nutrition Reports International 17:19–34.
McGinnis JP Jr, Greer JL, Daniels DS. 1985. Amalgam tattoo: Report of an unusual clinical presentation and the use of energy dispersive x-ray analysis as an aid to diagnosis. J Am Dent Assoc 110:52–54.3855919
McLaughlin AIG, Grout JLA, Barrie HJ, . 1945. Iron oxide dust and the lungs of silver finishers. Lancet, March 17, 337–341.
*McMahon JT, Bergfeld WF. 1983. Metallic cutaneous contaminant mimicking malignant melanoma. Cleveland Clinic Quarterly 50:177–181.6640934
Mehregan AH, Faghri B. 1974. Implantation dermatoses. Acta Dermatovener (Stockholm) 54:61–64.4135183
*Mehta AC, Dawson-Butterworth K, Woodhouse MA. 1966. Argyria. Electron microscopic study of a case. Br J Dermatol 78:175–179.
Mertz DP, Koschnick R, Wilk G, . 1968. [Studies on the metabolism of trace elements in humans. I. Serum values for cobalt, nickel, silver, cadmium, chromium, molybdenum, manganese]. Z Klin Chem Klin Biochem 6:171–174. (German).5709556
Mertz DP, Wilk G, Koschnick R. 1975. [Conditions affecting renal excretion of silver by humans. Studies on metabolism of trace elements. VIII]. Z Klin Chem Klin Biochem 13:13–15. (German).1121895
Minoia C, Oppezzo MC, Pozzoli L, . 1985. [Environmental and biological monitoring of subjects occupationally exposed]. G Ital Med Lav 7:65–73. (Italian).3836910
*Mitteldorf AJ, Landon DO. 1952. Spectrochemical determination of the mineral-element content of beef. Analytical Chemistry 24:469–472.
*Moffat DB, Creasey M. 1972. The distribution of ingested silver in the kidney of the rat and of the rabbit. Acta Anat 83:346–355.4639712
Mogilnicka EM, Piotrowski JK, Tomaszewski A. 1976. Effect of some metals (Rb, Cs, Ag, Ti, Sb, U) on metallothionein level in the liver and kidney of the rat. Bromat Chem Toksykol 9:357–359. (Polish)
Mogilnicka EM, Milaszewicz M, Piotrowsk JK. 1978. [Binding of silver in the liver of the rat]. Bromat Chem Toksykol 11:59–65. (Polish).
Moller B. 1979. Reactions of human dental pulp to silver amalgam restorations. A study with emphasis on source material characteristics. Swedish Dent [Suppl] 2:1–37.
Moore JW, Sutherland DJ. 1981. Distribution of heavy metals and radionuclides in sediments, water, and fish in an area of Great Bear Lake contaminated with mine wastes. Arch Environ Contam Toxicol 10:329–338.7259301
Morgan WKC. 1984. Other pneumoconioses. In: Morgan WKC, Seaton A, eds. Occupational lung disease. 2nd ed. Philadelphia, PA: W.B. Saunder Company, 449–497.
*Moss AP, Sugar A, Hargett NA, . 1979. The ocular manifestations and functional effects of occupational argyrosis. Arch Ophthalmol 97:906–908.312638
Muroma A. 1961. Skin reactions produced by certain metallic salts. Annales Medicine Experimentalis et Biologiae Fenniae 39:277–279.
*Murthy GK, Rhea U. 1968. Cadmium and silver content of market milk. J Dairy Science 51:610–613.
*Nadkarni RA, Ehmann WD, Burdick D. 1970. Investigations on the relative transference of trace elements from tobacco into smoke condensate. Tobacco 170:25–27.
Naganuma A, Tanaka T, Maeda K, . 1983. The interaction of selenium with various metals in vitro and in vivo. Toxicology 29:77–86.6658802
Nakamuro K, Sayato Y. 1986. Studies on the toxicity of silver ion in water filtered through a household water purifier equipped with a silver-coated charcoal filter. Eisei Kagaku 32:28–33.
*Nakashima R, Sasaki S, Shibata S. 1975. Determination of silver in biological materials by high-frequency plasma-torch emission spectrometry. Analytica Chimica Acta 77:65–70.1138577
*NAS/NRC. 1989. Biological markers in reproductive toxicology. National Research Council. Board of Environmental Studies and Toxicology. Committee on Biological Markers. 15–35.
Nathanson JA, Bloom FE. 1976. Heavy metals and adenosine cyclic 3’,5’-monophosphate metabolism: Possible relevance to heavy metal toxicity. Mol Pharmacol 12:390–398.180396
Nechay BR, Saunders JP. 1984. Inhibition of adenosine triphosphates in vitro by silver nitrate and silver sulfadiazine. Journal of the American College of Toxicology 3137–42.
Nehring RB. 1976. Aquatic insects as biological monitors of heavy metal pollution. Bull Environ Contam Toxicol 15:147–154.1252629
Neri LC, Hewitt D, Schreiber GB, . 1975. Health aspects of hard and soft waters. Journal American Water Works Association 67:403–409.
*Newton D, Holmes A. 1966. A case of accidental inhalation of zinc-65 and silver-110m. Radiat Res 29:403–412.5924187
Nilner K, Glantz P-O. 1982. The prevalence of copper-, silver-, tin-, and zinc-ions in human saliva. Swed Dent J 6:71–77.6955986
*NIOSH. 1976. National Occupational Hazard Survey (1970) Database. US Department of Health and Human Services, National Institute for Occupational Safety and Health, Cincinnati, OH
*NIOSH. 1984a. National Occupational Exposure Survey (1980-1983) Database. US Department of Health and Human Services, National Institute for Occupational Safety and Health, Cincinnati, OH.
*NIOSH. 1984b. NIOSH, manual of analytical methods. Washington, DC: US Government Printing Office., 73001–73005.
*NIOSH. 1985. Pocket guide to chemical hazards. Washington, DC: US Department of Health and Human Services. DHEW (NIOSH) Publication No 78-210.
Nishimura M. 1978. [A study on the cytotoxicity of Au-Pd-Ag alloys containing Cd (in vitro)]. Shika Rikogaku Zasshi 19:1–7. (Japanese).282374
*Nishioka H. 1975. Mutagenic activities of metal compounds in bacteria. Mutat Res 31:185–189.805366
Nordberg GF, Gerhardsson L. 1988. Silver. In: Seiler HG, Sigel H, eds. Handbook on toxicity of inorganic compounds. New York, NY: Marcel Dekker, Inc., 619–624.
Norden B, Matsuoka Y, Kurucsev T. 1986. Nucleic acid-metal interactions: V. The effect of silver(I) on the structures of A- and B-DNA forms. Biopolymers 25:1531–1545.3742004
Nriagu JR. 1979. Global inventory of natural and anthropogenic emissions of trace metals to the atmosphere. Nature 279:409–411.16068169
*NRC. 1977. Silver. In: Drinking water and health. Vol. 2. Washington, DC: National Academy of Sciences, National Research Council, 102–106.
*Nuttall KL. 1987. A model for metal selenide formation under biological conditions. Med Hypotheses 24:217–221.3683250
Oh SH, Whanger PD, Deagen JT. 1981. Tissue metallothionein: Dietary interaction of cadmium and zinc with copper, mercury, and silver. J Toxicol Environ Health 7:547–560.7288903
OHM, TADS. 1988. Oil and Hazardous Materials Technical Assistance Data System. Chemical Information System (CIS). December 5, 1988.
*Okazaki RK, Panietz MH. 1981. Depuration of twelve trace metals in tissues of the oysters Crassostrea gigas and Crassostrea virginica. Marine Biology 63:113–120.
*Olcott CT. 1947. Experimental argyrosis. III. Pigmentation of the eyes of rats following ingestion of silver during long periods of time. Am J Pathol 23:783–789.19970959
*Olcott CT. 1948. Experimental argyrosis. IV. Morphologic changes in the experimental animal. Am J Path 24:813–833.18874413
*Olcott CT. 1950. Experimental argyrosis. V. Hypertrophy of the left ventricle of the heart. Archives of Pathology 49:138–149.15401785
Olson BH, Guinn VP. 1978. Accumulations of trace elements in soil and plants from land disposal of secondary domestic wastewater. In: Land treatment of wastewater international symposium, Hanover, NH. 2:289–299
Oppenheimer BS, Oppenheimer ET, Danishefsky I, . 1956. Carcinogenic effect of metals in rodents. Cancer Res 16:439–441.13330036
Orentreich N, Pearlstein HH. 1969. Traumatic tattoo due to silver salt. Arch Dermatol 100:107–108.5822333
Orstavik D, Hongslo JK. 1985. Mutagenicity of endodontic sealers. Biomaterials 6:129–132.4005357
Osborn JF, Santhanam S, Davidson CI, . 1984. Characterization of airborne trace metal and trace organic species from coal gasification. Environmental Monitoring and Assessment 4:317–333.24257860
*OSHA. 1988a. US Department of Labor, Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.20
*OSHA. 1988b. US Department of Labor, Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000
Owens CJ, Yarbrough DR III, Brackett NC. 1974. Nephrotic syndrome following topically applied sulfadiazine silver therapy. Arch Intern Med 134:332–335.4843201
Page AL. 1974. Fate and effects of trace elements in sewage sludge when applied to agricultural lands. A literature review study. Ultimate Disposal Research Program. Cincinnati, OH: US Environmental Protection Agency, Office of Research and Development. NTIS PB-231 171.
Palmer GR, Weine FS, Palmer MJ, . 1979. A study of the tissue reaction to silver cones and Ti-6Al-4V in the rhesus monkey. Journal of Endodontics 5:116–120.120888
*Pariser RJ. 1978. Generalized argyria: Clinicopathologic features and histochemical studies. Arch Dermatol 114:373–377.629570
Parkki MG. 1981. Inhibition of rat hepatic microsomal epoxide hydrase by heavy- and organometals in vitro. Adv Exp Med Biol 136:729–738. Part A.7344488
Perry RMA. 1947. Diseases of the lung resulting from occupational dusts other than silica. Thorax 2:91–120.
*Pesch G, Reynolds B, Rogerson P. 1977. Trace metals in scallops from within and around two ocean disposal sites. Marine Pollution Bulletin 8:224–228.
Petering HG. 1976. Pharmacology and toxicology of heavy metals: Silver. Pharmacol Ther 1:127–130. Part A.
Peterson RP, Jensen LS, Harrison PC. 1973. Effect of silver-induced enlarged hearts during the first four weeks of life on subsequent performance of turkeys. Avian Diseases 17:802–806.4271910
Pezzarossa E, Alinovi A, Ferrari C. 1983. Generalized argyria. J Cutan Pathol 10:361–363.6630668
Pfitzer EA. 1975. Toxicology. In: Cralley LV, Atkins PR, eds. Industrial environmental health. The worker and the community. New York, NY: Academic Press, 67–128.
*Phalen RF, Morrow PE. 1973. Experimental inhalation of metallic silver. Health Phys 24:509–518.4707665
*Pickston L, Lewin JF, Drysdale JM, . 1983. Determination of potentially toxic metals in human livers in New Zealand. J Anal Toxicol 7:2–6.6834792
*Pierce FD, Gortatowski MJ, Mecham HD, . 1975. Improved automated extraction method for atomic adsorption spectrometry. Analytical Chemistry 47:1132–1135.
*Pifer JW, Friedlander BR, Kintz RT, . 1989. Absence of toxic effects in silver reclamation workers. Stand J Work Environ Health 15:210–221.
Pokorny J. 1983. [A model of interaction of metal ions with the phosphate group]. Biologia (Bratisl) 38:289–292. (German).
Polachek AA, Cope CB, Williard RF, . 1960. Metabolism of radioactive silver in a patient with carcinoid. J Lab Clin Med 56:499–505.13736663
Pratt JR, McCormick PV, Pontasch KW, . 1988. Evaluating soluble toxicants in contaminated soils. Water Air Soil Pollut 37:293–307.
Prose PH. 1963. An electron microscopic study of human generalized argyria. Am J Pathol 42:293–299 13986364
Quijada S, Soza X, Croxatto HB. 1978. Fertility inhibition by intraoviductal copper beads in rabbits. Contraception 17:553–562.720060
*Ragaini RC, Ralston HR, Roberts N. 1977. Environmental trace metal contamination in Kellogg, Idaho, near a lead smelting complex. Environ Sci Technol 11:773–781.
*Rains TC, Watters RL Jr, Epstein MS. 1984. Application of atomic absorption and plasma emission spectrometry for environmental analysis. Environment International 10:163–168.
Ramelow GJ, Maples RS, Thompson RL, . 1987. Periphyton as monitors for heavy metal pollution in the Calcasieu River estuary. Environ Poll 43:247–263.
Raskin RB. 1984. Toxicity of silver amalgam: Fact or fiction. NY State Dent J 50:582, 585, 587.
*Rattonetti A. 1974. Determination of soluble cadmium, lead, silver, and indium in rainwater and stream water with the use of flameless atomic absorption. Anal Chem 46:739..4825965
Rauber A, Bruner B. 1987. Ingestion of concentrated silver nitrate: A report of two cases. Vet Hum Toxicol 29:321–322.3629914
*Rawlings GD, Samfield M. 1979. Textile plant wastewater toxicity. Environmental Science and Technology 13:160–164.
*Reese RG Jr. 1986. The minerals year book. Vol. 1, Washington, DC: US Department of the Interior, Bureau of Mines, 837–856.
Reichenbach DD. 1985. Cardiovascular system. In: Mottet NK, ed. Environmental pathology. New York, NY: Oxford University Press, 356–367.
Reuss M. 1983. Comparison of different methods for estimating the leaching of heavy metals from coal combustion wastes. Nat Sci Tech 15:193–205.
Reymond J-L, Stoebner P, Amblard P. 1980. [Cutaneous argyria: An electron microscopic study of four cases with microanalysis X study of one case]. Ann Dermatol Venereol 107:251–255. (French).7387059
Ribadeau Dumas JL, Larmande P, Bourin M, . 1978. [Is there such a thing as encephalopathy related to organic compounds of silver]. Nouv Presse Med 7:1956. (French),
Ribarov SR, Benov LC. 1981. Relationship between the hemolytic action of heavy metals and lipid peroxidation. Bioch Biophys Acta 640:721–726.
Ribarov S, Benov L. 1985. Glutathione reductase and glucose-6-phosphate dehydrogenase in erythrocytes treated with heavy metals. Acta Physiol Pharmacol Bulg 11:51–54.3832794
Ribarov S, Benov L, Benchev I. 1986. The mechanism of AgNO3 induced lipid peroxidation in erythrocytes. Biomed Biochim Acta 45:321–330.3707552
Ridlington JW, Whanger PD. 1981. Interactions of selenium and antioxidants with mercury, cadmium and silver. Fundam Appl Toxicol 1:368–375.7185585
Rimerman RA, Buhler DR, Whanger PD. 1977. Metabolic interactions of selenium with heavy metals. In: Lee SD, ed. Biochemical effects of environmental pollutants. Ann Arbor, MI: Ann Arbor Science Publishers, Inc., 377–396.
*Robison SH, Cantoni O, Costa M. 1982. Strand breakage and decreased molecular weight of DNA induced by specific metal compounds. Carcinogenesis (Lond) 3:657–662.7116559
*Robkin MA, Swanson DR, Shepard TH. 1973. Trace metal concentrations in human fetal livers. Trans Am Nucl Sot 17:97.
Roe FJC, Lancaster MC. 1964. Natural, metallic and other substances, as carcinogens. Brit Med Bull 20:127–133.14169950
Roediger WEW. 1973. The nature of silver binding in the- canine thyroid “C” cell. S Afr J Med Sci 38:17–22.4130520
Roesijadi G, Young JS, Drum AS, . 1984. Behavior of trace metals in Mytilus edulis during a reciprocal transplant field experiment. Mar Ecol Prog Ser 18:155–170.
*Rosenman KD, Moss A, Kon S. 1979. Argyria: Clinical implications of exposure to silver nitrate and silver oxide. J Occup Med 21:430–435.469606
*Rosenman KD, Seixas N, Jacobs I. 1987. Potential nephrotoxic effects of exposure to silver. Br J Ind Med 44:267–272.3567102
Roshchin AV, Ordzhonikidze EK. 1986. [Metal toxicokinetics and its significance for the prevention of occupational poisoning]. Gig Tr Prof Zabol, Issue 3, 1–6. (Russian).
*Rossman TG, Molina M. 1986. The genetic toxicology of metal compounds: II. Enhancement of ultraviolet light-induced mutagenesis in Escherichia coli WP2. Environ Mutagen 8:263–271.3516673
Roy DR, Bailey JA. 1974. Effect of silver from cloud seeding on rumen microbial function. Water Air Soil Pollut 3:343–351.4456881
*RTECS. 1988. Registry of Toxic Effects of Chemical Substances. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. December 5, 1988.
*Rungby J. 1986. Experimental argyrosis: Ultrastructural localization of silver in rat eye. Exp Mol Pathol 45:22–30.3758305
Rungby J. 1986. Exogenous silver in dorsal root ganglia, peripheral nerve, enteric ganglia, and adrenal medulla. Acta Neuropathol (Berl) 69:45–53.3962597
Rungby J. 1986. The silver nitrate prophylaxis of crede causes silver deposition in the cornea of experimental animals. Exp Eye Res 42:93–94.3956607
*Rungby J. 1987. Silver-induced lipid peroxidation in mice: Interactions with selenium and nickel. Toxicology 45:135–142.3603579
*Rungby J, Danscher G. 1983a. Neuronal accumulation of silver in brains of progeny from argyric rats. Acta Neuropathol (Berl) 61:258–262.6650140
*Rungby J, Danscher G. 1983b. Localization of exogenous silver in brain and spinal cord of silver exposed rats. Acta Neuropathol (Berl) 60:92–98.6880627
*Rungby J, Danscher G. 1984. Hypoactivity in silver exposed mice. Acta Pharmacol Toxicol 55:398–401.
*Rungby J, Slomianka L, Danscher G, . 1987. A quantitative evaluation of the neurotoxic effect of silver on the volumes of the components of the developing rat hippocampus. Toxicology 43:261–268.3824394
Rungby J, Ellermann-Eriksen S, Danscher G. 1987. Effects of selenium on toxicity and ultrastructural localization of silver. Arch Toxicol 61:40–45.3439873
Rungby J, Hultman P, Ellermann-Eriksen S. 1987. Silver affects viability and structure of cultured mouse peritoneal macrophages and peroxidative capacity of whole mouse liver. Arch Toxicol 59:408–412.3606385
Ryan DE, Holzbecher J, Stuart DC. 1978. Trace elements in scalp-hair of persons with multiple sclerosis and of normal individuals. Clin Chem 24:1996–2000.709834
Saffiotti U, Shubik P. 1963. Studies on promoting action in skin carcinogenesis. National Cancer Institute Monograph 10:489–506.
Sakai K, Umeda T, Yamane Y. 1985. In vitro DNA methylation by methylnitrosourea in isolated copper- or silver-preloaded rat liver nuclei. Biochemical Pharmacology 34:4071–4073.4062978
*Sano S, Fujimori R, Takashima M, . 1982. Absorption, excretion and tissue distribution of silver sulphadiazine. Burns 8:278–285.
Saxena J, Howard PH. 1977. Environmental transformation of alkylated and inorganic forms of certain metals. In: Perlman D, ed. Advances in applied microbiology. Vol. 21, New York, NY: Academic Press, 185–226.
Schatz H. 1982. Unusual cases. Retina 2:189–90.7178689
Schelenz R. 1977. Dietary intake of 25 elements by man estimated by neutron activation analysis. J Radioan Chem 37:539–548.
Schmahl D, Steinhoff D. 1960. [Experimental carcinogenesis in rats with colloidal silver and gold solutions]. Z Krebsforsc 63:586–591. (German)
Schopf E, Schulz KH, Isensee I. 1969. [Investigations on lymphocyte transformation in mercury sensitivity. Non specific transformation due to mercury compounds]. Arch Klin Exp Derm 234:420–433. (German).4902486
Schultka R, Schmidt R, Drosner H-P. 1971. [Histochemical localization of heavy metal in the kidneys of white rats during embryonal and postnatal development]. Acta Histochem (Jena) 40:123–130. (German).5000857
Schulze A, Bingas B. 1968. [Meningioma development induced by a foreign body]. Beitr Neurochir 15:297–301. (German).5739458
*Scicchitano DA, Pegg AE. 1987. Inhibition of 06-alkylguanine-DNA-alkyltransferase by metals. Mutat Res 192:207–210.3683440
Scott WL Jr. 1967. Silver uptake in brains of chronically gamma-irradiated rats: A study by neutron activation analysis. Radiat Res 31:522–528.6029218
*Scott KG, Hamilton JG. 1950. The metabolism of silver in the rat with radio-silver used as an indicator. University of California Publications in Pharmacology 2:241–262.24538271
Scott KG, Hamilton JG. 1948. The metabolism of silver [Abstract]. J Clin Invest 27:555–556.
Scott R, Norman PM. 1980. Silver deposition in arteriolar basal laminae in the cerebral cortex of argyric rats. Acta Neuropathol (Berl) 52:243–246.7445987
*Scow K, Goyer M, Nelken L, . 1981. Exposure and risk assessment for silver. Report to US Environmental Protection Agency, Office of Water Regulations and Standards, Washington, D.C., by Arthur D. Little, Inc., Cambridge, MA. PB85-211993.
*Segar DA, Gilio JL. 1973. The determination of trace transition elements in biological tissues using flameless atom reservoir atomic absorption. Int J Environ Anal Chem 2:291–301.4752398
Sharma DC, Sharma M, Rathore AS, . 1980. Effect of silver, gold, and mercury colloids on erythrocyte and iron metabolism. Indian J Exp Biol 18:1309–1311.7216294
Shaver SL, Mason KE. 1951. Impaired tolerance to silver in vitamin E deficient rats. Anat Ret 109:382.
Shaw EB. 1980. Questions the need for prophylaxis with silver nitrate. Pediatrics 59:792.
*Shelton D, Goulding R. 1979. Silver poisoning associated with an antismoking lozenge [letter]. Br Med J, January 27; 1(6158):267.
*Shimamoto Y, Shimamoto H. 1987. Systemic argyria secondary to breath freshener “Jintan Silver Pills”. Hiroshima J Med Sci 36:245–247.3654273
*Shouse SS, Whipple GH. 1931. I. Effects of the intravenous injection of colloidal silver upon the hematopoietic system in dogs. Jour Exp Med 53:413–420.19869854
Siemiatycki J, Gerin M, Hubert J. 1981. Exposure-based case control approach to discovering occupational carcinogens: Preliminary findings. In: Peto R, Schneiderman M, eds. Quantification of occupational cancer, Banbury Report No. 9. Cold Spring Harbor, NY: Cold Spring Harbor Laboratory, 471–481.
Silver Institute. 1975. Silver guards good health. Silver Inst. Lett. 5(5):1.
Sirover MA, Loeb LA. 1976. Infidelity of DNA synthesis [underlined: in vitro]: Screening for potential metal mutagens or carcinogens. Science 194:1434–1436.1006310
Sittig M. 1985. Silver and Compounds. Handbook of toxic and hazardous chemicals and carcinogens. 2nd ed. Park Ridge, NJ: Noyes Data Corporation, 789–790.
Skouby SO, Tabor A. 1978. [Experience with a copper-silver IUD, Cu-T 2200 WI. Ugeskr Laeg 140:1882–1885. (Danish).684927
Smirnov VG. 1983. [Experimental studies of toxicology of silver and establishment of maximum permissible levels for its compounds in the air of worksites]. Gig Tr Prof Zabol, Issue 12, 33–37. (Russian).
Smith DR, Stephenson MD, Flegal AR. 1986. Trace metals in mussels transplanted to San Francisco Bay. Environmental Toxicology and Chemistry 5:129–138.
*Smith IC, Carson BL. 1977. Trace metals in the environment, Vol. 2. Silver. Ann Arbor, MI: Ann Arbor Science Publishers, Inc.
Smith TJ, Blough S. 1982. Chromium, manganese, nickel,and other elements. In: Rom WN, ed. Environmental and occupational medicine. Boston, MA: Little, Brown and Co., 491–510.
*Snider EH, Manning FS. 1982. A survey of pollutant emission levels in waste waters and residuals from the petroleum refining industry. Environment International 7:237–258.
*Snyder WS, . 1975. Report of the task group on reference man. Oxford, England: Pergamon Press, 407–708.
*Soldatenkova NA, Smirnov VG. 1983. [Atomic absorption method of determining silver in the air]. Gig Tr Prof Zabol, Issue 6, 53–54. (Russian).
Spiegel L. 1931. A discoloration of the skin and mucous membranes resembling argyria, following the use of bismuth and silver arsphenamine. Archives of Dermatology and Syphilology 23:266–286.
Spielman A, Gutman D, Laufer D. 1981. Anesthesia following endodontic overfilling with AH26. Report of a case. Oral Surg Oral Med Oral Pathol 52:554–556.6946382
Splittgerber AG, Tappel AL. 1979. Inhibition of glutathione peroxidase by cadmium and other metal ions. Arch Biochem Biophys 197:534–542.507828
Stammberger H. 1982. [Argyrosis of the nasal mucosa]. Laryng Rhino1 Otol (Stuttg) 61:234–237. (German).
Stanley JS. 1986. Broad scan analysis of the FY82 national human adipose tissue survey specimens. Volume 1. Executive Summary. Washington, DC: US Environmental Protection Agency, Office of Toxic Substances, Design and Development Branch, National Human Monitoring Program. EPA 560/5-86-035.
*Starkey BJ, Taylor AP, Walker AW. 1987. Measurement of silver in blood by electrothermal atomic absorption spectrometry (ET-AAS). Ann Clin Biochem 24:SI91–SI93.
Starzynska T, Mandat A. 1987. [A case of argyria after peroral treatment of peptic ulcer with silver albuminate]. Wiad Lek 40:691–693. (Polish).3673077
Stephenson T, Lester JN. 1987. Heavy metal behavior during the activated sludge process I. Extent of soluble and insoluble metal removal. Sci Total Environ 63:199–214.
Stephenson T, Lester JN. 1987. Heavy metal behavior during the activated sludge process II. Insoluble metal removal mechanisms. Sci Total Environ 63:215–230.
*Stokinger HE. 1981. The metals. In: Clayton GD, Clayton FE, eds. Patty’s industrial hygiene and toxicology. Vol. 2A, 3rd ed. New York, NY: John Wiley and Sons, Inc., 1881–1894.
Strassburg M, Schubel F. 1967. [Generalized allergic reaction caused by silver amalgam fillings]. Deutsch Zahnarztuche Zeitschrift 22:3–9. (German).
Strauch B, Buch W, Grey W, . 1969. Methemoglobinemia: A complication of silver nitrate therapy used in burns. AORN’ Journal 10:54–56.
Strauch B, Buch W, Grey W, . 1969. Successful treatment of methemoglobinemia secondary to silver nitrate therapy. New England Journal of Medicine 281:257–258.5791292
Strong CR, Luoma SN. 1981. Variations in the correlation of body size with concentrations of copper and silver in the bivalve Macoma balthica. Can J Fish Aquat Sci 38:1059–1064.
*Struempler AW. 1975. Trace element composition in atmospheric particulates during 1973 and the summer of 1974 at Chadron, Neb. Environ Sci Technol 9:1164–1168.
Sugawara N, Sugawara C. 1984. Effect of silver on ceruloplasmin synthesis in relation to low-molecular-weight protein. Toxicology Letters 20:99–104.6695402
Suissa M. 1983. Spectrophotometric quantitation of silver grains eluted from autoradiograms. Anal Biochem 133:511–514.6638510
Sujari ANA, Bowen HJM. 1986. Interactions of silver with humates and other species in natural waters. 3 Radioanal Nucl Chem 106:213–222.
Sunderman FW Jr. 1987. Metal induction of heme oxygenase. In: Silbergeld EK, Fowler RA, eds. Annals of the New York Academy of Sciences. Vol. 514, New York, NY: New York Academy of Sciences, 65–80.
Swanson AB, Wagner PA, Ganther HE, . 1974. Antagonistic effects of silver and tri-o-cresyl phosphate on selenium and glutathione peroxidase in rat liver and erythrocytes [Abstract]. Fed Proc 33:693.
Tan E-L, Williams MW, Schenley RL, . 1984. The toxicity of sixteen metallic compounds in Chinese hamster ovary cells. Toxicol Appl Pharmacol 74:330–336.6429900
*Tanita Y, Kato T, Hanada K, . 1985. Blue macules of localized argyria caused by implanted acupuncture needles. Electron microscopy and roentgenographic microanalysis of deposited metal. Arch Dermatol 121:1550–1552.4062338
Temple RM, Farooqi AA. 1985. An elderly, slate-grey woman. Practitioner 229:1053–1054.4088958
Teraok H. 1981. Distribution of 24 elements in the internal organs of normal males and the metallic workers in Japan. Archives of Environmental Health 36:155–165.7271320
*Terhaar CJ, Ewe11 WS,. Dziuba SP, . 1977. A laboratory model for evaluating the behavior of heavy metals in an aquatic environment. Water Research 11: 101–110.
Terner K, Javor R. 1982. The effect of PGF2a on human oral mucous membrane. Pharmacol Res Commun 14:511–522.6956931
*The International Technical Information Institute (ITII). 1982. Toxic and hazardous industrial chemicals safety manual. Tokyo, Japan: International Technical Information Institute, 464–465.
Theodossiadis G, Kouris T, Papadopoulou C. 1982. Determination of trace element Ag and SC concentrations in human cataractous lenses. Ophthalmic Res 14:436–441.7162771
*The Silver Institute. 1988. Silver consumption in the photographic industry. The Silver Institute, Washington, DC. 20008.
*The Silver Institute. 1990. Latest Silver Institute refining statistics. The Silver Institute, Inc., Washington, DC. 20008.
Thompson JD, Nechay BR. 1981. Inhibition by metals of a canine renal calcium, magnesium activated adenosine triphosphatase. J Toxicol Environ Health 7:901–908.6115068
*Thomson EA, Luoma SN, Johansson CE, . 1984. Comparison of sediments and organisms in identifying sources of biologically available trace metal contamination. Water Research 18:755–766.
Thorlacius-Ussing O, Rungby J. 1984. Ultrastructural localization of exogenous silver in the anterior pituitary gland of the rat. Exp Mol Pathol 41:58–66.6468636
Thorlacius-Ussing O, Graabaek PM. 1986. Simultaneous ultrastructural demonstration of heavy metals (silver, mercury) and acid phosphatase. Histochemical Journal 18:639–646.3558002
Tichy P, Rosina J, Blaha K Jr, . 1986. Biliary excretion of 110mAg and its kinetics in the isolated perfused liver. J Hyg Epidemiol Microbial Immunol 30:145–148.
Timperley MH. 1978. Collaborative tests of water analysis (the CHEMAQUA program). New Zealand Journal of Science 21:557–564.
Tipton IH, Cook MJ. 1963. Trace elements in human tissue. Part II. Adult subjects from the United States. Health Phys 9:103–145.13985137
*Tipton IH, Stewart PL, Martin PG. 1966. Trace elements in diets and excreta. Health Phys 12:1683–1689.
Tomokuni K. 1979. Interaction of zinc and other metals on the activity of erythrocyte delta- aminolevulinic acid dehydratase in vitro. J Toxicol Sci 4:11–18.480402
Tomokuni K, Ogata M. 1980. Comparative study of effects of lead on the activity of erythrocyte pyrimidine 5’ -nucleotidase and delta-aminolevulinate dehydratase in vivo and in vitro. Arch Toxicol 45:197–201.6257208
Tomokuni K, Ogata M. 1980. [In-vitro effect of heavy metals on the activity of pyrimidine 5’ nucleotidase and gamma amino levulinate dehydratase in the human erythrocyte]. Jap J Ind Health 22:282–283. (Japanese).
Tomza U, Janicki T, Kossman S. 1983. Instrumental neutron activation analysis of trace elements in hair: A study of occupational exposure to a non-ferrous smelter. Radiochem and Radioanal Letters 58:209–220.
*Ulitzur S, Barak M. 1988. Detection of genotoxicity of metallic compounds by bacterial bioluminescence test. Journal of Bioluminescence and Chemiluminescence 2:95–99.3213595
Underwood EJ. 1979. Interactions of trace elements. In: Oehme FW, ed. Hazardous and toxic substances. Vol. 2, New York, NY: Marcel Dekker, Inc., 641–668.
Valente P, Axelrod JL. 1978. Acute leukopenia associated with silver sulfadiazine therapy. J Trauma 18:146–147.633424
Van Campen DR. 1966. Effects of zinc, cadmium, silver and mercury on the absorption and distribution of copper-64 in rats. J Nutr 88:125–130.5900620
Van Vleet JF. 1976. Induction of lesions of selenium-vitamin E deficiency in pigs fed silver. Am J Vet Res 37:1415–1420.999068
*Van Vleet JF. 1977. Protection by various nutritional supplements against lesions of selenium- vitamin E deficiency induced in ducklings fed tellurium or silver. Am J Vet Res 38:1393–1398.921035
Van Vleet JF. 1982. Amounts of twelve elements required to induce selenium-vitamin E deficiency. Am J Vet Res 43:851–857.7091849
*Van Vleet JF, Boon GD, Ferrans VJ. 1981. Induction of lesions of selenium-vitamin E deficiency in ducklings fed silver, copper, cobalt, tellurium, cadmium, or zinc: Protection by selenium. Am 3 Vet Res 42:1206–1217.
Venugopal B, Luckey TD. 1978. Introduction to heavy metal toxicity in mammals. Metal toxicity in mammals. Vol. 2, New York, NY: Plenum Press, 36–37.
Veron C, Hildebrand HF, Martin P. 1986. [Dental amalgams and allergy]. J Biol Buccale 14:83–100. (French).3525526
*VIEW Database. 1989. Agency for Toxic Substances and Disease Registry (ATSDR), Office of External Affairs, Exposure and Disease Registry Branch, Atlanta, GA. February 21, 1989.
Vik H, Andersen KJ, Julshawn K, . 1985. Neuropathy caused by silver absorption from arthroplasty cement [letter]. Lancet, April 13; 1(8433):872.
*Vince DG, Williams DF. 1987. Determination of silver in blood and urine by graphite furnace atomic absorption spectrometry. The Analyst 112:1627–1629.3439608
Von Mallinckrodt MG, Pooth M. 1969. [Simultaneous spectrographic testing for 25 metals and metaloids in biological material]. Arch Toxikol 25:5–18. (German).5806380
Von Rosen G. 1954. Breaking of chromosomes by the action of elements of the periodical system and by some other principles. Hereditas 40:258–263.
Von Rosen G. 1957. Mutations induced by the action of metal ions in pisum. Hereditas 43:644–664.
Wagner PA, Hoekstra WG, Ganther HE. 1975. Alleviation of silver toxicity by selenite in the rat in relation to tissue glutathione peroxidase. Proc Sot Exp Biol Med 148:1106–1110.
*Wahlberg JE. 1965. Percutaneous toxicity of metal compounds. A comparative investigation in guinea pigs. Arch Environ Health 11:201–204.5832249
Walberg JE. 1982. Metals and skin. In: Malbach HI, Gellin GA, eds. Occupational and industrial dermatology. Chicago, IL: Year Book Medical Publishers, Inc., 346–350.
*Walker F. 1971. Experimental argyria: A model for basement membrane studies. Br J Exp Pathol 52:589–593.5135534
Wallace A, Alexander GV, Chaudhry FM. 1977. Phytotoxicity of cobalt, vanadium, titanium, silver, and chromium. Communication in Soil Science and Plant Analysis 8:751–756.
*Ward NI, Roberts E, Brooks RR. 1979. Silver uptake by seedlings of Lolium perenne L. and Trifolium repens L. New Zealand Journal of Science 22:129–132.
*WDHSS. 1989. Written communication regarding State of Wisconsin regulation of silver levels in groundwater. Madison, WI: Wisconsin Department of Health and Social Services. (June 8).
*Weast RC, Astle MJ, Beyer WH, ed. 1988–1989. Handbook of chemistry and physics. 69th ed. Boca Raton, FL: CRC Press, Inc.
*Webster DA, Spadaro JA, Becker RO, . 1981. Silver anode treatment of chronic osteomyelitis. Clinical Orthopedics and Related Research 161:105–114.
Weir FW. 1979. Health hazard from occupational exposure to metallic copper and silver dust. American Industrial Hygiene Association Journal 40:245–247.495463
*Weiss G, ed. 1986. Hazardous chemicals data book. 2nd ed. Park Ridge, NJ: Noyes Data Corporation, 887–893.
Weitzenblum S, Peter J-D, Zawislak PR, . 1977. [Argyria: Apropos of a case in a child]. Pediatrie 32:371–375. (French).887357
Wenzloff DR. 1976. Distribution and abundance of heavy metals in finfish, invertebrates, and sediments collected at a deepwater disposal site. Marine Pollution Bulletin 7:185–187.
West HD, Goldie H. 1956. Topical localization in mouse of radioactive silver oxide (Ag111)20 introduced by various routes. Proc Sot Exp Biol Med 92:116–120.
West HD, Elliott RR, Johnson AP, . 1950. In vivo localization of radioactive silver at predetermined sites in tissues. American Journal Roentgenology Radium Therapy 64:831–834.
Weston RF, Chairman PE, Morrell RA. 1977. Treatment of water and waste water for removal of heavy metals. Viruses and trace contaminants in water and wastewater. Ann Arbor, MI: Ann Arbor Science Publishers, Inc., 167–181.
Whanger PD. 1976. Selenium versus metal toxicity in mammals. Proceedings of the Symposium on Selenium-Tellurium in the Environment:234–252.
Whanger PD. 1985. Metabolic interactions of selenium with cadmium, mercury, and silver. Adv Nutr Res 7:221–250.3913299
Whanger PD, Weswig PH, Schmitz JA, . 1976. Effects of selenium, cadmium, mercury, tellurium, arsenic, silver and cobalt on white muscle disease in lambs and effect of dietary forms of arsenic. Nutrition Reports International 14:63–72.
White IR, Rycroft RJG. 1982. Contact dermatitis from silver fulminate-fulminate itch. Contact Dermatitis 8:159–163.6212182
*Whitlow SI, Rice DL. 1985. Silver complexation in river waters of central New York. Water Res. 19:619–626.
Wilhelm FX, Daune M. 1969. [Interactions of metallic ions with DNA. III. Stability and configuration of Ag-DNA complexes], Biopolymers 8:121–137. (French).
*Windholz M, ed. 1983. The Merck index. 10 ed. Rahway, NJ: Merck & Co., Inc., 8338, 8343, 8352–8357.
Wise SA, Zeisler R. 1984. The pilot environmental specimen bank program. Environ Sci Technol 18:302a–307a.
Wood M. 1965. Silver nitrate and burns--caution. Ariz Med 2:817.
Wright DC, Gallant RF, Spangberg L. 1982. Correlation of corrosion behavior and cytotoxicity in Au-Cu-Ag ternary alloys. J Biomed Mater Res 16:509–517.7107663
Wysor MS. 1975. Orally administered silver sulfadiazine: Chemotherapy and toxicology in CF-1 mice; Plasmodium berghei (malaria) and Pseudomonas aerygubis. Chemotherapy 21:302–310.807459
Yatomi H. 1986. Study on the interaction of trace metals, silver and copper. J Yonago Med Ass 37:405–414.
Yatomi H, Nose T, Sugiyama K, . 1983. [The interaction between silver and copper in the rat]. Igaku to Seibutsugaku 107:265–267. (Japanese).
Yoshida M, Tashiro H, Iwami K, . 1983. Bioavailability of selenite, selenomethionine and selenocystine in rats with silver loading. Agric Biol Chem 47:807–813.
Yoshikawa H. 1970. Preventive effect of pretreatment with low dose of metals on the acute toxicity of metals in mice. Ind Health 8:184–191.
Zakour RA, Kunkel TA, Loeb LA. 1981. Metal-induced infidelity of DNA synthesis. Environ Health Perspect 40:197–205.7274184
Zech P, Colon S, Labeeuw R, . 1973. [Nephrotic syndrome with deposits in the glomerular basement membranes during argyria]. Nouv Presse Med 2:161–164. (French).4685019
Zegarelli EV, Kutscher AH. 1978. Toxicity reactions. In: Zegarelli EV, Kutscher AH, Hyman GA, eds. Diagnosis of diseases of the mouth and jaws. 2nd ed. Philadelphia, PA: Lea & Febiger, 327–331.
Zieker AW, Wisnicki J. 1979. Cornea1 burns from watch battery explosion. Am J Ophthalmol 88:798–9.