# 7 REGULATIONS AND ADVISORIES

Silver is on the list of chemicals appearing in “Toxic Chemicals Subject to Section 313 of the Emergency Planning and Community Right-to-Know Act of 1986” (EPA 1987b).

No international regulations pertaining to silver were found. The national and state regulations and guidelines regarding silver in air, water, and other media are summarized in Table 7-1.

TABLE 7-1 Regulations and Guidelines Applicable to Silver

Agency | | Description | Value | Reference
[underlined: National]
Regulations:
a. | Air:
a. | OSHA | PEL TWA (metal and soluble compound) | 0.01 mg/m^3^ | OSHA 1988b (29 CFR 1910.1000)
b. | Water:
b. | EPA ODW | Drinking water MCL^a^ | 0.05 mg/L | EPA 1987d (40 CFR 141)
b. | EPA ODW | Proposed drinking water SMCL | 0.09 mg/L | EPA 1989b
b. | EPA ODW | Permissible levels in bottled water | 0.05 mg/L | FDA 1988a (21 CFR 103.35)
b. | FDA | | | FDA 1988a (21 CFR 103.35)
c. | Other:
c. | EPA OSW | Silver nitrate designated as hazardous waste substance | No data | EPA 1987a (40 CFR 116.4)
c. | EPA OERR | Reportable Quantity (RQ) | | EPA 1988b (40 CFR 302.4)
c. | EPA OERR | (silver and compounds) | 1000 lb | EPA 1988b (40 CFR 302.4)
c. | EPA OERR | (silver nitrate) | 1 lb | EPA 1988b (40 CFR 302.4)
c. | EPA OTS | Toxic chemical release reporting; community right-to-known (proposed) (silver and compounds) | No data | EPA 1987b (52 FR 21152)
c. | OSHA | Meets proposed medical records rule | No data | OSHA 1988a (29 CFR 1910.20)
Guidelines:
a. | Air:
a. | ACGIH | TLV TWA:
a. | ACGIH | Silver metal dust | 0.1 mg/m^3^ | ACGIH 1986
a. | ACGIH | Airborne soluble silver compounds | 0.01 mg/m^3^
a. | NIOSH | Recommended exposure limit | 0.01 mg/m^3^ | NIOSH 1985
a. | NIOSH | IDLH (silver and soluble silver compounds) | 0.01 mg/m^3^ | NIOSH 1985
b. | Water:
b. | EPA ODW | Recommended drinking water limits | 0.05 mg/L | EPA 1985a
b. | EPA OWRS | Ambient water quality criteria to protect human health ingesting water and organisms | 0.05 mg/L | EPA 1980b (45 FR 79318)
c. | Other:
c. | EPA | RfD (oral) | 3×10^−3^ mg/kg/day | IRIS 1989
c. | EPA ODW | Carcinogen classification | Group D^b^ | EPA 1988a
[underlined: State]
| | Regulations:
a. | Water: | Maximum concentration levels in drinking water: | 0.05 mg/L | CELDS 1988
a. | Alabama
a. | Alaska
a. | Arkansas
a. | Arizona
a. | California
a. | Colorado
a. | Connecticut
a. | Delaware
a. | District of Columbia
a. | Florida
a. | Hawaii
a. | Idaho
a. | Illinois
a. | Indiana
a. | Kansas
a. | Kentucky
a. | Louisiana
a. | Maine
a. | Maryland
a. | Massachusetts
a. | Michigan
a. | Mississippi
a. | Minnesota
a. | Missouri
a. | Montana
a. | Nebraska
a. | Nevada
a. | New Hampshire
a. | New Mexico
a. | New York
a. | North Carolina
a. | North Dakota
a. | Ohio
a. | Oklahoma
a. | Oregon
a. | Pennsylvania
a. | Rhode Island
a. | South Carolina
a. | South Dakota
a. | Tennessee
a. | Texas
a. | Utah
a. | Vermont
a. | Virginia
a. | Washington
a. | West Virginia
a. | Wisconsin
a. | Wyoming
a. | | Groundwater concentration limits^c^: | 0.05 mg/L | CELDS 1988
a. | Colorado
a. | Indiana
a. | Kentucky
a. | Massachusetts
a. | Nevada
a. | New Mexico
a. | New York
a. | Wisconsin | | 0.05 mg/L | WDHSS 1989
a. | | Water quality criteria^d^ | 0.05 mg/L | CELDS 1988
a. | Arizona
a. | Mississippi
a. | New Jersey
a. | New York
a. | South Dakota
a. | Virginia

a The EPA has proposed to delete the MCL for silver (EPA 1989b).

b Group D. Not classifiable as to carcinogenicity in humans.

c The classification of groundwater by future use may vary between states.

d The criteria upon which this value is based may vary between states, e.g., recreation aquatic life, etc.

ACGIH = American Conference of Government Industrial Hygienists; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; IDLH = Immediately Dangerous to Life or Health; MCL = Maximum Contaminant Level; NIOSH = National Institute for Occupational Safety and Health; ODW = Office of Drinking Water; OERR = Office of Emergency and Remedial Response; OSHA = Occupational Safety and Health Administration; OSW = Office of Solid Wastes; OTS = Office of Toxic Substances; OWRS = Office of Water Regulations and Standards; PEL = Permissible Exposure Limit; RfD = Reference Dose; RQ = Reportable Quantity; SMCL = Secondary Maximum Contaminant Level; TLV = Threshold Limit Value; TWA = Time-Weighted Average