# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

The synonyms and identification numbers for silver and selected silver compounds are listed in Tables 3-1 through 3-6.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Important physical and chemical properties of silver and selected silver compounds are given in Tables 3-7 through 3-12.

TABLE 3-1 Chemical Identity of Silver

| Value | Reference
Chemical name | Silver
Synonyms | Silver; argentum; argentum crede; CI 77820; shell silver; silver atom; silver colloidal; silflake; silpowder; silber | CHEMLINE 1988; HSDB 1988
Trade names | No data
Chemical formula | Ag | Grayson 1983; Windholz 1983
Chemical structure | Ag | HSDB 1988
Wiswesser | ● Ag | HSDB 1988
Identification numbers:
CAS Registry | 7440-22-4 | HSDB 1988
NIOSH RTECS | VW 3500000 | HSDB 1988
EPA Hazardous Waste | DO11 | HSDB 1988
OHM/TADS | 7216881 | HSDB 1988
DOT/UN/NA/IMCO shipping | No data
HSDB | 5034 | HSDB 1988
NCI | No data
STCC | No data

HSDB = Hazardous Substance Data Bank; CAS = Chemical Abstracts Services; NIOSH = National Institute for Occupational Safety and Health; RTECS = Registry of Toxic Effects of Chemical Substances; EPA = Environmental Protection Agency; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; NCI = National Cancer Institute; and STCC = Standard Transport Commodity Code.

TABLE 3-2 Chemical Identity of Silver Nitrate

| Value | Reference
Chemical name | Silver nitrate
Synonyms | Lunar caustic; fused silver nitrate; molded silver nitrate; argenti; nitras; nitric acid silver (I) salt; nitric acid silver (1+) salt; Silver (1+) nitrate | HSDB 1988; Weiss 1986; Windholz
Trade names | No data
Chemical formula | AgNO_3_ | Grayson 1983; Weiss 1986
Chemical structure | Ag^+^ NO_3_^−^ | HSDB 1988
Wiswesser | AG N-03 | HSDB 1988
Identification numbers:
CAS Registry | 7761-88-8 | Grayson 1983; Weiss 1986
NIOSH RTECS | VW 4725000 | HSDB 1988
EPA Hazardous Waste | No data
OHM/TADS | 7216883 | HSDB 1988
DOT/UN/NA/IMCO shipping | DOT 1493 | Weiss 1986
DOT/UN/NA/IMCO shipping | UN 1493 | HSDB 1988
DOT/UN/NA/IMCO shipping | IMCO 5.1
HSDB | 685 | HSDB 1988
NCI | No data
STCC | 49 187 42 | HSDB 1988

HSDB = Hazardous Substance Data Bank; CAS = Chemical Abstracts Services; NIOSH = National Institute for Occupational Safety and Health; RTECS = Registry of Toxic Effects of Chemical Substances; EPA = Environmental Protection Agency; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; NCI = National Cancer Institute; and STCC = Standard Transport Coranodity Code.

TABLE 3-3 Chemical Identity of Silver (I) Oxide

| Value | Reference
Chemical name | Silver (I) oxide
Synonyms | Argentous oxide; silver (1+) oxide; disilver oxide; silver oxide | Windholz 1983
Trade names | No data
Chemical formula | Ag_2_O | Grayson 1983; Weiss 1986
Chemical structure | Ag^+^ O^2−^ Ag^+^ | RTECS 1989
Wiswesser | AG 2-0 | RTECS 1989
Identification numbers:
CAS Registry | 20667-12-3 | Grayson 1983
NIOSH RTECS | VW 4900000 | RTECS 1989
EPA Hazardous Waste | No data
OHM/TADS | No data
DOT/UN/NA/IMCO shipping | IMO/UN-not listed | Weiss 1986
HSDB | No data
NCI | No data
STCC | No data

RTECS = Registry of Toxic Effects of Chemical Substances; CAS = Chemical Abstracts Services; NIOSH = National Institute for Occupational Safety and Health; EPA = Environmental Protection Agency; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; HSDB = Hazardous Substance Data Bank; NCI = National Cancer Institute; and STCC = Standard Transport Commodity Code.

TABLE 3-4 Chemical Identity of Silver (II) Oxide

| Value | Reference
Chemical name | Silver (II) oxide
Synonyms | Argentic oxide; silver peroxide; silver suboxide; divasil | Windholz 1983
Trade names | No data
Chemical formula | AgO | Grayson 1983
Chemical structure | Ag^2+^ O^2−^ | Grayson 1983
Wiswesser | No data
Identification numbers:
CAS Registry | 1301-96-8, 35366-11-1 | Grayson 1983
NIOSH RTECS | No data
EPA Hazardous Waste | No data
OHM/TADS | No data
DOT/UN/NA/IMCO shipping | No data
HSDB | No data
NCI | No data
STCC | No data

CAS = Chemical Abstracts Services; NIOSH = National Institute for Occupational Safety and Health; RTECS = Registry of Toxic Effects and Chemical Registry; EPA = Environmental Protection Agency; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; HSDB = Hazardous Substance Data Bank; NCI = National Cancer Institute; and STCC = Standard Transport Commodity Code.

TABLE 3-5 Chemical Identity of Silver Sulfide

| Value | Reference
Chemical name | Silver sulfide
Synonyms | Acanthite; argentous sulfide | Weast 1988; Windholz 1983
Trade names | No data
Chemical formula | Ag_2_S | Grayson 1983
Chemical structure | Ag^+^ S^2−^ Ag^+^ | Windholz 1983
Wiswesser | No data
Identification numbers:
CAS Registry | 21548-73-2 | Grayson 1983
NIOSH RTECS | No data
EPA Hazardous Waste | No data
OHM/TADS | No data
DOT/UN/NA/IMCO shipping | No data
HSDB | No data
NCI | No data
STCC | No data

CAS = Chemical Abstracts Services; NIOSH = National Institute for Occupational Safety and Health; RTECS = Registry of Toxic Effects of Chemical Substances; EPA = Environmental Protection Agency; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; and STCC = Standard Transport Commodity Code.

TABLE 3-6 Chemical Identity of Silver Chloride

| Value | Reference
Chemical name | Silver chloride
Synonyms | Silver (I) chloride; Silver monochloride | RTECS 1988
Trade names | No data
Chemical formula | AgCl | Grayson 1983
Chemical structure | Ag^+^ Cl^−^ | RTECS 1988
Wiswesser | No data
Identification numbers:
CAS Registry | 7783-90-6 | Grayson 1983
NIOSH RTECS | VW 3563000 | RTECS 1988
EPA Hazardous Waste | No data
OHM/TADS | No data
DOT/UN/NA/IMCO shipping | No data
HSDB | No data
NCI | No data
STCC | No data

RTECS = Registry of Toxic Effects of Chemical Substances; CAS = Chemical Abstracts Services; NIOSH = National Institute for Occupational Safety and Health; EPA = Environmental Protection Agency; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; HSDB = Hazardous Substance Data Bank; NCI = National Cancer Institute; and STCC = Standard Transport Commodity Code.

TABLE 3-7 Physical and Chemical Properties of Silver

| Value | Reference
Molecular weight | 107.868 | Weast 1988
Color | Lustrous, white | Weast 19-88
Physical state | Solid metal | Grayson 1983
Valence state | + 1, +2 | Windholz 1983
Melting point | 961.93°C | Weast 1988
Boiling point | 2,212°C at 760 mmHg | Weast 1988
Density at 20°C | 10.50 g/cm^3^ | Weast 1988
20°C | 10.43 g/cm^3^ (hard drawn) | Grayson 1983
20 °C | 10.49 g/cm^3^ (annealed | Grayson 1983
Odor | No data
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 20°C | Insoluble; soluble in nitric acid, not in sulfuric acid and alkali cyanide solutions | Windholz 1983; ITII 1982
Organic solvents | No data
Partition coefficients | No data
Vapor pressure:
Liquid silver at 1,865°C | 100 mmHg | Weast 1988
Henry’s law constant | No data
Autoignition temperature | No data
Flashpoint | No data
Flammability limits | Dust is moderately flammable | ITII 1982
Conversion factors | Troy ounces × 31.1034768 = grams | Weast 1988

TABLE 3-8 Physical and Chemical Properties of Silver Nitrate

| Value | Reference
Molecular weight | 169.89 | Weast 1988
Color | Colorless or white | Grayson 1983
Physical state | Solid crystalline | Weast 1988
Melting point | 212°C | Grayson 1983
Boiling point | Decomposes at 440°C | Grayson 1983
Density at 19°C | 4.35 | HSDB 1988
at 19°C | 4.33 | Weiss 1986
Odor | Odorless | Weiss 1986
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 0°C | 122 g/100 mL H_2_O at 0°C | HSDB 1988
Organic solvents | Soluble in ethanol and acetone | Grayson 1983
Partition coefficients | No data
Vapor pressure | No data
Henry’s law constant | No data
Autoignition temperature | Not flammable | Weiss 1986
Flashpoint | Not flammable | Weiss 1986
Flammability limits | Not flammable | Weiss 1986

TABLE 3-9 Physical and Chemical Properties of Silver (I) Oxide

| Value | Reference
Molecular weight | 231.8 | Weiss 1986
Color | Dark brown-to-black | Windholz 1983
Physical state | Solid crystalline | Weast 1988; Weiss 1986;; Windholz 1983
Melting point | Decomposes at 230°C | Weast 1988
Boiling point | Decomposes between 200°-300°C | Windholz 1983
Boiling point | Decomposition complete at 300°C | Grayson 1983
Density at 20°C | 7.14 g/cm^3^ | Weiss 1986
Odor | Odorless | Weiss 1986
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 25°C | 2.2×10^−2^ g/L | Grayson 1983
Organic solvents | Practically insoluble in alcohol | Windholz 1983
Partition coefficients | No data
Vapor pressure | No data
Henry’s law constant | No data
Autoignition temperature | No data
Flashpoint | Not flanmable | Weiss 1986
Flammability limits | Not flanmable | Weiss 1986

TABLE 3-10 Physical and Chemical Properties of Silver (II) Oxide

| Value | Reference
Molecular weight | 123.88 | Windholz 1983
Color | Charcoal gray powder, black crystal | Grayson 1983; Windholz 1983
Physical state | Solid | Windholz 1983
Melting point | No data
Boiling point | Decomposes above 100°C | Windholz 1983
Density | No data
Odor | No data
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 20°C | Decomposes in aqueous solution | Windholz 1983
Organic solvents | No data
Partition coefficients: | No data
Vapor pressure | No data
Henry’s law constant | No data
Autoignition temperature | No data
Flashpoint | No data
Flammability limits | No data

TABLE 3-11 Physical and Chemical Properties of Silver Sulfide

| Value | Reference
Molecular weight | 247.80 | Weast 1988
Color | Gray-black | Weast 1988
Physical state | Solid | Grayson 1983
Melting point | No data
Boiling point | Decomposes at 810°C | Grayson 1983
Density at 20°C | 7.326 g/cm^3^ | Weast 1988
Odor | No data
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 20°C | 1.4×10^−4^ g/L | Grayson 1983
Organic solvents | No data
Partition coefficients | No data
Vapor pressure | No data
Henry’s law constant | No data
Autoignition temperature | No data
Flashpoint | No data
Flammability limits | No data

TABLE 3-12 Physical and Chemical Properties of Silver Chloride

| Value | Reference
Molecular weight | 143.34 | Windholz 1983
Color | White | Windholz 1983
Physical state | Solid | Windholz 1983
Melting point | 455°C | Windholz 1983
Boiling point | 1,550°C | Windholz 1983
Density at 20°C | 5.56 g/cm^3^ | Windholz 1983
Odor | No data
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 25°C | 1.93 mg/L | Windholz 1983
Organic solvents | No data
Partition coefficients | No data
Vapor pressure
Henry’s law constant | No data
Autoignition temperature | No data
Flashpoint | No data
Flammability limits | No data