# CHAPTER 8 REFERENCES

+ Cited in supplemental document

Abderrazak A, Syrovets T, Couchie D, . 2015. NLRP3 inflammasome: from a danger signal sensor to a regulatory node of oxidative stress and inflammatory diseases. Redox biol 4:296–307. 10.1016/j.redox.2015.01.008.25625584
Abdul-Wahab SA, Worthing MA, Al-Maamari S. 2005. Mineralogy of atmospheric suspended dust in three indoor and one outdoor location in Oman. Environ Monit Assess 107(1–3):313–327. 10.1007/s10661-005-3112-4.16418920
Absher MP, Hemenway DR, Leslie KO, . 1992. Intrathoracic distribution and transport of aerosolized silica in the rat. Exp Lung Res 18(5):743–757. 10.3109/01902149209031705.1327732
Adler AJ, Berlyne GM. 1986. Silicon metabolism. II. Renal handling in chronic renal failure patients. Nephron 44(1):36–39.
Aggarwal BD. 2014. Lactate dehydrogenase as a biomarker for silica exposure-induced toxicity in agate workers. Occup Environ Med 71(8):578–582. 10.1136/oemed-2014-102190.24876203
Akbar-Khanzadeh F, Milz S, Ames A, . 2007. Crystalline silica dust and respirable particulate matter during indoor concrete grinding - wet grinding and ventilated grinding compared with uncontrolled conventional grinding. J Occup Environ Hyg 4(10):770–779. 10.1080/15459620701569708.17763068
Akbar-Khanzadeh F, Milz SA, Wagner CD, . 2010. Effectiveness of dust control methods for crystalline silica and respirable suspended particulate matter exposure during manual concrete surface grinding. J Occup Environ Hyg 7(12):700–711. 10.1080/15459624.2010.527552.21058155
Akgun M. 2016. Denim production and silicosis. Curr Opin Pulm Med 22(2):165–169. 10.1097/mcp.0000000000000249.26807688
Althouse RB, Bang KM, Castellan RM. 1995. Tuberculosis comortality with silicosis—United States, 1979-1991. Appl Occup Environ Hyg 10(12):1037–1041.
Altindag ZZ, Baydar T, Isimer A, . 2003. Neopterin as a new biomarker for the evaluation of occupational exposure to silica. Int Arch Occup Environ Health 76(4):318–322. 10.1007/s00420-003-0434-9.12768284
Altree-Williams S, Sprogis I. 1982. Quartz: correlation between crystallinity index and fibrogenicity? Ann Occup Hyg 25(4):455–458.6299158
Amandus H, Costello J. 1991. Silicosis and lung cancer in US metal miners. Arch Environ Health 46(2):82–89.2006898 (As cited in Erren et al. 2009a, 2009b; Lacrasse et al. 2005)
Amandus HE, Shy C, Wing S, . 1991. Silicosis and lung cancer in North Carolina dusty trades workers. Am J Ind Med 20(1):57–70.1867218 (As cited in Erren et al. 2009a, 2009b; Lacrasse et al. 2005)
Amandus HE, Shy C, Castellan RM, . 1995. Silicosis and lung cancer among workers in North Carolina dusty trades. Scand J Work Environ Health 21 Suppl 2:81–83. (As cited in Kurihara and Wada 2004)
Andersson L, Bryngelsson IL, Ngo Y, . 2012. Exposure assessment and modeling of quartz in Swedish iron foundries for a nested case-control study on lung cancer. J Occup Environ Hyg 9(2):110–119. 10.1080/15459624.2011.645397.22239127
Archer JD, Cooper GS, Reist PC, . 2002. Exposure to respirable crystalline silica in eastern North Carolina farm workers. AIHA J (Fairfax, Va) 63(6):750–755.12570084
Armstrong BK, McNulty JC, Levitt LJ, . 1979. Mortality in gold and coal miners in Western Australia with special reference to lung cancer. Br J Ind Med 36(3):199–205.315411 (As cited in Erren et al. 2009a, 2009b)
+Arts JH, Muijser H, Duistermaat E, . 2007. Five-day inhalation toxicity study of three types of synthetic amorphous silicas in Wistar rats and post-exposure evaluations for up to 3 months. Food Chem Toxicol 45(10):1856–1867. 10.1016/j.fct.2007.04.001.17524541
+Aschengrau A, Zierler S, Cohen A. 1989. Quality of community drinking water and the occurrence of spontaneous abortion. Arch Environ Health 44(5):283–290. 10.1080/00039896.1989.9935895.2554824
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 2015. Silica. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/SPL/resources/index.html. July 6, 2016.
Bailey MR, Ansoborlo E, Guilmette RA, . 2007. Updating the ICRP human respiratory tract model. Radiat Prot Dosimetry 127(1–4):331–334.
Bakke B, Ulvestad B, Stewart P, . 2004. Cumulative exposure to dust and gasses as determinants of lung function in tunnel construction workers. Occup Environ Med 61:262–269.14985522
Bang BE, Suhr H. 1998. Quartz exposure in the slate industry in northern Norway. Ann Occup Hyg 42(8):557–563.9838869
Bang KM, Attfield MD, Wood JM, . 2008. National trends in silicosis mortality in the United States, 1981-2004. Am J Ind Med 51(9):633–639. 10.1002/ajim.20607.18626906
Bang KM, Mazurek JM, Wood JM, . 2015. Silicosis mortality trends and new exposures to respirable crystalline silica - United States, 2001-2010. MMWR Morb Mortal Wkly Rep 64(5):117–120.25674992
Barredo BF, Polo Diez L. 1980. Routine accurate determination of silica in silicate materials by atomic-absorption spectrophotometry and subsequent computation. Talanta 27:69–70.18962618
Bartunkova J, Pelclova D, Fenclova Z, . 2006. Exposure to silica and risk of ANCA-associated vasculitis. Am J Ind Med 49(7):569–576. 10.1002/ajim.20327.16691610
Basaran N, Shubair M, Undeger U, . 2003. Monitoring of DNA damage in foundry and pottery workers exposed to silica by the alkaline comet assay. Am J Ind Med 43(6):602–610. 10.1002/ajim.10222.12768610
Beaudreuil S, Lasfargues G, Laueriere L, . 2005. Occupational exposure in ANCA-positive patients: a case-control study. Kidney Int 67(5):1961–1966. 10.1111/j.1523-1755.2005.00295.x.15840044
Beaudry C, Lavoue J, Sauve JF, . 2013. Occupational exposure to silica in construction workers: a literature-based exposure database. J Occup Environ Hyg 10(2):71–77. 10.1080/15459624.2012.747399.23252413
Beckett W, Abraham J, Becklake M, . 1997. Adverse effects of crystalline silica exposure. Am J Respir Crit Care Med 155(2):761–768.9032226
Begin R, Filion R, Ostiguy G. 1995. Emphysema in silica and asbestos-exposed workers seeking compensation. A CT scan study. Chest 108(3):647–655.7656611
Begin R, Masse S, Sebastien P, . 1987. Sustained efficacy of aluminum to reduce quartz toxicity in the lung. Exp Lung Res 13(2):205–222.2822380
Berlyne GM, Adler AJ, Ferran N, . 1986. Silicon metabolism. I. Some aspects of renal silicon handling in normal man. Nephron 43(1):5–9.3703066
Berry G, Rogers A, Yeung P. 2004. Silicosis and lung cancer: A mortality study of compensated men with silicosis in New South Wales, Australia. Occup Med (London) 54(6):387–394. 10.1093/occmed/kqh029.15347775
Beskow R. 1978. Silicosis in diatomaceous earth factory workers in Sweden. Scand J Respir Dis 59(4):216–221.211578
Bhagia LJ. 2009. Non-occupational exposure to silica dust in vicinity of slate pencil industry, India. Environ Monit Assess 151(1–4):477–482. 10.1007/s10661-008-0290-x.18566906
Bhagia LJ. 2012. Non-occupational exposure to silica dust. Indian J Occup Environ Med 16(3):95–100. 10.4103/0019-5278.111744.23776316
Birk T, Mundt KA, Guldner K, . 2009. Mortality in the German porcelain industry 1985-2005: first results of an epidemiological cohort study. J Occup Environ Med 51(3):373–385. 10.1097/JOM.0b013e3181973e19.19225421
Birk T, Guldner K, Mundt KA, . 2010. Quantitative crystalline silica exposure assessment for a historical cohort epidemiologic study in the German porcelain industry. J Occup Environ Hyg 7(9):516–528. 10.1080/15459624.2010.487789.20552502
Borm PJ, Tran L. 2002. From quartz hazard to quartz risk: the coal mines revisited. Ann Occup Hyg 46(1):25–32 12005128
Bott J, Stormer A, Franz R. 2015. Investigation into the migration potential of colloidal silica from food packaging plastics into food. Fraunhofer https://www.ivv.fraunhofer.de/content/dam/ivv/en/documents/Forschungsfelder/Produktsicherheit-und-analytik/Migration_potential_of_colloidal_silica_from_food_packaging_plastics_into_food.pdf.
Boujemaa W, Lauwerys R, Bernard A. 1994. Early indicators of renal dysfunction in silicotic workers. Scand J Work Environ Health 20(3):180–183.7973489
Bovenzi M, Barbone F, Betta A, . 1995. Scleroderma and occupational exposure. Scand J Work Environ Health 21(4):289–292.8553004
Bovenzi M, Barbone F, Pisa FE, . 2004. A case-control study of occupational exposures and systemic sclerosis. Int Arch Occup Environ Health 77(1):10–16. 10.1007/s00420-003-0462-5.14530983
Bratveit M, Moen BE, Mashalla YJ, . 2003. Dust exposure during small-scale mining in Tanzania: A pilot study. Ann Occup Hyg 47(3):235–240.12639837
Braz NF, Carneiro AP, Amorim MR, . 2014. Association between inflammatory biomarkers in plasma, radiological severity, and duration of exposure in patients with silicosis. J Occup Environ Med 56(5):493–497. 10.1097/jom.0000000000000164.24806562
Brody AR, Roe MW, Evans JN, . 1982. Deposition and translocation of inhaled silica in rats. Quantification of particle distribution, macrophage participation, and function. Lab Invest 47(6):533–542.6292578
Brooks SM, Stockwell HG, Pinkham PA, . 1992. Sugarcane exposure and the risk of lung cancer and mesothelioma. Environ Res 58:195–203.1511673
Brown T. 2009. Silica exposure, smoking, silicosis and lung cancer--complex interactions. Occup Med (London) 59(2):89–95. 10.1093/occmed/kqn171.19233828
Brown GM, Donaldson K. 1996. Modulation of quartz toxicity by aluminum. In: Castranova V, Vallyathan V, Wallace WE, eds. Silica and silica-induced lung diseases. Boca Raton, FL: CRC Press, 299–304.
Brown TP, Rushton L. 2005a. Mortality in the UK industrial silica sand industry: 1. Assessment of exposure to respirable crystalline silica. Occup Environ Med 62(7):442–445. 10.1136/oem.2004.017715.15961619
Brown TP, Rushton L. 2005b. Mortality in the UK industrial silica sand industry: 2. A retrospective cohort study. Occup Environ Med 62(7):446–452. 10.1136/oem.2004.017731.15961620
Brown D, Kaplan S, Zumwalde R, . 1986. Retrospective cohort mortality study of underground gold mine workers. In: Goldsmith DF, Winn DM, Shy CM, eds. Silica, silicosis, and cancer: Controversy in occupational medicine. New York: Praeger, 335–350. (As cited in Mannetje et al. 2002b)
Brown LM, Gridley G, Olsen JH, . 1997. Cancer risk and mortality patterns among silicotic men in Sweden and Denmark. J Occup Environ Med 39(7):633–638.9253724
Bruske I, Thiering E, Heinrich J, . 2014. Respirable quartz dust exposure and airway obstruction: a systematic review and meta-analysis. Occup Environ Med 71(8):583–589. 10.1136/oemed-2013-101796.24863263
Bruske-Hohlfeld I, Mohner M, Pohlabeln H, . 2000. Occupational lung cancer risk for men in Germany: Results from a pooled case-control study. Am J Epidemiol 151(4):384–395.10695597 (As cited in Kurihara and Wada 2004; Lacasse et al. 2009; Pelucci et al. 2006)
Burns CJ, Laing TJ, Gillespie BW, . 1996. The epidemiology of scleroderma among women: Assessment of risk from exposure to silicone and silica. J Rheumatol 23(11):1904–1911.8923364
Cakmak GD, Schins RP, Shi T, . 2004. In vitro genotoxicity assessment of commercial quartz flours in comparison to standard DQ12 quartz. Int J Hyg Environ Health 207(2):105–113. 10.1078/1438-4639-00276.15031953
Caldwell DM. 1958. The coalescent lesion of diatomaceous earth pneumoconiosis. Am Rev Tuberc 77:644–661.13521260
Calvert GM, Steenland K, Palu S. 1997. End-stage renal disease among silica-exposed gold miners. A new method for assessing incidence among epidemiologic cohorts. J Am Med Assoc 277(15):1219–1223.
Calvert GM, Rice FL, Boiano JM, . 2003. Occupational silica exposure and risk of various diseases: An analysis using death certificates from 27 states of the United States. Occup Environ Med 60(2):122–129.12554840
Carta P, Aru G, Manca P. 2001. Mortality from lung cancer among silicotic patients in Sardinia: An update study with 10 more years of follow up. Occup Environ Med 58(12):786–793.11706145 (As cited in Erren et al. 2009a, 2009b; Lacrasse et al. 2005; Pelucci et al. 2006)
Case BW, Dufresne A, Richardson L, . 1995. Lung-retained dose following occupational exposure to silica. Appl Occup Environ Hyg 10(12):1031–1036.
Cassel SL, Eisenbarth SC, Iyer SS, . 2008. The Nalp3 inflammasome is essential for the development of silicosis. Proc Natl Acad Sci USA 105(26):9035–9040. 10.1073/pnas.0803933105.18577586
Castranova V, Vallyathan V. 2000. Silicosis and coal workers’ pneumoconiosis. Environ Health Perspect 108 Suppl 4:675–684.
CDC. 1998a. Silicosis deaths among young adults- United States, 1968-1994. MMWR Morb Mortal Wkly Rep 47(16):331–335.9583901
CDC. 1998b. Silicosis deaths among young adults- United States, 1968-1994. JAMA 280(1):13–15.9660349
Chalupka S. 2012. Occupational silica exposure in hydraulic fracturing. Workplace Health Saf 60(10):460. 10.3928/21650799-20120926-70.23054167
Chan CK, Leung CC, Tam CM, . 2000. Lung cancer mortality among a cohort of men in a silicotic register. J Occup Environ Med 42(1):69–75.10652691 (As cited in Kurihara and Wada 2004; Erren et al. 2009a, 2009b; Lacrasse et al. 2005; Pelucci et al. 2006)
Chan JYW, Tsui JCC, Law PTW, . 2017. Profiling of the silica-induced molecular events in lung epithelial cells using the RNA-Seq approach. J Appl Toxicol 37(10):1162–1173. 10.1002/jat.3471.28425640
Checkoway H. 2000. Epidemiological evidence on the carcinogenicity of silica: factors in scientific judgement. Ann Occup Hyg 44(6):483–484.11023442
Checkoway H, Franzblau A. 2000. Is silicosis required for silica-associated lung cancer? Am J Ind Med 37(3):252–259.10642414
Checkoway H, Heyer NJ, Demers PA. 1996a. An updated mortality follow-up study of Florida phosphate industry workers. Am J Ind Med 30(4):452–460. 10.1002/(sici)1097-0274(199610)30:4<452::aid-ajim11>3.0.co;2-3.8892551 (As cited in Pelucci et al. 2006)
Checkoway H, Heyer NJ, Demers PA, . 1993. Mortality among workers in the diatomaceous earth industry. Br J Ind Med 50(7):586–597.8343419
Checkoway H, Heyer NJ, Demers PA, . 1996b. Reanalysis of mortality from lung cancer among diatomaceous earth industry workers, with consideration of potential confounding by asbestos exposure. Occup Environ Med 53(9):645–647.8882123 (As cited in Mannetje et al. 2002b)
Checkoway H, Heyer NJ, Seixas NS, . 1997. Dose-response associations of silica with nonmalignant respiratory disease and lung cancer mortality in the diatomaceous earth industry. Am J Epidemiol 145(8):680–688.9125994
Checkoway H, Hughes JM, Weill H, . 1999. Crystalline silica exposure, radiological silicosis, and lung cancer mortality in diatomaceous earth industry workers. Thorax 54(1):56–59.10343633 (As cited in Erren et al. 2009a, 2009b; Kurihara and Wada 2004; Lacrasse et al. 2005; Pelucci et al. 2006)
ChemID. 2019. Silica compounds (7631-86-9, 14464-46-1, 14808-60-7, 15468-32-3, 60676-86-0, 61790-53-2, 63231-67-4, 68855-54-9, 69012-64-2, 91053-39-3, 112926-00-8, colloidal silica). U.S. National Library of Medicine. https://chem.nlm.nih.gov/chemidplus/. March 14, 2019.
Chen W, Chen J. 2002. Nested case-control study of lung cancer in four Chinese tin mines. Occup Environ Med 59(2):113–118.11850554 (As cited in Pelucci et al. 2006)
Chen F, Shi X. 2002. NF-κB, a pivotal transcription factor in silica-induced diseases. Mol Cell Biochem 234–235(1):169–176.12162430
Chen M, Tse LA. 2012. Laryngeal cancer and silica dust exposure: a systematic review and meta-analysis. Am J Ind Med 55(8):669–676. 10.1002/ajim.22037.22457229
Chen W, Bochmann F, Sun Y. 2007. Effects of work related confounders on the association between silica exposure and lung cancer: a nested case-control study among Chinese miners and pottery workers. Int Arch Occup Environ Health 80(4):320–326. 10.1007/s00420-006-0137-0.16897095
Chen SY, Hayes RB, Liang SR, . 1990. Mortality experience of haematite mine workers in China. Br J Ind Med 47(3):175–181.2328225 (As cited in Lacrasse et al. 2005)
Chen J, McLaughlin JK, Zhang JY, . 1992. Mortality among dust-exposed Chinese mine and pottery workers. J Occup Med 34(3):311–316.1312152
Chen W, Zhuang Z, Attfield MD, . 2001. Exposure to silica and silicosis among tin miners in China: Exposure-response analyses and risk assessment. Occup Environ Med 58(1):31–37.11119632
Chen W, Yang J, Chen J, . 2006. Exposures to silica mixed dust and cohort mortality study in tin mines: exposure-response analysis and risk assessment of lung cancer. Am J Ind Med 49(2):67–76. 10.1002/ajim.20248.16362950 (As cited in Poinen-Rughooputh et al. 2016)
Chen W, Liu Y, Wang H, . 2012. Long-term exposure to silica dust and risk of total and cause-specific mortality in Chinese workers: A cohort study. PLoS Med 9(4):e1001206. 10.1371/journal.pmed.1001206.22529751
Cherry NM, Burgess GL, Turner S, . 1998. Crystalline silica and risk of lung cancer in the potteries. Occup Environ Med 55(11):779–785.9924456 (As cited in Kurihara and Wada 2004; Pelucci et al. 2006)
Cherry N, Harris J, McDonald C, . 2013. Mortality in a cohort of Staffordshire pottery workers: follow-up to December 2008. Occup Environ Med 70(3):149–155. 10.1136/oemed-2012-100782.23104732
Chia KS, Ng TP, Jeyaratnam J. 1992. Small airways function of silica-exposed workers. Am J Ind Med 22(2):155–162.1329507
Chia SE, Chia KS, Phoon WH, . 1991. Silicosis and lung cancer among Chinese granite workers. Scand J Work Environ Health 17(3):170–174.1648788 (As cited in Erren et al. 2009a, 2009b; Lacrasse et al. 2005)
Chiazze L, Watkins DK, Fryar C. 1997. Historical cohort mortality study of a continuous filament fiberglass manufacturing plant. I. White men. J Occup Environ Med 39(5):432–441.9172088 (As cited in Pelucci et al. 2006)
Chiyotani K, Saito K, Okubo T, . 1990. Lung cancer risk among pneumoconiosis patients in Japan, with special reference to silicotics. IARC Sci Publ (97):95–104.
Choudat D, Frisch C, Barrat G, . 1990. Occupational exposure to amorphous silica dust and pulmonary function. Br J Ind Med 47(11):763–766.2173947
Churchyard GJ, Ehrlich R, teWaterNaude JM, . 2004. Silicosis prevalence and exposure-response relations in South African goldminers. Occup Environ Med 61(10):811–816. 10.1136/oem.2003.010967.15377766
Clark BH, Peacor DR. 1992. Pyrometamorphism and partial melting of shales during combustion metamorphism: Mineralogical, textural, and chemical effects. Contrib Mineral Petrol 112:558–568.
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Cocco PL, Carta P, Bario P, . 1990. Case-controlled study on silicosis and lung cancer. In: Sakurai H, Okazaki I, Omae K, eds. Occupational medicine: Proceedings of the 7th international symposium on epidemiology in occupational health. Amsterdam: Excerpta Medica. (As cited in Erren et al. 2009a, 2009b)
Cocco PL, Carta P, Belli S, . 1994. Mortality of Sardinian lead and zinc miners: 1960-88. Occup Environ Med 51(10):674–682.8000492
Cocco P, Rice CH, Chen JQ, . 2001. Lung cancer risk, silica exposure, and silicosis in Chinese mines and pottery factories: The modifying role of other workplace lung carcinogens. Am J Ind Med 40(6):674–682.11757044 (As cited in Erren et al. 2009a, 2009b; Lacasse et al. 2009; Pelucci et al. 2006)
Coggiola M, Bosio D, Pira E, . 2003. An update of a mortality study of talc miners and millers in Italy. Am J Ind Med 44(1):63–69. 10.1002/ajim.10240.12822137 (As cited in Pelucci et al. 2006)
Collins JF, Salmon AG, Brown JP, . 2005. Development of a chronic inhalation reference level for respirable crystalline silica. Regul Toxicol Pharmacol 43(3):292–300. 10.1016/j.yrtph.2005.08.003.16185799
Conrad K, Mehlhorn J, Luthke K, . 1996. Systemic lupus erythematosus after heavy exposure to quartz dust in uranium mines: Clinical and serological characteristics. Lupus 5(1):62–69.8646229
Cooper WC, Jacobson G. 1977. A 21-year radiographic follow-up of workers in the diatomite industry. J Occup Med 19(8):563–566.197217
Cooper WC, Sargent EN. 1984. A 26-year radiographic follow-up of workers in a diatomite mine and mill. J Occup Med 26(6):456–460.6330326
Cooper GS, Wither J, Bernatsky S, . 2010. Occupational and environmental exposures and risk of systemic lupus erythematosus: silica, sunlight, solvents. Rheumatology (Oxford) 49(11):2172–2180. 10.1093/rheumatology/keq214.20675707
Costa D, Fubini B, Giamello E, . 1991. A novel type of active site at the surface of crystalline silicon dioxide (alpha-quartz) and its possible impact on pathogenicity. Can J Chem 69(9):1427–1434.
Costello J, Graham WGB. 1988. Vermont granite workers’ mortality study. Am J Ind Med 13(4):483–497.2834946
Costello J, Castellan RM, Swecker GS, . 1995. Mortality of a cohort of U.S. workers employed in the crushed stone industry, 1940-1980. Am J Ind Med 27(5):625–640.7611302
Cowie RL. 1987. Silica-dust-exposed mine workers with scleroderma (systemic sclerosis). Chest 92(2):260–262.3038476
Cowie RL. 1994. The epidemiology of tuberculosis in gold miners with silicosis. Am J Respir Crit Care Med 150(5 Pt 1):1460–1462. 10.1164/ajrccm.150.5.7952577.7952577
Cowie RL, Hay M, Thomas RG. 1993. Association of silicosis, lung dysfunction, and emphysema in gold miners. Thorax 48(7):746–749.8153925
Cox LA, Jr. 2011. An exposure-response threshold for lung diseases and lung cancer caused by crystalline silica. Risk Anal 31(10):1543–1560. 10.1111/j.1539-6924.2011.01610.x.21477084
Daniel LN, Mao Y, Saffiotti U. 1993. Oxidative DNA damage by crystalline silica. Free Radic Biol Med 14(5):463–472.8394268
Daniel LN, Mao Y, Wang TC, . 1995. DNA strand breakage, thymine glycol production, and hydroxyl radical generation induced by different samples of crystalline silica in vitro. Environ Res 71(1):60–73.8757240
Das PB, Fletcher AG, Dordhare SG. 1976. Mesothelioma in an agricultural community of India: A clinicopathological study. Aust N Z J Med 46:218–226.
Davis GS. 1986. Pathogenesis of silicosis: Current concepts and hypotheses. Lung 164(3):139–154.3088337
Davis LK, Wegman DH, Monson RR, . 1983. Mortality experience of Vermont granite workers. Am J Ind Med 4(6):705–723.6316782 (As cited in Mannetje et al. 2002b)
Davis BL, Johnson LR, Stevens RK, . 1984. The quartz content and elemental composition of aerosols from selected sites of the EPA inhalable particulate network. Atmos Environ 18(4):771–782.
De Berardis B, Incocciati E, Massera S, . 2007. Airborne silica levels in an urban area. Sci Total Environ 382(2–3):251–258. 10.1016/j.scitotenv.2007.04.044.17553550
De Klerk NH, Musk AW. 1998. Silica, compensated silicosis, and lung cancer in Western Australian goldminers. Occup Environ Med 55(4):243–248.9624278
De Stefani E, Kogevinas M, Boffetta P, . 1996. Occupation and the risk of lung cancer in Uruguay. Scand J Work Environ Health 22(5):346–352.8923607 (As cited in Kurihara and Wada 2004; Pelucci et al. 2006)
Deane KD, El-Gabalawy H. 2014. Pathogenesis and prevention of rheumatic disease: Focus on preclinical RA and SLE. Nat Rev Rheumatol 10(4):212–228.24514912
Deb U, Lomash V, Raghuvanshi S, . 2012. Effects of 28 days silicon dioxide aerosol exposure on respiratory parameters, blood biochemical variables and lung histopathology in rats. Environ Toxicol Pharmacol 34(3):977–984. 10.1016/j.etap.2012.07.009.22974794
Demircigil GC, Coskun E, Vidinli N, . 2010. Increased micronucleus frequencies in surrogate and target cells from workers exposed to crystalline silica-containing dust. Mutagenesis 25(2):163–169. 10.1093/mutage/gep057.19939883
Demoruelle MK, Deane KD, Holers VM. 2014. When and where does inflammation begin in rheumatoid arthritis? Curr Opin Rheumatol 26(1):64–71.24247116
Ding M, Chen F, Shi X, . 2002. Diseases caused by silica: Mechanisms of injury and disease development. Int Immunopharmacol 2(2–3):173–182.11811922
Dion C, Dufresne A, Jacob M, . 2005. Assessment of exposure to quartz, cristobalite and silicon carbide fibres (whiskers) in a silicon carbide plant. Ann Occup Hyg 49(4):335–343. 10.1093/annhyg/meh099.15650014
Diot E, Lesire V, Guilmot JL, . 2002. Systemic sclerosis and occupational risk factors: A case-control study. Occup Environ Med 59(8):545–549.12151611
+Dobbie JW, Smith MJ. 1982. Silicate nephrotoxicity in the experimental animal: the missing factor in analgesic nephropathy. Scott Med J 27(1):10–16.6278583
Dobreva M, Burilkov T, Kolev K, . 1975. Characteristics of lung dusts and their relation to dust exposure and pathological findings in the lungs. In: Inhaled particles IV. Proceedings of an international symposium organized by The British Occupational Hygiene Society, Edinburgh, 22–26 September 1975. Vol. 4 Pt 2. Oxford: Pergamon Press, 717–725.
DOE. 2018a. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/. July 26, 2018.
DOE. 2018b. Table 3: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/docs/Revision_29A_Table3.pdf. July 26, 2018.
Donaldson K, Borm PJ. 1998. The quartz hazard: a variable entity. Ann Occup Hyg 42(5):287–294.9729916
Dong D, Xu G, Sun Y, . 1995. Lung cancer among workers exposed to silica dust in Chinese refractory plants. Scand J Work Environ Health 21 Suppl 2:69–72 8929695 (As cited in Erren et al. 2009a, 2009b; Kurihara and Wada 2004; Lacrasse et al. 2005)
Dosemeci M, Chen JQ, Hearl F, . 1993. Estimating historical exposure to silica among mine and pottery workers in the People’s Republic of China. Am J Ind Med 24(1):55–66.8394648 (As cited in Mannetje et al. 2002b)
Driscoll KE, Deyo LC, Carter JM, . 1997. Effects of particle exposure and particle-elicited inflammatory cells on mutation in rat alveolar epithelial cells. Carcinogenesis 18(2):423–430.9054638
Driscoll T, Nelson DI, Steenland K, . 2005. The global burden of non-malignant respiratory disease due to occupational airborne exposures. Am J Ind Med 48(6):432–445.16299701
Dufresne A, Begin R, Dion C, . 1998. Angular and fibrous particles in lung in relation to silica-induced diseases. Int Arch Occup Environ Health 71(4):263–269 9638483
Dutra FR. 1965. Diatomaceous earth pneumoconiosis. Arch Environ Health 11:613–619.4284802
Ebihara I, Kawami M. 1998. Lung cancer and immunopathologic diseases among copper miners in a small copper mine, stone masons and pneumoconiotic patients in Japan. In: Chiyotani K, Honda Y, Aizawa Y, eds. Advances in the prevention of occupational respiratory disease. Amsterdam: Elsevier Science, 225–236. (As cited in Kurihara and Wada 2004)
Ebihara I, Shinokawa E, Kawami M, . 1990. A retrospective cohort mortality study of pneumoconiotics. J Sci Labour 66(9):399–407. (As cited in Kurihara and Wada 2004; Lacrasse et al. 2005)
ECETOC. 2006. Synthetic amorphous silica. Brussels: European Centre for Ecotoxicology and Toxicology of Chemicals. JACC No. 51. http://www.ecetoc.org/wp-content/uploads/2014/08/JACC-051.pdf. March 14, 2019.
ECHA. 2019. Registration dossier: Silicon dioxide; synthetic amorphous silicon dioxide (nano). European Chemicals Agency. https://echa.europa.eu/de/registration-dossier/-/registered-dossier/15556/1. March 8, 2019.
Ehrlich RI, Myers JE, te Water Naude JM, . 2011. Lung function loss in relation to silica dust exposure in South African gold miners. Occup Environ Med 68(2):96–101. 10.1136/oem.2009.048827.20884796
Eisen EA, Smith TJ, Wegman DH, . 1984. Estimation of long term dust exposures in the Vermont granite sheds. Am Ind Hyg Assoc J 45(2):89–94. 10.1080/15298668491399424.6322564 (As cited in Mannetje et al. 2002b)
Eisen EA, Wegman DH, Louis TA, . 1995. Healthy worker effect in a longitudinal study of one-second forced expiratory volume (FEV1) and chronic exposure to granite dust. Int J Epidemiol 24(6):1154–1161.8824857
Elias Z, Poirot O, Daniere MC, . 2000. Cytotoxic and transforming effects of silica particles with different surface properties in Syrian hamster embryo (SHE) cells. Toxicol in Vitro 14(5):409–422.10963957
Elias Z, Poirot O, Fenoglio I, . 2006. Surface reactivity, cytotoxic, and morphological transforming effects of diatomaceous earth products in Syrian hamster embryo cells. Toxicol Sci 91(2):510–520. 10.1093/toxsci/kfj177.16571621
El-Safty IAM, Gadallah M, Shouman AE, . 2003. Subclinical nephrotoxicity caused by smoking and occupational silica exposure among Egyptian industrial workers. Arch Med Res 34(5):415–421. 10.1016/s0188-4409(03)00077-8.14602509
Englert H, Small-McMahon J, Davis K, . 2000. Male systemic sclerosis and occupational silica exposure-a population-based study. Aust N Z J Med 30(2):215–220.10833113
Environment Canada. 2013. Screening assessment for the challenge. Quartz chemical abstracts service registry number 14808-60-7 cristobalite chemical abstracts service registry number 14464-46-1. Environment Canada, Health Canada. https://www.ec.gc.ca/ese-ees/1EB4F4EF-88EE-4679-9A6C-008F0CBC191C/FSAR_B12%20-%2014464-46-1%20%26%2014808-60-7%20%28QC%29_EN.pdf. October 6, 2015.
EPA. 1974. Development of emission factors for fugitive dust sources. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA450374037. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000MC6B.txt. March 14, 2019.
EPA. 1991. R.E.D. facts. Silicon dioxide and silica gel. U.S. Environmental Protection Agency. 738F91107. http://www.epa.gov/pesticides/chem_search/reg_actions/reregistration/fs_G-74_1-Sep-91.pdf. October 6, 2015.
EPA. 1996. Ambient levels and noncancer health effects of inhaled crystalline and amorphous silica: Health issue assessment. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600R95115. http://ofmpub.epa.gov/eims/eimscomm.getfile?p_download_id=4608. October 6, 2015.
EPA. 2003. Method 200.5. Determination of trace elements in drinking water by axially viewed inductively coupled plasma-atomic emission spectrometry. U.S. Environmental Protection Agency. EPA600R06115. http://water.epa.gov/scitech/methods/cwa/upload/Determination-of-Trace-Elements-in-Drinking-Water-by-Axially-Viewed-Inductively-Coupled-Plasma-Atomic-Emission-Spectrometry.pdf. October 6, 2015.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001.
EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
EPA. 2011. Exposure factors handbook. U.S. Environmental Protection Agency. http://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=236252. September 22, 2015.
EPA. 2014. 2012 Chemical data reporting results: Silica, amorphous, fumed, cryst.-free. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/chemical-data-reporting-previously-collected-data. February 20, 2019.
EPA. 2016. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2016-03/documents/compiled_aegl_update_.pdf. September 8, 2017.
EPA. 2017. 2016 Chemical data reporting results: Silica compounds (7631-86-9, 14464-46-1, 14808-60-7, 15468-32-3, 60676-86-0, 61790-53-2, 63231-67-4, 68855-54-9, 69012-64-2, 91053-39-3, 112926-00-8). U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting. February 20, 2019.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. July 25, 2018.
EPA. 2018b. Tolerances and exemptions for pesticide chemical residues in food. Subpart D - exemptions from tolerances. Tolerance exemptions for minimal risk active and inert ingredients. Specific chemical substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.950(e). https://www.govinfo.gov/content/pkg/CFR-2018-title40-vol26/pdf/CFR-2018-title40-vol26-sec180-950.pdf. December 17, 2018.
Erdogdu G, Hasirci V. 1998. An overview of the role of mineral solubility in silicosis and asbestosis. Environ Res 78(1):38–42. 10.1006/enrs.1998.3842.9630443
Erren TC, Glende CB, Morfeld P, . 2009a. Is exposure to silica associated with lung cancer in the absence of silicosis? A meta-analytical approach to an important public health question. Int Arch Occup Environ Health 82(8):997–1004. 10.1007/s00420-008-0387-0.19066933
Erren TC, Glende CB, Morfeld P, . 2009b. Electronic supplemental materials. Is exposure to silica associated with lung cancer in the absence of silicosis? A meta-analytical approach to an important public health question. Int Arch Occup Environ Health 10.1007/s00420-008-0387-0.
Esswein EJ, Breitenstein M, Snawder J, . 2013. Occupational exposures to respirable crystalline silica during hydraulic fracturing. J Occup Environ Hyg 10(7):347–356. 10.1080/15459624.2013.788352.23679563
Fairfax R, Oberbeck B. 2008. OSHA compliance issues. Exposure to crystalline silica in a countertop manufacturing operation. J Occup Environ Hyg 5(8):D81–85. 10.1080/15459620802161934.18569511
Fanizza C, Ursini CL, Paba E, . 2007. Cytotoxicity and DNA-damage in human lung epithelial cells exposed to respirable alpha-quartz. Toxicol in Vitro 21(4):586–594. 10.1016/j.tiv.2006.12.002.17257809
FDA. 2013. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnnavigation.cfm?rpt=eafuslisting. January 8, 2014.
FDA. 2015a. Silica aerogel. Subpart B-multiple purpose GRAS food substances. Food and Drug Administration. Code of Federal Regulations. 21 CFR 182.1711. http://www.gpo.gov/fdsys/pkg/CFR-2015-title21-vol3/pdf/CFR-2015-title21-vol3-sec182-1711.pdf. September 23, 2015.
FDA. 2015b. Substances migrating to food from paper and paperboard products. Subpart A. Food and Drug Administration. Code of Federal Regulations 21 CFR 18290 http://www.gpo.gov/fdsys/pkg/CFR-2015-title21-vol3/pdf/CFR-2015-title21-vol3-sec182-90.pdf. September 23, 2015.
FDA. 2018a. Diatomaceous earth. Substances added to food. Washington, DC: U.S. Food and Drug Administration. https://www.accessdata.fda.gov/scripts/fdcc/?set=FoodSubstances&id=DIATOMACEOUSEARTH. December 16, 2018.
FDA. 2018b. Silicon dioxide. Substances added to food. Washington, DC: U.S. Food and Drug Administration. https://www.accessdata.fda.gov/scripts/fdcc/index.cfm?set=FoodSubstances&id=SILICONDIOXIDE. December 16, 2018.
Fenoglio I, Croce A, DiRenzo F, . 2000. Pure silica zeolites (porosils) as model solids for the evaluation of the physiochemical features determining silica toxicity to macrophages. Chem Res Toxicol 13:489–500 10858322
Fenwick S, Main J. 2000. Increased prevalence of renal disease in silica-exposed workers. Lancet 356(9233):913–914. 10.1016/s0140-6736(00)02686-6.11036901
Filios MS, Mazurek JM, Schleiff PL, . 2015. Surveillance for silicosis- Michigan and New Jersey 2003-2010. MMWR Morb Mortal Wkly Rep 62(54):81–85.26505318
Finckh A, Cooper GS, Chibnik LB, . 2006. Occupational silica and solvent exposures and risk of systemic lupus erythematosus in urban women. Arthritis Rheum 54(11):3648–3654. 10.1002/art.22210.17075811
Finkelstein MM. 1995. Radiographic abnormalities and the risk of lung cancer among workers exposed to silica dust in Ontario. Can Med Assoc J 152(1):37–43.7804920 (As cited in Erren et al. 2009a, 2009b; Kurihara and Wada 2004; Lacrasse et al. 2005)
Finkelstein MM. 1998. Radiographic silicosis and lung cancer risk among workers in Ontario. Am J Ind Med 34(3):244–251.9698993 (As cited in Erren et al. 2009a, 2009b; Pelucci et al. 2006)
Finkelstein MM. 2000. Silica, silicosis, and lung cancer: A risk assessment. Am J Ind Med 38(1):8–18.10861762
Finkelstein MM, Verma DK. 2005. Mortality among Ontario members of the International Union of Bricklayers and Allied Craftworkers. Am J Ind Med 47(1):4–9. 10.1002/ajim.20116.15597359 (As cited in Pelucci et al. 2006)
Finkelstein M, Kusiak R, Suranyi G. 1982. Mortality among miners receiving workmen’s compensation for silicosis in Ontario: 1940-1975. J Occup Med 24(9):663–667.6215474 (As cited in Poinen-Rughooputh et al. 2016)
Finkelstein M, Liss GM, Krammer F, . 1987. Mortality among workers receiving compensation awards for silicosis in Ontario 1940-85. Br J Ind Med 44(9):588–594.2959310 (As cited in Erren et al. 2009a, 2009b; Lacrasse et al. 2005)
Flanagan ME, Seixas N, Becker P, . 2006. Silica exposure on construction sites: results of an exposure monitoring data compilation project. J Occup Environ Hyg 3(3):144–152. 10.1080/15459620500526552.16464818
Florke OW, Graetsch HA, Brunk F, . 2008. Silica. In: Ullmann’s encyclopedia of industrial chemistry. John Wiley & Sons, Inc.
Forastiere F, Lagorio S, Michelozzi P, . 1986. Silica, silicosis and lung cancer among ceramic workers: A case-referent study. Am J Ind Med 10(4):363–370.3788981 (As cited in Erren et al. 2009a, 2009b; Kurihara and Wada 2004; Lacrasse et al. 2005)
Forastiere F, Lagorio S, Michelozzi P, . 1989. Mortality pattern of silicotic subjects in the Latium region, Italy. Br J Ind Med 46(12):877–880.2611162 (As cited in Erren et al. 2009a, 2009b)
Foreland S, Bye E, Bakke B, . 2008. Exposure to fibres, crystalline silica, silicon carbide and sulphur dioxide in the Norwegian silicon carbide industry. Ann Occup Hyg 52(5):317–336. 10.1093/annhyg/men029.18550624
Franklin BS, Mangan MS, Latz E. 2016. Crystal formation in inflammation. Annu Rev Immunol 34:173–202. 10.1146/annurev-immunol-041015-055539.26772211
Freeman CS, Grossman EA. 1995. Silica exposures in workplaces in the United States between 1980 and 1992. . Scand J Work Environ Health 21(Suppl 2):47–49.8929689
Freund A, Zuckerman N, Luo H, . 2014. Diesel and silica monitoring at two sites following hurricane sandy. J Occup Environ Hyg 11(9):D131–143. 10.1080/15459624.2014.904518.25046545
Fruijtier-Polloth C. 2012. The toxicological mode of action and safety of synthetic amorphous silica - a nanostructured material. Toxicol Abstr 294:61–79.
Fruijtier-Polloth C. 2016. The safety of nanostructured synthetic amorphous silica (SAS) as a food additive (E 551). Arch Toxicol 90:2885–2916.27699444
Fu H, Gu X, Jin X, . 1994. Lung cancer among tin miners in southeast China: Silica exposure, silicosis, and cigarette smoking. Am J Ind Med 26(3):373–381.7977411 (As cited in Lacrasse et al. 2005)
Fubini B, Bolis V, Cavenago A, . 1995. Physicochemical properties of crystalline silica dusts and their possible implication in various biological responses. Scand J Work Environ Health 21(Suppl 2):9–14.8929680
Fujimura N. 2000. Pathology and pathophysiology of pneumoconiosis. Curr Opin Pulm Med 6(2):140–144.10741774
Fulekar MH. 1999. Occupational exposure to dust in quartz manufacturing industry. Ann Occup Hyg 43(4):269–273.10432870
Fulekar MH, Khan MMA. 1995. Occupational exposure to dust in slate pencil manufacture. Ann Occup Hyg 39(1):107–114.7702243
Gamble JF. 2011. Crystalline silica and lung cancer: a critical review of the occupational epidemiology literature of exposure-response studies testing this hypothesis. Crit Rev Toxicol 41(5):404–465. 10.3109/10408444.2010.541223.21548755
Gamsky TE, McCurdy SA, Samuels SJ, . 1992. Reduced FVC among California grape workers. Am Rev Respir Dis 145(2):257–262.1736728
GBD. 2015. Global, regional, and national age-sex specific all-cause and cause-specific mortality of 240 causes of death, 1990-2013: A systematic analysis for the Global Burden of Disease Study 2013. Lancet (North American Edition) 385:117–171.
George S, Steinberg SM, Hodge V. 2000. The concentration, apparent molecular weight and chemical reactivity of silica from groundwater in southern Nevada. Chemosphere 40:57–63.10665445
Ghahramani N. 2010. Silica nephropathy. Int J Occup Environ Health 1(3):108–115.
Gibelin A, Maldini C, Mahr A. 2011. Epidemiology and etiology of Wegener granulomatosis, microscopic polyangiitis, Churg-Strauss syndrome and Goodpasture syndrome: Vasculitides with frequent lung involvement. Semin Respir Crit Care Med 32(3):264–273.21674413
Giles RD, Sturgill BC, Suratt PM, . 1978. Massive proteinuria and acute renal failure in a patient with acute silicoproteinosis. Am J Ind Med 64(2):336–342
+Gillette-Guyonnet S, Andrieu S, Nourhashemi F, . 2005. Cognitive impairment and composition of drinking water in women: findings of the EPIDOS Study. Am J Clin Nutr 81(4):897–902.15817869
Gold LS, Ward MH, Dosemeci M, . 2007. Systemic autoimmune disease mortality and occupational exposures. Arthritis Rheum 56(10):3189–3201. 10.1002/art.22880.17907164
Goldsmith JR, Goldsmith DF. 1993. Fiberglass or silica exposure and increased nephritis or ESRD (end-stage renal disease). Am J Ind Med 23(6):873–881.8392293
Goldsmith DF, Beaumont JJ, Morrin LA, . 1995. Respiratory cancer and other chronic disease mortality among silicotics in California. Am J Ind Med 28(4):459–467.8533788
Gomez-Puerta JA, Gedmintas L, Costenbader KH. 2013. The association between silica exposure and development of ANCA-associated vasculitis: Systematic review and meta-analysis. Autoimmun Rev 12(12):1129–1135. 10.1016/j.autrev.2013.06.016.23820041
Gonzalez Huergo D, Rojo Ortega D. 1991. [Experimental study of silica absorption through the digestive tract as a cause of extrapulmonary silicosis]. Rev Esp Enferm Dig 80(2):95–98. (Spanish)1665076
Graham WG, Costello J, Vacek PM. 2004. Vermont granite mortality study: An update with an emphasis on lung cancer. J Occup Environ Med 46(5):459–466.15167394 (As cited in Pelucci et al. 2006)
Greaves IA. 2000. Not-so-simple silicosis: a case for public health action. Am J Ind Med 37(3):245–251.10642413
Green FHY, Yoshida K, Fick G, . 1990. Characterization of airborne mineral dusts associated with farming activities in rural Alberta, Canada. Int Arch Occup Environ Health 62(6):423–430 2246059
Greenberg MI, Waksman J, Curtis J. 2007. Silicosis: a review. Dis Mon 53(8):394–416. 10.1016/j.disamonth.2007.09.020.17976433
Gregorini G, Ferioli A, Donato F, . 1993. Association between silica exposure and necrotizing crescentic glomerulonephritis with p-ANCA and anti-MPO antibodies: A hospital-based case-control study. Adv Exp Med Biol 336:435–440.8296651
+Groth DH, Moorman WJ, Lynch DW, . 1981. Chronic effects of inhaled amorphous silicas in animals. In: Dunnom DD, ed. Health effects of synthetic silica particulates. (ASTM STP 732). Philadelphia, PA: American Society for Testing and Materials, 118–143.
Guenel P, Hojberg G, Lynge E. 1989. Cancer incidence among Danish stone workers. Scand J Work Environ Health 15(4):265–270.2772581 (As cited in Kurihara and Wada 2004)
Guidi P, Nigro M, Bernardeschi M, . 2013. Genotoxicity of amorphous silica particles with different structure and dimension in human and murine cell lines. Mutagenesis 28(2):171–180. 10.1093/mutage/ges068.23325795
Guthrie GD, Jr. 1995. Mineralogical factors affect the biological activity of crystalline silica. Appl Occup Environ Hyg 10(12):1126–1131.
Hall RM, Achutan C, Sollberger R, . 2013. Exposure assessment for roofers exposed to silica during installation of roof tiles. J Occup Environ Hyg 10(1):D6–10. 10.1080/15459624.2012.739439.23186147
Hamilton RF, Jr., Thakur SA, Holian A. 2008. Silica binding and toxicity in alveolar macrophages. Free Radic Biol Med 44(7):1246–1258. 10.1016/j.freeradbiomed.2007.12.027.18226603
Harber P, Dahlgren J, Bunn W, . 1998. Radiographic and spirometric findings in diatomaceous earth workers. J Occup Environ Med 40(1):22–28.9467117
Hart GA, Hesterberg TW. 1998. In vitro toxicity of respirable-size particles of diatomaceous earth and crystalline silica compared with asbestos and titanium dioxide. J Occup Environ Med 40(1):29–42.9467118
Hauglustaine D, Van Damme B, Daenens P, . 1980. Silicon nephropathy: a possible occupational hazard. Nephron 26(5):219–224.6252491
Haynes WM, Lide DR, Bruno TJ, . 2014. In: CRC handbook of chemistry and physics. 95th ed. Boca Raton, FL: CRC Press, 4–88.
Hayumbu P, Robins TG, Key-Schwartz R. 2008. Cross-sectional silica exposure measurements at two Zambian copper mines of Nkana and Mufulira. Int J Environ Res Public Health 5(2):86–90.18678921
Hedlund U, Jonsson H, Eriksson K, . 2008. Exposure-response of silicosis mortality in Swedish iron ore miners. Ann Occup Hyg 52(1):3–7. 10.1093/annhyg/mem057.18063590
Hemenway DR, Absher MP, Trombley L, . 1990. Comparative clearance of quartz and cristobalite from the lung. Am Ind Hyg Assoc J 51(7):363–369. 10.1080/15298669091369790.2166428
Hemlick CG, Felson DT, Lawrence RC, . 2008. Estimates of the prevalence of arthritis and other rheumatic conditions in the United States. Arthritis Rheum 58(1):15–25.18163481
Hertzberg VS, Rosenman KD, Reilly MJ, . 2002. Effect of occupational silica exposure on pulmonary function. Chest 122(2):721–728.12171857
Hessel PA, Gamble JF, Gee JB, . 2000. Silica, silicosis, and lung cancer: a response to a recent working group report. J Occup Environ Med 42(7):704–720.10914339
Hesterberg TW, Barrett JC. 1984. Dependence of asbestos- and mineral dust-induced transformation of mammalian cells in culture on fiber dimension. Cancer Res 44(5):2170–2180.6324999
Hewson GS. 1993. Estimates of silica exposure among metalliferous miners in Western Australia (1925-1993). Perth: Department of Minerals and Energy Western Australia. (As cited in Mannetje et al. 2002b)
Hinchcliff M, Varga J. 2008. Systemic sclerosis/scleroderma: A treatable multisystem disease. Am Fam Physician 78(8):961–968.18953973
Hnizdo E. 1990. Combined effect of silica dust and tobacco smoking on mortality from chronic obstructive lung disease in gold miners. Br J Ind Med 47(10):656–664.2171628
Hnizdo E, Sluis-Cremer GK. 1991. Silica exposure, silicosis, and lung cancer: A mortality study of South African gold miners. Br J Ind Med 48(1):53–60.1847069 (As cited in Finkelstein 2000; Mannetje et al. 2002b)
Hnizdo E, Sluis-Cremer GK. 1993. Risk of silicosis in a cohort of white South African gold miners. Am J Ind Med 24(4):447–457.8250063
Hnizdo E, Murray J. 1998. Risk of pulmonary tuberculosis relative to silicosis and exposure to silica dust in South African gold miners. Occup Environ Med 55(7):496–502.9816385 (As cited in Mannetje et al. 2002b)
Hnizdo E, Vallyathan V. 2003. Chronic obstructive pulmonary disease due to occupational exposure to silica dust: a review of epidemiological and pathological evidence. Occup Environ Med 60(4):237–243.12660371
Hnizdo E, Murray J, Klempman S. 1997. Lung cancer in relation to exposure to silica dust, silicosis and uranium production in South African gold miners. Thorax 52(3):271–275.9093345 (As cited in Erren et al. 2009a, 2009b; Finkelstein 2000; Kurihara and Wada 2004; Mannetje et al. 2002b; Pelucci et al. 2006; Steenland et al. 2001a)
Hnizdo E, Murray J, Sluis-Cremer GK, . 1993. Correlation between radiological and pathological diagnosis of silicosis: an autopsy population based study. Am J Ind Med 24(4):427–445.8250062
Hogan SL, Satterly KK, Dooley MA, . 2001. Silica exposure in anti-neutrophil cytoplasmic autoantibody-associated glomerulonephritis and lupus nephritis. J Am Soc Nephrol 12(1):134–142.11134259
Hogan SL, Cooper GS, Savitz DA, . 2007. Association of silica exposure with anti-neutrophil cytoplasmic autoantibody small-vessel vasculitis: A population-based, case-control study. Clin J Am Soc Nephrol 2(2):290–299. 10.2215/cjn.03501006.17699427
Holloway MD, Rudd O. 2014. Fracking operations. In: Kirk-Othmer encyclopedia of chemical technology. John Wiley & Sons. 10.1002/0471238961.fracholl.a01.
Hornung V, Bauernfeind F, Halle A, . 2008. Silica crystals and aluminum salts activate the NALP3 inflammasome through phagosomal destabilization. Nat Immunol 9(8):847–856 10.1038/ni.1631.18604214
Horwell CJ, Le Blond JS, Michnowicz SAK, . 2010. Cristobalite in a rhyolitic lava dome: evolution of ash hazard. Bull Volcanol 72:249–253. 10.1007/s00445-009-0327-1.
Horwell CJ, Williamson BJ, Donaldson K, . 2012. The structure of volcanic cristobalite in relation to its toxicity; relevance for the variable crystalline silica hazard. Part Fibre Toxicol 9:44. 10.1186/1743-8977-9-44.23164071
Horwell CJ, Baxter PJ, Hillman SE, . 2013. Physicochemical and toxicological profiling of ash from the 2010 and 2011 eruptions of Eyjafjallajokull and Grimsvotn volcanoes, Iceland using a rapid respiratory hazard assessment protocol. Environ Res 127:63–73. 10.1016/j.envres.2013.08.011.24267795
Hotz P, Gonzalez-Lorenzo J, Siles E, . 1995. Subclinical signs of kidney dysfunction following short exposure to silica in the absence of silicosis. Nephron 70(4):438–442.7477649
HSDB. 2009. Amorphous silica. CASRN: No CAS RN. Hazardous Substances Data Bank. National Library of Medicine. https://toxnet.nlm.nih.gov/newtoxnet/hsdb.htm. September 23, 2015.
HSDB. 2012. Crystalline silica. CASRN: No CAS RN. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. September 23, 2015.
Huaux F. 2007. New developments in the understanding of immunology in silicosis. Curr Opin Allergy Clin Immunol 7(2):168–173. 10.1097/ACI.0b013e32802bf8a5.17351471
Hughes JM, Weill H, Checkoway H, . 1998. Radiographic evidence of silicosis risk in the diatomaceous earth industry. Am J Respir Crit Care Med 158(3):807–814. 10.1164/ajrccm.158.3.9709103.9731009
Hughes JM, Weill H, Rando RJ, . 2001. Cohort mortality study of North American industrial sand workers. II. Case-referent analysis of lung cancer and silicosis deaths. Ann Occup Hyg 45(3):201–207.11295143
Iannello S, Camuto M, Cantarella S, . 2002. Rheumatoid syndrome associated with lung interstitial disorder in a dental technician exposed to ceramic silica dust. A case report and critical literature review. Clin Rheumatol 21(1):76–81.11954893
IARC. 1987. Silica and some silicates. In: IARC monographs of the evaluation of the carcinogenic risk of chemicals to humans. Vol. 42. Lyon, France: International Agency for Research on Cancer.
IARC. 1997. Silica. IARC Monographs on the evaluation of carcinogenic risks to humans. Volume 68. Silica, some silicates, coal dust and para-aramid fibrils. Lyon, France: International Agency for Research on Cancer. https://monographs.iarc.fr/wp-content/uploads/2018/06/mono68-6.pdf. December 12, 2018.
IARC. 2012. Silica dust, crystalline, in the form of quartz or cristobalite. IARC Monographs on the evaluation of carcinogenic risks to humans. Volume 100C. Arsenic, metals, fibres and dusts. Lyon, France: International Agency for Research on Cancer. https://monographs.iarc.fr/wp-content/uploads/2018/06/mono100C-14.pdf. December 12, 2018.
Ibrahim KS, Ahmed SB, Amer NM. 2011. Study of kidney dysfunction in non-silicotic Egyptian workers. Int J Hyg Environ Health 214(1):53–58. 10.1016/j.ijheh.2010.08.012.20851677
ICRP. 1994. Annex D. Deposition of inhaled particles, Annex E. Clearance of particles from the respiratory tract. In: Human respiratory tract model for radiological protection. ICRP Publication 66. Tarrytown, NY: International Commission on Radiological Protection. Elsevier Science, Inc., 231–413.
Infante-Rivard C, Armstrong B, Petitclerc M, . 1989. Lung cancer mortality and silicosis in Quebec, 1938-85. Lancet 2(8678–8679):1504–1507.2574779 (As cited in Erren et al. 2009a, 2009b; Kurihara and Wada 2004; Lacrasse et al. 2005)
Iocopini GA, Brantley SL, Heaney PJ. 2005. Kinetics of silica oligomerization and nanocolloid formation as a function of pH and ionic strength at 25 degrees C. Geochim Cosmochim Acta 69(2):293–303.
IRIS. 2018. List of final IRIS assessments. Washington, DC: Integrated Risk Information System. U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris_drafts/simple_list.cfm. July 25, 2018.
Jacobsen NR, Saber AT, White P, . 2007. Increased mutant frequency by carbon black, but not quartz, in the lacZ and cII transgenes of mutaTM mouse lung epithelial cells. Environ Mol Mutagen 48(6):451–461. 10.1002/em.20300.17584883
+Jacqmin-Gadda H, Commenges D, Letenneur L, . 1996. Silica and aluminum in drinking water and cognitive impairment in the elderly. Epidemiology 7(3):281–285.8728442
Jensen M, Keding R, Hoche T, . 2009. Biologically formed mesoporous amorphous silica. J Am Chem Soc 131(7):2717–2721. 10.1021/ja808847y.19199622
Jiang PR, Cao Z, Qiu ZL, . 2015. Plasma levels of TNF-alpha and MMP-9 in patients with silicosis. Eur Rev Med Pharmacol Sci 19:1716–1720.26004615
+Johnston CJ, Driscoll KE, Finkelstein JN, . 2000. Pulmonary chemokine and mutagenic responses in rats after subchronic inhalation of amorphous and crystalline silica. Toxicol Sci 56(2):405–413.10911000
Jorna T, Borm PJA, Koiter KD, . 1994. Respiratory effects and serum type III procollagen in potato sorters exposed to diatomaceous earth. Int Arch Occup Environ Health 66(4):217–222.7843830
Joy GJ. 2012. Evaluation of the approach to respirable quartz exposure control in U.S. coal mines. J Occup Environ Hyg 9(2):65–68. 10.1080/15459624.2011.639232.22181563
Kada T, Hirano K, Shirasu Y. 1980. Screening of environmental chemical mutagens by the Rec-assay system with Bacillus subtilis. Chem Mutagen 6:149–173.
Kambouchner M, Bernaudin JF. 2015. The pathologist’s view of silicosis in 1930 and in 2015. The Johannesburg Conference legacy. Am J Ind Med 58 Suppl 1:S48–58. 10.1002/ajim.22506.26509753
Kanematsu N, Hara M, Kada T. 1980. Rec assay and mutagenicity studies on metal compounds. Mutat Res 77:109–116.6769036
Katsnelson BA, Konysheva LK, Privalova LI, . 1992. Development of a multicompartmental model of the kinetics of quartz dust in the pulmonary region of the lung during chronic inhalation exposure of rats. Br J Ind Med 49(3):172–181 1554613
Kauppinen T, Heikkila P, Partanen T, . 2003. Mortality and cancer incidence of workers in Finnish road paving companies. Am J Ind Med 43:49–57.12494421 (As cited in Pelucci et al. 2006)
Kawasaki H. 2015. A mechanistic review of silica-induced inhalation toxicity. Inhal Toxicol 27(8):363–377. 10.3109/08958378.2015.1066905.26194035
Kelly DP, Lee KP. 1990. Pulmonary response to Ludox colloidal silica inhalation exposure in rats. Toxicologist 90:202.
Keshava C, Keshava N, Zhou G, . 1999. Genomic instability in silica- and cadmium chloride-transformed BALB/c-3T3 and tumor cell lines by random amplified polymorphic DNA analysis. Mutat Res 425(1):117–123.10082922
Klockars M, Koskela RS, Jarvinen E, . 1987. Silica exposure and rheumatoid arthritis: A follow up study of granite workers 1940-81. Br Med J 294(6578):997–1000.2823951
Knaapen AM, Albrecht C, Becker A, . 2002. DNA damage in lung epithelial cells isolated from rats exposed to quartz: Role of surface reactivity and neutrophilic inflammation. Carcinogenesis 23(7):1111–1120.12117767
Koskela RS. 1995. Association of silica dust exposure with lung cancer and other diseases. Acta Universitatis Tamperensis, Ser A Vol 460 Academic dissertation, University of Tampere, Finland (As cited in Mannetje et al. 2002b)
Koskela RS, Klockars M, Jarvinen E, . 1987a. Cancer mortality of granite workers. Scand J Work Environ Health 13(1):26–31.3033818 (As cited in Mannetje et al. 2002b)
Koskela RS, Klockars M, Jarvinen E, . 1987b. Mortality and disability among granite workers. Scandinavian Journal of Work, Environment & Health 13(1):18–25.
Koskela RS, Klockars M, Laurent H, . 1994. Silica dust exposure and lung cancer. Scand J Work Environ Health 20(6):407–416.7701286
Kramer MR, Blanc PD, Fireman E, . 2012. Artificial stone silicosis: Disease resurgence among artificial stone workers. Chest 142(2):419–424. 10.1378/chest.11-1321.22383661
Kreiss K, Zhen B. 1996. Risk of silicosis in a Colorado mining community. Am J Ind Med 30(5):529–539. 10.1002/(sici)1097-0274(199611)30:5<529::aid-ajim2>3.0.co;2-o.8909602
Kreyling WG. 1990. Interspecies comparison of lung clearance of “insoluble” particles. J Aerosol Med 3(Supplement 1):S-93 S-110.
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kullman GJ, Greife AL, Costello J, . 1995. Occupational exposures to fibers and quartz at 19 crushed stone mining and milling operations. Am J Ind Med 27(5):641–660.7611303
Kurihara N, Wada O. 2004. Silicosis and smoking strongly increase lung cancer risk in silica-exposed workers. Ind Health 42(3):303–314.15295901
Lacasse Y, Martin S, Gagne D, . 2009. Dose-response meta-analysis of silica and lung cancer. Cancer Causes Control 20(6):925–933. 10.1007/s10552-009-9296-0.19184475
Lacey JV, Laing TJ, Gillespie BW, . 1997. Mr. Lacey, et al reply. [Reply to “Epidemiology of scleroderma among women: assessment of risk from exposure to silicone and silica”]. J Rheumatol 24(9):1853–1855.9292822
Lagorio S, Forastiere F, Michelozzi P, . 1990. A case-referent study on lung cancer mortality among ceramic workers. IARC Sci Publ (97):21–28 (As cited in Erren et al. 2009a, 2009b)
Lane SE, Watts RA, Bentham G, . 2003. Are environmental factors important in primary systemic vasculitis? Arthritis Rheum 48(3):8114–8823.
Large DJ, Kelly S, Spiro B, . 2009. Silica-volatile interaction and the geological cause of the Xuan Wei lung cancer epidemic. Environ Sci Technol 43(23):9016–9021. 10.1021/es902033j.19943682
Latz E. 2010. The inflammasomes: mechanisms of activation and function. Curr Opin Immunol 22(1):28–33. 10.1016/j.coi.2009.12.004.20060699
Lawson RJ, Schenker MB, McCurdy SA, . 1995. Exposure to amorphous silica fibers and other particulate matter during rice farming operations. Appl Occup Environ Hyg 10(8):677–684.
Le Blond JS, Horwell CJ, Williamson BJ, . 2010. Generation of crystalline silica from sugarcane burning. J Environ Monit 12(7):1459–1470. 10.1039/c0em00020e.20520870
Lee K. 2009. OSHA compliance issues benzene and crystalline silica exposures in a grey iron foundry. J Occup Environ Hyg 6(5):D15–17. 10.1080/15459620902754380.19205997
+Lee KP, Kelly DP. 1992. The pulmonary response and clearance of Ludox colloidal silica after a 4-week inhalation exposure in rats. Fundam Appl Toxicol 19(3):399–410.1334015
Lee S, Hayashi H, Maeda M, . 2012. Environmental factors producing autoimmune dysregulation--chronic activation of T cells caused by silica exposure. Immunobiology 217(7):743–748. 10.1016/j.imbio.2011.12.009.22226303
Lee S, Matsuzaki H, Kumagai-Takei N, . 2014. Silica exposure and altered regulation of autoimmunity. Environ Health Prev Med 19(5):322–329. 10.1007/s12199-014-0403-9.25135741
Lee S, Hayashi H, Mastuzaki H, . 2017. Silicosis and autoimmunity. Curr Opin Allergy Clin Immunol 17(2):78–84. 10.1097/aci.0000000000000350.28177948
Legge RT, Rosencrantz E. 1932. Observations and studies on silicosis by diatomaceous silica. Arch Environ Health 1:125–128.
Leung CC, Yu IT, Chen W. 2012. Silicosis. Lancet 379(9830):2008–2018. 10.1016/s0140-6736(12)60235-9.22534002
+Lewinson J, Mayr W, Wagner H. 1994. Characterization and toxicological behavior of synthetic amorphous hydrophobic silica. Regul Toxicol Pharmacol 20(1):37–57. 10.1006/rtph.1994.1035.7838991
Li H, Haberzettl P, Albrecht C, . 2007. Inhibition of the mitochondrial respiratory chain function abrogates quartz induced DNA damage in lung epithelial cells. Mutat Res 617(1–2):46–57. 10.1016/j.mrfmmm.2006.12.001.17239409
Lickiss PD. 2006. Silicon: Inorganic chemistry. In: Encyclopedia of inorganic chemistry. John Wiley & Sons, Ltd. 10.1002/0470862106.ia219. September 22, 2015.
Linch KD, Miller WE, Althouse RB, . 1998. Surveillance of respirable crystalline silica dust using OSHA compliance data (1979-1995). Am J Ind Med 34(6):547–558.9816412
Lippmann M, Timbrell V. 1990. Particle loading in the human lung—human experience and implications for exposure limits. J Aerosol Med 3:155–168
Liu S, Liu N, Li J. 1996a. Silicosis caused by rice husk ashes. J Occup Health 38(2):57–62.
Liu X, Keane MJ, Zhong BZ, . 1996b. Micronucleus formation in V79 cells treated with respirable silica dispersed in medium and in simulated pulmonary surfactant. Mutat Res 2(3):89–94.
Liu B, Guan R, Zhou P, . 2000. A distinct mutational spectrum of p53 and K-ras genes in lung cancer of workers with silicosis. J Environ Pathol Toxicol Oncol 19(1–2):1–7.10905501
Liu Y, Steenland K, Rong Y, . 2013. Exposure-response analysis and risk assessment for lung cancer in relationship to silica exposure: a 44-year cohort study of 34,018 workers. Am J Epidemiol 178(9):1424–1433. 10.1093/aje/kwt139.24043436
Liu H, Patel DJ, Welch AM, . 2016. Association between occupational exposures and sarcoidosis. Chest Surg Clin N Am 150(2):289–298.
Loosereewanich P, Ritchie AC, Armstrong B, . 1995. Pulmonary dust retention in silicotics with and without lung cancer. Appl Occup Environ Hyg 10(12):1104–1106.
Love RG, Waclawski ER, Maclaren WM, . 1999. Risks of respiratory disease in the heavy clay industry. Occup Environ Med 56(2):124–133.10448318
Madl AK, Donovan EP, Gaffney SH, . 2008. State-of-the-science review of the occupational health hazards of crystalline silica in abrasive blasting operations and related requirements for respiratory protection. J Toxicol Environ Health B Crit Rev 11(7):548–608. 10.1080/10937400801909135.18584454
Maeda M, Nishimura Y, Kumagai N, . 2010. Dysregulation of the immune system caused by silica and asbestos. J Immunotoxicol 7(4):268–278. 10.3109/1547691x.2010.512579.20849352
Maitre A, Hours M, Bonneterre V, . 2004. Systemic sclerosis and occupational risk factors: Role of solvents and cleaning products. J Rheumatol 31:2395–2401.15570640
Makol A, Reilly MJ, Rosenman KD. 2011. Prevalence of connective tissue disease in silicosis (1985-2006)-a report from the state of Michigan surveillance system for silicosis. Am J Ind Med 54(4):255–262. 10.1002/ajim.20917.20957678
Malmberg P, Hedenstrom H, Sundblad BM. 1993. Changes in lung function of granite crushers exposed to moderately high silica concentrations: A 12 year follow up. Br J Ind Med 50(8):726–731.8398859
Mancuso JD, McCoy J, Pelka B, . 2008. The challenge of controlling lead and silica exposures from firing ranges in a special operations force. Mil Med 173(2):182–186.18333495
Mannetje A, Steenland K, Attfield M, . 2002a. Exposure-response analysis and risk assessment for silica and silicosis mortality in a pooled analysis of six cohorts. Occup Environ Med 59(11):723–728.12409529
Mannetje A, Steenland K, Checkoway H, . 2002b. Development of quantitative exposure data for a pooled exposure-response analysis of 10 silica cohorts. Am J Ind Med 42(2):73–86. 10.1002/ajim.10097.12125083
Manson JJ, Rahman A. 2006. Systemic lupus erythematosus. Orphanet J Rare Dis 1:6. 10.1186/1750-1172-1-6.16722594
Mao Y, Daniel LN, Whittaker N, . 1994. DNA binding to crystalline silica characterized by Fourier-transform infrared spectroscopy. Environ Health Perspect 102 Suppl 10:165–171.
Marie I, Gehanno JF, Bubenheim M, . 2014. Prospective study to evaluate the association between systemic sclerosis and occupational exposure and review of the literature. Autoimmun Rev 13(2):151–156. 10.1016/j.autrev.2013.10.002.24129037
Marinaccio A, Scarselli A, Gorini G, . 2006. Retrospective mortality cohort study of Italian workers compensated for silicosis. Occup Environ Med 63(11):762–765. 10.1136/oem.2006.027854.16847031
Martin JC, Imbernon E, Goldberg M, . 2000. Occupational risk factors for lung cancer in the French electricity and gas industry: A case-control survey nested in a cohort of active employees. Am J Epidemiol 151(9):902–912.10791563 (As cited in Kurihara and Wada 2004; Pelucci et al. 2006)
Mastrangelo G, Zambon P, Simonato L, . 1988. A case-referent study investigating the relationship between exposure to silica dust and lung cancer. Int Arch Occup Environ Health 60(4):299–302.2836314 (As cited in Erren et al. 2009a, 2009b; Kurihara and Wada 2004; Lacrasse et al. 2005)
Mauderly JL, Cheng YS, Snipes MB. 1990. Particle overload in toxicology studies: Friend or foe? J Aerosol Med 3(Suppl 1):S169–S187
Maxim DL, Venturin D, Allshouse JN. 1999. Respirable crystalline silica exposure associated with the installation and removal of RCF and conventional silica-containing refractories in industrial furnaces. Regul Toxicol Pharmacol 29(1):44–63. 10.1006/rtph.1998.1268.10051418
Mazurek JM, Attfield MD. 2008. Silicosis mortality among young adults in the United States, 1968-2004. Am J Ind Med 51(8):568–578. 10.1002/ajim.20597.18521821
McClellan RO. 1990. Particle overload in the lung: Approaches to improving our knowledge. J Aerosol Med 3:197–207.
McCormic ZD, Khuder SS, Aryal BK, . 2010. Occupational silica exposure as a risk factor for scleroderma: A meta-analysis. Int Arch Occup Environ Health 83(7):763–769. 10.1007/s00420-009-0505-7.20047060
McDonald JC, Cherry N, McNamee R, . 1995. Preliminary analysis of proportional mortality in a cohort of British pottery workers exposed to crystalline silica. Scand J Work Environ Health 21 Suppl 2:63–65.8929693
McDonald AD, McDonald JC, Rando RJ, . 2001. Cohort mortality study of North American industrial sand workers. I. Mortality from lung cancer, silicosis and other causes. Ann Occup Hyg 45(3):193–199.11295142
McDonald JC, McDonald AD, Hughes JM, . 2005. Mortality from lung and kidney disease in a cohort of North American industrial sand workers: An update. Ann Occup Hyg 49(5):367–373. 10.1093/annhyg/mei001.15728107
McLaughlin JK, Chow WH, Levy LS. 1997. Amorphous silica: a review of health effects from inhalation exposure with particular reference to cancer. J Toxicol Environ Health 50(6):553–566. 10.1080/15287399709532054.15279029
McLaughlin JK, Chen JQ, Dosemeci M, . 1992. A nested case-control study of lung cancer among silica exposed workers in China. Br J Ind Med 49(3):167–171.1313281 (As cited in Kurihara and Wada 2004; Mannetje et al. 2002b)
Meeker JD, Susi P, Pellegrino A. 2005. Exposure to silica and metals among painters using specular hematite abrasive. J Occup Environ Hyg 2(8):D60–64.16080258
Mehlhorn J, Enderlein G, Conrad K, . 1999. [Analysis for the association between progressive systemic scleroderma, exposure to quartz dust, and silicosis in East Germany uranium mining]. Zbl Arbeitsmed 49:134–147. (As cited in McCormic et al. 2010 - German)
Mehnert WH, Staneczek W, Mohner M, . 1990. A mortality study of a cohort of slate quarry workers in the German Democratic Republic. IARC Sci Publ 97:55–64. (As cited in Erren et al. 2009a, 2009b; Kurihara and Wada 2004; Lacrasse et al. 2005)
Meijer E, Kromhout H, Heederik D. 2001. Respiratory effects of exposure to low levels of concrete dust containing crystalline silica. Am J Ind Med 40(2):133–140.11494340
Meijers JM, Swaen GM, Slangen JJ. 1996. Mortality and lung cancer in ceramic workers in The Netherlands: Preliminary results. Am J Ind Med 30(1):26–30. 10.1002/(sici)1097-0274(199607)30:1<26::aid-ajim4>3.0.co;2-q.8837678 (As cited in Erren et al. 2009a, 2009b; Kurihara and Wada 2004; Lacrasse et al. 2005)
Menvielle G, Luce D, Fevotte J, . 2003. Occupational exposures and lung cancer in New Caledonia. Occup Environ Med 60(8):584–589.12883019 (As cited in Pelucci et al. 2006)
Merget R, Bauer T, Kupper HU, . 2002. Health hazards due to the inhalation of amorphous silica. Arch Toxicol 75(11–12):625–634.11876495
Merlo F, Costantini M, Reggiardo G, . 1991. Lung cancer risk among refractory brick workers exposed to crystalline silica: A retrospective cohort study. Epidemiology 2(4):299–305.1655067 (As cited in Kurihara and Wada 2004)
Merlo F, Fontana L, Reggiardo G, . 1995. Mortality among silicotics in Genoa, Italy, from 1961 to 1987. Scand J Work Environ Health 21 Suppl 2:77–80.8929697 (As cited in Lacrasse et al. 2005)
Merlo DF, Garattini S, Gelatti U, . 2004. A mortality cohort study among workers in a graphite electrode production plant in Italy. Occup Environ Med 61(2):e9.14739393 (As cited in Pelucci et al. 2006)
Millerick-May ML, Schrauben S, Reilly MJ, . 2015. Silicosis and chronic renal disease. Am J Ind Med 58:730–736. 10.1002/ajim.22465.25940153
MMWR. 1989. Exposure trends in silica flour plants--United States, 1975-1986. MMWR Morb Mortal Wkly Rep 38(21):380–383.2541329
Mohner M, Kersten N, Gellissen J. 2013a. Chronic obstructive pulmonary disease and longitudinal changes in pulmonary function due to occupational exposure to respirable quartz. Occup Environ Med 70(1):9–14. 10.1136/oemed-2012-100775.23000825
Mohner M, Kersten N, Gellissen J. 2013b. Re: Clinically significant lung function impairment due to current levels of respirable quartz? (Authors’ response). Occup Environ Med 70(12):893–894. 10.1136/oemed-2013-101808.
Mohner M, Pohrt A, Gellissen J. 2017. Occupational exposure to respirable crystalline silica and chronic non-malignant renal disease: systematic review and meta-analysis. Int Arch Occup Environ Health 90(7):555–574. 10.1007/s00420-017-1219-x.28409224
Molocznik A. 2002. Qualitative and quantitative analysis of agricultural dust in working environment. Ann Agric Environ Med 9(1):71–78.12088401
Moore M. 1999. Crystalline silica: Occurrence and use. Indoor Built Environ 8:82–88.
Morfeld P, Mundt KA, Taeger D, . 2013. Threshold value estimation for respirable quartz dust exposure and silicosis incidence among workers in the German porcelain industry. J Occup Environ Med 55(9):1027–1034. 10.1097/JOM.0b013e318297327a.23969500
Morfeld P, Taeger D, Mitura H, . 2014. Cross-sectional study on respiratory morbidity in workers after exposure to synthetic amorphous silica at five German production plants: exposure assessment and exposure estimates. J Occup Environ Med 56(1):72–78. 10.1097/jom.0000000000000055.24351895
Morita T, Asano N, Awogi T, . 1997. Evaluation of the rodent micronucleus assay in the screening of IARC carcinogens (groups 1, 2A and 2B) the summary report of the 6th collaborative study by CSGMT/JEMS MMS. [published erratum appears in Mutat Res 391(3):259–267]. Mutat Res 389(1):3–122.9062586
Morrow PE. 1992. Dust overloading of the lungs: Update and appraisal. Toxicol Appl Pharmacol 113:1–12 1553742
Moshammer H, Neuberger M. 2004. Lung cancer and dust exposure: Results of a prospective cohort study following 3260 workers for 50 years. Occup Environ Med 61(2):157–162.14739382 (As cited in Pelucci et al. 2006)
Mossman BT, Churg A. 1998. Mechanisms in the pathogenesis of asbestosis and silicosis. Am J Respir Crit Care Med 157(5 Pt 1):1666–1680. 10.1164/ajrccm.157.5.9707141.9603153
Mossman BT, Glenn RE. 2013. Bioreactivity of the crystalline silica polymorphs, quartz and cristobalite, and implications for occupational exposure limits (OELs). Crit Rev Toxicol 43(8):632–660. 10.3109/10408444.2013.818617.23863112
Motley HL. 1960. Pulmonary function studies in diatomaceous earth workers. 2. A cross section survey of 98 workers on the job. Ind Med Surg 29:370–378.14424659
Motley HL, Smart RH, Valero A. 1956. Pulmonary function studies in diatomaceous earth workers. I. Ventilatory and blood gas exchange disturbances. AMA Arch Ind Health 13(3):265–274.13291906
Moulin JJ, Clavel T, Roy D, . 2000. Risk of lung cancer in workers producing stainless steel and metallic alloys. Int Arch Occup Environ Health 73(3):171–180.10787132 (As cited in Pelucci et al. 2006)
MPCA. 2015a. Shakopee Sand (previously Great Plains Sand) ambient air monitoring Jordan, Minnesota July 2012 – June 2015. Saint Paul, MN: Minnesota Pollution Control Agency. G-70-03. https://www.pca.state.mn.us/sites/default/files/g-70-03.pdf. January 18, 2017.
MPCA. 2015b. Titan Lansing Transload ambient air monitoring data report North Branch, Minnesota November 2012 – September 2015. Saint Paul, MN: Minnesota Pollution Control Agency. G-13-03. https://www.pca.state.mn.us/sites/default/files/g-13-03.pdf. January 17, 2017.
MPCA. 2015c. Winona - Community ambient air monitoring Winona, Minnesota January 2014 – December 2014. Saint Paul, MN: Minnesota Pollution Control Agency. G-85-03. https://www.pca.state.mn.us/sites/default/files/g-85-03.pdf. January 17, 2017.
Msiska Z, Pacurari M, Mishra A, . 2010. DNA double-strand breaks by asbestos, silica, and titanium dioxide: Possible biomarker of carcinogenic potential? Am J Respir Cell Mol Biol 43(2):210–219. 10.1165/rcmb.2009-0062OC.19783790
Muir DC, Shannon HS, Julian JA, . 1989a. Silica exposure and silicosis among Ontario hardrock miners: I. Methodology. Am J Ind Med 16(1):5–11.2750750
Muir DC, Julian JA, Shannon HS, . 1989b. Silica exposure and silicosis among Ontario hardrock miners: III. Analysis and risk estimates. Am J Ind Med 16(1):29–43.2750748
Mukhopadhyay K, Ramalingam A, Ramani R, . 2011. Exposure to respirable particulates and silica in and around the stone crushing units in central India. Ind Health 49(2):221–227.21173527
Mundt KA, Birk T, Parsons W, . 2011. Respirable crystalline silica exposure-response evaluation of silicosis morbidity and lung cancer mortality in the German porcelain industry cohort. J Occup Environ Med 53(3):282–289. 10.1097/JOM.0b013e31820c2bff.21346639
Murashov V, Harper M, Demchuk E. 2006. Impact of silanol surface density on the toxicity of silica aerosols measured by erythrocyte haemolysis. J Occup Environ Hyg 3(12):718–723.17133693
Nagalakshmi R, Nath J, Ong T, . 1995. Silica-induced micronuclei and chromosomal aberrations in Chinese hamster lung (V79) and human lung (Hel 299) cells. Mutat Res 335(1):27–33.7616986
Naghizadeh A, Mahvi AH, Jabbari H, . 2011. Exposure assessment to dust and free silica for workers of Sangan iron ore mine in Khaf, Iran. Bull Environ Contam Toxicol 87(5):531–538. 10.1007/s00128-011-0375-z.21805121
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press. 15–35.
Neuberger M, Westphal G, Bauer P. 1988. Long-term effect of occupational dust exposure. Sangyo Igaku 30(5):362–370.3204694 (As cited in Poinen-Rughooputh et al. 2016)
Neuberger M, Kundi M, Westphal G, . 1986. The Viennese dusty worker study. In: Goldsmith DF, Winn DM, Shy CM, eds. Silica, silicosis, and cancer: Controversy in occupational medicine. New York: Praeger, 415–422. (As cited in Erren et al. 2009, 2009b)
+Newberne PM, Wilson RB. 1970. Renal damage associated with silicon compounds in dogs. Proc Nat Acad Sci U S A 65(4):872–875.
Ng T, Chan S. 1994. Quantitative relations between silica exposure and development of radiological small opacities in granite workers. Ann Occup Hyg 38(inhaled particles VII):857–863.
Ng TP, Chan SL, Lee J. 1990. Mortality of a cohort of men in a silicosis register: Further evidence of an association with lung cancer. Am J Ind Med 17(2):163–171.2301408
Ng TP, Lee HS, Phoon WH. 1993. Further evidence of human silica nephrotoxicity in occupationally exposed workers. Br J Ind Med 50(10):907–912.8217850
Ng TP, Ng YL, Lee HS, . 1992. A study of silica nephrotoxicity in exposed silicotic and non-silicotic workers. Br J Ind Med 49(1):35–37.1370761
Nieuwenhuijsen MJ, Noderer KS, Schenker MB, . 1999. Personal exposure to dust, endotoxin and crystalline silica in California agriculture. Ann Occup Hyg 43(1):35–42.10028892
Ning RY. 2002. Discussion of silica speciation, fouling, control and maximum reduction. Desalination 151:67–73.
NIOSH. 1981. Silica flour: Silicosis (crystalline silica). National Institute for Occupational Safety and Health. 81–137. http://www.cdc.gov/niosh/docs/81-137/. September 23, 2015.
NIOSH. 1986. Occupational respiratory diseases. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/docs/86-102/86-102.pdf. March 12, 2019.
NIOSH. 1994a. Silica, amorphous. Immediately Dangerous to Life or Health Concentrations (IDLH). Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/idlh/7631869.html. December 13, 2018.
NIOSH. 1994b. Silica, crystalline. Immediately Dangerous to Life or Health Concentrations (IDLH). Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/idlh/14808607.html. December 13, 2018.
NIOSH. 1994c. Work-related lung disease surveillance report. National Institute for Occupational Safety and Health. NIOSH Publ 94-120.
NIOSH. 2002. NIOSH hazard review. Health effects of occupational exposure to respirable crystalline silica. National Institute for Occupational Safety and Health. DHHS (NIOSH) publication number 2002-129. http://www.cdc.gov/niosh/docs/2002-129/pdfs/2002-129.pdf. October 6, 2015.
NIOSH. 2003a. Silica, crystalline, by XRD (filter redeposition). Method 7500, Issue 4. NIOSH Manual of Analytical Methods (NMAM). National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/docs/2003-154/pdfs/7500.pdf. October 6, 2015.
NIOSH. 2003b. Silica, crystalline, by VIS. Method 7601, issue 3. NIOSH Manual of Analytical Methods (NMAM). National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/docs/2003-154/pdfs/7601.pdf. October 6, 2015.
NIOSH. 2003c. Silica, amorphous. Method 7501, Issue 3. NIOSH Manual of Analytical Methods (NMAM). National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/docs/2003-154/pdfs/7501.pdf. October 6, 2015.
NIOSH. 2003d. Silica, crystalline by IR (KBr pellet) Method 7602. NIOSH Manual of Analytical Methods (NMAM). National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/docs/2003-154/pdfs/7602.pdf. October 6, 2015.
NIOSH. 2011. 1988 OSHA PEL project documentation. Silica, crystal. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/pel88/1317-95.html. August 06, 2015.
NIOSH. 2015a. Silica, amorphous. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/npg/npgd0552.html. July 30, 2015.
NIOSH. 2015b. Silica, crystalline (as respirable dust). NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/npg/npgd0684.html. July 30, 2015.
NIOSH. 2016a. Silica, amorphous. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0552.html. December 13, 2018.
NIOSH. 2016b. Silica, crystalline. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0684.html. December 13, 2018.
Norboo T, Angchuk PT, Yahya M, . 1991a. Silicosis in a Himalayan village population: Role of environmental dust. Thorax 46:341–343.2068689
Norboo T, Angchuk PT, Yahya M, . 1991b. Correction: Silicosis in a Himalayan village population: Role of environmental dust. (Thorax 46:341-343). Thorax 46:544.
NTP. 2009. Chemical information review document for silica flour (micronized alpha-quartz). Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/ntp/noms/support_docs/silica%20flour_oct2009.pdf. October 6, 2015.
NTP. 2014. Silica, crystalline (respirable size). Report on carcinogens. Thirteenth edition. Research Triangle Park, NC: National Toxicology Program. http://ntp.niehs.nih.gov/ntp/roc/content/profiles/silica.pdf. July 30, 2015.
NTP. 2016. Silica, crystalline (respirable size). Report on carcinogens, Fourteenth edition. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/silica.pdf. December 12, 2018.
Nuyts GD, Van Vlem E, De Vos A, . 1995. Wegener granulomatosis is associated to exposure to silicon compounds: A case-control study. Nephrol Dial Transplant 10(7):1162–1165.7478118
Oberdorster G. 2010. Safety assessment for nanotechnology and nanomedicine: concepts of nanotoxicology. J Intern Med 267(1):89–105. 10.1111/j.1365-2796.2009.02187.x.20059646
OECD. 2016. Silicon dioxide: Summary of the dossier. Series on the safety of manufactured nanomaterials No. 71. Organisation for Economic Co-operation and Development. JT03397644. ENV/JM/MONO(2016)23. http://www.oecd.org/officialdocuments/publicdisplaydocumentpdf/?cote=env/jm%20/mono(2016)23&doclanguage=en. March 8, 2019.
Ogawa S, Imai H, Ikeda M. 2003. Mortality due to silico-tuberculosis and lung cancer among 200 whetstone cutters. Ind Health 41(3):231–235.12916753 (As cited in Pelucci et al. 2006)
Oksa P, Pukkala E, Karjalainen A, . 1997. Cancer incidence and mortality among Finnish asbestos sprayers and in asbestosis and silicosis patients. Am J Ind Med 31(6):693–698.9131223 (As cited in Erren et al. 2009a, 2009b; Kurihara and Wada 2004; Lacrasse et al. 2005)
+Oner G, Cirrik S, Bakan O. 2005. Effects of silica on mitochondrial functions of the proximal tubule cells in rats. Kidney Blood Press Res 28(4):203–210. 10.1159/000086006.15925897
+Oner G, Cirrik S, Bulbul M, . 2006. Dietary silica modifies the characteristics of endothelial dilation in rat aorta. Endothelium 13(1):17–23. 10.1080/10623320600660045.16885063
OSHA. 1997. Occupational exposure to methylene chloride. Occupational Safety and Health Administration. Fed Regist 62(7):1494–1619. https://www.federalregister.gov/articles/1997/01/10/97-198/occupational-exposure-to-methylene-chloride. June 28, 2016.
OSHA. 2009. Controlling silica exposures in construction. Occupational Safety and Health Administration. https://www.osha.gov/Publications/3362silica-exposures.pdf. October 24, 2016.
OSHA. 2013. Occupational exposure to respirable crystalline silica. Occupational Safety and Health Administration. Fed Regist 78(177):56274–56504. http://www.gpo.gov/fdsys/pkg/FR-2013-09-12/pdf/2013-20997.pdf. October 6, 2015.
OSHA. 2018a. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Respirable crystalline silica. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1053. https://www.gpo.gov/fdsys/pkg/CFR-2018-title29-vol7/pdf/CFR-2018-title29-vol7-sec1915-1053.pdf. December 12, 2018.
OSHA. 2018b. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.gpo.gov/fdsys/pkg/CFR-2018-title29-vol6/pdf/CFR-2018-title29-vol6-sec1910-1000.pdf. December 13, 2018.
OSHA. 2018c. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Respirable crystalline silica. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1053. https://www.gpo.gov/fdsys/pkg/CFR-2018-title29-vol6/pdf/CFR-2018-title29-vol6-sec1910-1053.pdf. December 12, 2018.
OSHA. 2018d. Safety and health regulations for construction. Subpart Z - Toxic and hazardous substances. Respirable crystalline silica. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.1153. https://www.gpo.gov/fdsys/pkg/CFR-2018-title29-vol8/pdf/CFR-2018-title29-vol8-sec1926-1153.pdf. December 13, 2018.
Oshimura M, Hesterberg TW, Tsutsui T, . 1984. Correlation of asbestos-induced cytogenetic effects with cell transformation of Syrian hamster embryo cells in culture. Cancer Res 44(11):5017–5022.6091868
Otsuki T, Maeda M, Murakami S, . 2007. Immunological effects of silica and asbestos. Cell Mol Immunol 4(4):261–268.17764616
Page-Shipp RJ, Harris E. 1972. A study of the dust exposure of South African white gold miners J South Afri Instit Mining Metal August:10-22. (As cited in Mannetje et al. 2002b)
Pairon JC, Jaurand MC, Kheuang L, . 1990. Sister chromatid exchanges in human lymphocytes treated with silica. Br J Ind Med 47(2):110–115.2155649
Park R, Rice F, Stayner L, . 2002. Exposure to crystalline silica, silicosis, and lung disease other than cancer in diatomaceous earth industry workers: a quantitative risk assessment. Occup Environ Med 59(1):36–43.11836467
Parks CG, Conrad K, Cooper GS. 1999. Occupational exposure to crystalline silica and autoimmune disease. Environ Health Perspect 107(Suppl 5):793–802.10970168
Partanen T, Pukkala E, Vainio H, . 1994. Increased incidence of lung and skin cancer in Finnish silicotic patients. J Occup Med 36(6):616–622.8071722 (As cited in Erren et al. 2009a, 2009b; Lacrasse et al. 2005)
Pelucchi C, Pira E, Piolatto G, . 2006. Occupational silica exposure and lung cancer risk: A review of epidemiological studies 1996-2005. Ann Oncol 17(7):1039–1050. 10.1093/annonc/mdj125.16403810
Peluso ME, Munnia A, Giese RW, . 2015. Oxidatively damaged DNA in the nasal epithelium of workers occupationally exposed to silica dust in Tuscany region, Italy. Mutagenesis 30(4):519–525. 10.1093/mutage/gev014.25771384
Piacitelli GM, Amandus HE, Diefenbach A. 1990. Respirable dust exposures in USA surface coal mines (1982-1986). Arch Environ Health 45(4):202–209.2169228
Plunkett ER, Dewitt BJ. 1962. Occupational exposure to Hi-Sil and Silene. Report of an 18-year study. Arch Environ Health 5:469–472.13944117
Poinen-Rughooputh S, Rughooputh MS, Guo Y, . 2016. Occupational exposure to silica dust and risk of lung cancer: an updated meta-analysis of epidemiological studies. BMC Public Health 16(1):1137. 10.1186/s12889-016-3791-5.27814719
Pollard KM. 2016. Silica, silicosis, and autoimmunity. Front Immunol 7:97. 10.3389/fimmu.2016.00097.27014276
Pratt PC. 1983. Lung dust content and response in guinea pigs inhaling three forms of silica. Arch Environ Health 38(4):197–204.6311117
Price-Jones MJ, Gubbings G, Chamberlain M. 1980. The genetic effects of crocidolite asbestos: Comparison of chromosome abnormalities and sister-chromatid exchanges. Mutat Res 79(4):331–336.
Pukkala E, Guo J, Kyyronen P, . 2005. National job-exposure matrix in analyses of census-based estimates of occupational cancer risk. Scand J Work Environ Health 31:97–107.15864903 (As cited in Lacasse et al. 2009; Pelucci et al. 2006)
Puntoni R, Goldsmith DF, Valerio F, . 1988. A cohort study of workers employed in a refractory brick plant. Tumori 74(1):27–34.2832986 (As cited in LaCasse et al. 2005; Poinen-Rughooputh et al. 2016)
Qaseem A, Wilt TJ, Weinberger SE, . 2011. Diagnosis and management of stable chronic obstructive pulmonary disease: a clinical practice guideline update from the American College of Physicians, American College of Chest Physicians, American Thoracic Society, and European Respiratory Society. Ann Intern Med 155(3):179–191. 10.7326/0003-4819-155-3-201108020-00008.21810710
Rabovsky J. 1995. Biogenic amorphous silica. Scand J Work Environ Health 21 Suppl 2(2):108–110. http://www.ncbi.nlm.nih.gov/pubmed/8929705.8929705
Radnoff D, Todor MS, Beach J. 2014. Occupational exposure to crystalline silica at Alberta work sites. J Occup Environ Hyg 11(9):557–570. 10.1080/15459624.2014.887205.24479465
Radovanovic Z, Markovic-Denic L, Marinkovic J, . 1991. Well water characteristics and the Balkan nephropathy. Nephron 57(1):52–54.1646406
Rafnsson V, Gunnarsdottir H. 1997. Lung cancer incidence among an Icelandic cohort exposed to diatomaceous earth and cristobalite. Scand J Work Environ Health 23(3):187–192.9243728 (As cited in Kurihara and Wada 2004; Pelucci et al. 2006)
Rafnsson V, Ingimarsson O, Hjalmarsson I, . 1998. Association between exposure to crystalline silica and risk of sarcoidosis. Occup Environ Med 55(10):657–660.9930085
Ranavaya MI, Reger RB, Battigelli MC. 1992. Non-occupational pneumoconiosis at high altitude villages in central Ladakh. Br J Ind Med 49(6):452–453.
Rando RJ, Shi R, Hughes JM, . 2001. Cohort mortality study of North American industrial sand workers. III. Estimation of past and present exposures to respirable crystalline silica. Ann Occup Hyg 45(3):209–216.11295144
Rapiti E, Sperati A, Miceli M, . 1999. End stage renal disease among ceramic workers exposed to silica. Occup Environ Med 56(8):559–561.10492655
Rappaport SM, Goldberg M, Susi P, . 2003. Excessive exposure to silica in the US construction industry. Ann Occup Hyg 47(2):111–122.12581996
Rasch EK, Hirsch R, Paulose-Ram R, . 2003. Prevalence of rheumatoid arthritis in persons 60 years of age and older in the United States Effects of different methods of case classification. Arthritis Rheum 48(4):917–926.12687533
Rees D, Murray J. 2007. Silica, silicosis and tuberculosis. Int J Tuberc Lung Dis 11(5):474–484.17439668
Reid PJ, Sluis-Cremer GK. 1996. Mortality of white South African gold miners. Occup Environ Med 53(1):11–16.8563852 (As cited in Mannetje et al. 2002b)
RePORTER. 2015. Silica compounds. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. September 18, 2015.
RePORTER. 2019. Silica compounds. National Institutes of Health, Research Portfolio Online Reporting Tools. March 14, 2019. http://projectreporter.nih.gov/reporter.cfm.
+Reuzel PG, Bruijntjes JP, Feron VJ, . 1991. Subchronic inhalation toxicity of amorphous silicas and quartz dust in rats. Food Chem Toxicol 29(5):341–354.1648030
Richards JR, Brozell TT, Rea C, . 2009. PM4 crystalline silica emission factors and ambient concentrations at aggregate-producing sources in California. J Air Waste Manage Assoc 59:1287–1295. 10.3155/1047-3289.59.11.1287.
Rihova Z, Maixnerova D, Jancova E, . 2005. Silica and asbestos exposure in ANCA-associated vasculitis with pulmonary involvement. Ren Fail 27(5):605–608.16153001
Rimal B, Greenberg AK, Rom WN. 2005. Basic pathogenetic mechanisms in silicosis: Current understanding. Curr Opin Pulm Med 11(2):169–173.15699791
Rimola A, Costa D, Sodupe M, . 2013. Silica surface features and their role in the adsorption of biomolecules: Computational modeling and experiments. Chem Rev 113(6):4216–4313. 10.1021/cr3003054.23289428
Robalo-Cordeiro AJ, Baganha MF, Azevedo-Bernarda R, . 1985. Biological effects of fume silica amorphous type. In: Beck EG, Bignon J, eds. In vitro effects of mineral dusts. New York, NY: Springer-Verlag, 489–496.
Rocha-Parise M, Santos LM, Damoiseaux JG, . 2014. Lymphocyte activation in silica-exposed workers. Int J Hyg Environ Health 217(4–5):586–591. 10.1016/j.ijheh.2013.11.002.24332681
Rodnan GP, Benedek TG, Medsger TA, Jr., . 1967. The association of progressive systemic sclerosis (scleroderma) with coal miners’ pneumoconiosis and other forms of silicosis. Ann Intern Med 66(2):323–334.4224922
Rodriguez V, Tardon A, Kogevinas M, . 2000. Lung cancer risk in iron and steel foundry workers: A nested case-control study in Asturias, Spain. Am J Ind Med 38(6):644–650.11071687 (As cited in Pelucci et al. 2006)
Rong Y, Zhou M, Cui X, . 2018. MiRNA-regulated changes in extracellular matrix protein levels associated with a severe decline in lung function induced by silica dust. J Occup Environ Med 60(4):326–321. 10.1097/JOM.0000000000001268.
+Rosenbruch M. 1992. Inhalation of amorphous silica: morphological and morphometric evaluation of lung associated lymph nodes in rats. Exp Toxicol Pathol 44(1):10–14. 10.1016/s0940-2993(11)80130-2.1327331
Rosenman KD, Zhu Z. 1995. Pneumoconiosis and associated medical conditions. Am J Ind Med 27(1):107–113.7900728
Rosenman KD, Moore-Fuller M, Reilly MJ. 1999. Connective tissue disease and silicosis. Am J Ind Med 35(4):375–381.10086214
Rosenman KD, Moore-Fuller M, Reilly MJ. 2000. Kidney disease and silicosis. Nephron 85(1):14–19.10773750
Rosenman KD, Reilly MJ, Henneberger PK. 2003. Estimating the total number of newly-recognized silicosis cases in the United States. Am J Ind Med 44(2):141–147. 10.1002/ajim.10243.12874846
Rothschild H, Mulvey JJ. 1982. An increased risk for lung cancer mortality associated with sugarcane farming. J Natl Cancer Inst 68:755–750.6951086
Saffiotti U, Daniel LH, Mao Y, . 1993. Biological studies on the carcinogenic effects of quartz. In: Reviews in mineralogy. Health effects of mineral dusts. Proceedings of a short course endorsed by the American College of Chest Physicians and the U.S. Geological Survey. Vol. 28. Washington, DC: Mineralogical Society of America, 523–544.
Sakai-Kato K, Hidaka M, Un K, . 2014. Physicochemical properties and in vitro intestinal permeability properties and intestinal cell toxicity of silica particles, performed in simulated gastrointestinal fluids. Biochim Biophys Acta 1840(3):1171–1180. 10.1016/j.bbagen.2013.12.014.24361607
Saldanha LF, Rosen VJ, Gonnick HC. 1975. Silicon nephropathy. Am J Med 59:95–103.1138557
Sanderson WT, Steenland K, Deddens JA. 2000. Historical respirable quartz exposures of industrial sand workers: 1946-1996. Am J Ind Med 38(4):389–398.10982979
Sauni R, Oksa P, Lehtimaki L, . 2012. Increased alveolar nitric oxide and systemic inflammation markers in silica-exposed workers. Occup Environ Med 69(4):256–260. 10.1136/oemed-2011-100347.22068172
Sayan M, Mossman BT. 2016. The NLRP3 inflammasome in pathogenic particle and fibre-associated lung inflammation and diseases. Part Fibre Toxicol 13(1):51. 10.1186/s12989-016-0162-4.27650313
Scarselli A, Binazzi A, Forastiere F, . 2011. Industry and job-specific mortality after occupational exposure to silica dust. Occup Med (Lond) 61(6):422–429. 10.1093/occmed/kqr060.21685405 (As cited in Poinen-Rughooputh et al. 2016)
Scarselli A, Corfiati M, Marzio DD, . 2014. Evaluation of workplace exposure to respirable crystalline silica in Italy. Int J Occup Environ Health 20(4):301–307. 10.1179/2049396714y.0000000078.25078346
+Schepers GW. 1959. Hypertension due to inhaled submicron amorphous silica. Toxicol Appl Pharmacol 1:487–500.13854666
+Schepers GWH. 1962. Reaction of monkey lung to siliceous dust. Arch Environ Health 5:278–299.14498249
+Schepers GWH. 1981. Biological action of precipitation-process submicron a-silica (HI-SIL 233). In: Dunnom DD, ed. Health effects of synthetic silica particulates: A symposium sponsored by ASTM Committee E-34 on occupational health and safety and the Industrial Health Foundation. ASTM special technical publication 732. Philadelphia, PA: American Society for Testing and Materials, 144–171.
+Schepers GW, Durkan TM, Delahant AB, . 1957a. The biological action of Degussa submicron amorphous silica dust (Dow Corning silica). I. Inhalation studies on rats. AMA Arch Ind Health 16(2):125–146.13443529
+Schepers GW, Durkan TM, Delahant AB, . 1957b. The biological action of inhaled Degussa submicron amorphous silica dust (Dow Corning silica). II. The pulmonary reaction in uninfected guinea pigs. AMA Arch Ind Health 16(3):203–224.13457439
+Schepers GW, Delahant AB, Schmidt JG, . 1957c. The biological action of Degussa submicron amorphous silica dust (Dow Corning silica). III. Inhalation studies on rabbits. AMA Arch Ind Health 16(4):280–301.13457449
Schiller A, Gusbeth-Tatomir P, Pavlovic N, . 2008. Balkan endemic nephropathy: A still unsolved puzzle. J Nephrol 21:673–680.18949721
Schins RP. 2002. Mechanisms of genotoxicity of particles and fibers. Inhal Toxicol 14(1):57–78. 10.1080/089583701753338631.12122560
Schins RPF, Duffin R, Hohr D, . 2002a. Surface modification of quartz inhibits toxicity, particle uptake, and oxidative DNA damage in human lung epithelial cells. Chem Res Toxicol 15(9):1166–1173.12230410
Schins RPF, Knaapen AM, Cakmak GD, . 2002b. Oxidant-induced DNA damage by quartz in alveolar epithelial cells. Mutat Res 517(1–2):77–86.12034310
Schuler G, Ruttner JR. 1986. Silicosis and lung cancer in Switzerland. In: Goldsmith DF, Winn DM, Shy CM, eds. Silica, silicosis, and cancer: Controversy in occupational medicine. New York: Praeger, 357–366. (As cited in Erren et al. 2009a, 2009b)
Seiler F, Rehn B, Rehn S, . 2001a. Evidence of a no-effect level in silica-induced rat lung mutagenicity but not in fibrogenicity. Arch Toxicol 74(11):716–719.11218049
Seiler F, Rehn B, Rehn S, . 2001b. Quartz exposure of the rat lung leads to a linear dose response in inflammation but not in oxidative DNA damage and mutagenicity. Am J Respir Cell Mol Biol 24(4):492–498. 10.1165/ajrcmb.24.4.4181.11306444
Seiler F, Rehn B, Rehn S, . 2001c. Significant differences in the cellular and molecular reactions of rat and hamster lung after quartz exposure. Toxicol Lett 119(1):11–19.11275417
Seixas NS, Heyer NJ, Welp EAE, . 1997. Quantification of historical dust exposures in the diatomaceous earth industry. Ann Occup Hyg 41(5):591–604.9332160 (As cited in Mannetje et al. 2002b)
Sellamuthu R, Umbright C, Roberts JR, . 2011. Blood gene expression profiling detects silica exposure and toxicity. Toxicol Sci 122(2):253–264. 10.1093/toxsci/kfr125.21602193
Semple S, Green DA, McAlpine G, . 2008. Exposure to particulate matter on an Indian stone-crushing site. Occup Environ Med 65(5):300–305. 10.1136/oem.2007.032805.17681995
Sferratore A, Garnier J, Billen G, . 2006. Diffuse and point sources of silica in the Seine River watershed. Environ Sci Technol 40(21):6630–6635.17144288
Sheffield GS. 1994. Quantitative measurement of crystalline silica by thermal analysis. Anal Chim Acta 286(1):125–128.
Sherson D, Svane O, Lynge E. 1991. Cancer incidence among foundry workers in Denmark. Arch Environ Health 46(2):75–81. 10.1080/00039896.1991.9937432.2006897 (As cited in Erren et al. 2009a, 2009b; Kurihara and Wada 2004)
Shi X, Mao Y, Daniel LN, . 1994. Silica radical-induced DNA damage and lipid peroxidation. Environ Health Perspect 102 Suppl 10:149–154.
Shi X, Ding M, Chen F, . 2001. Reactive oxygen species and molecular mechanism of silica-induced lung injury. J Environ Pathol Toxicol Oncol 20 Suppl 1:85–93.11570677
Shih TS, Lu PY, Chen CH, . 2008. Exposure profiles and source identifications for workers exposed to crystalline silica during a municipal waste incinerator relining period. J Hazard Mater 154(1–3):469–475. 10.1016/j.jhazmat.2007.10.047.18063296
Shiraki R, Holmen BA. 2002. Airborne respirable silica near a sand and gravel facility in central California: XRD and elemental analysis to distinguish source and background quartz. Environ Sci Technol 36(23):4956–4961.12523406
Shtraichman O, Blanc PD, Ollech JE, . 2015. Outbreak of autoimmune disease in silicosis linked to artificial stone. Occup Med (Lond) 65(6):444–450. 10.1093/occmed/kqv073.26070814
Silman AJ, Jones S. 1992. What is the contribution of occupational environmental factors to the occurrence of scleroderma in men? Ann Rheum Dis 51(12):1322–1324.1336652
Singh SV, Das B, Khan MF, . 1984. The binding of silica to proteins from plasma and lungs of rat: in vitro. Chem Biol Interact 49(1–2):155–164 6327093
Sinks T, Goodman MT, Kolonel LN, . 1994. A case-control study of mesothelioma and employment in the Hawaii sugarcane industry. Epidemiology 5(4):466–468. http://www.ncbi.nlm.nih.gov/pubmed/7918819.7918819
Sirianni G, Hosgood HD, 3rd, Slade MD, . 2008. Particle size distribution and particle size-related crystalline silica content in granite quarry dust. J Occup Environ Hyg 5(5):279–285. 10.1080/15459620801947259.18300081
Slavov E, Miteva L, Prakova G, . 2010. Correlation between TNF-alpha and IL-12p40-containing cytokines in silicosis. Toxicol Ind Health 26(8):479–486. 10.1177/0748233710373082.20529962
Sluis-Cremer GK, Hessel PA, Nizdo EH, . 1985. Silica, silicosis, and progressive systemic sclerosis. Br J Ind Med 42(12):838–843.3000415
Sluis-Cremer GK, Hessel PA, Hnizdo E, . 1986. Relationship between silicosis and rheumatoid arthritis. Thorax 41(8):596–601.3787543
Smailyte G, Kurtinaitis J, Andersen A. 2004. Mortality and cancer incidence among Lithuanian cement producing workers. Occup Environ Med 61(6):529–534.15150393 (As cited in Pelucci et al. 2006)
Smart RH, Andersen WM. 1952. Pneumoconiosis due to diatomaceous earth: Clinical and x-ray aspects. Ind Med Surg 21:509–518.13010838
Smith DK. 1998. Opal, cristobalite, and tridymite: Noncrystallinity versus crystallinity, nomenclature of the silica minerals and bibliography. Powder Diffr 13(1):2–19. 10.1017/s0885715600009696.
Smith CM. 2006. Silica, vitreous. In: Kirk-Othmer encyclopedia of chemical technology. Vol. 22. John Wiley & Sons, Inc. http://onlinelibrary.wiley.com/doi/10.1002/0471238961.2209201819051316.a01.pub2/abstract. September 22, 2015.
Smith AH, Lopipero PA, Barroga VR. 1995. Meta-analysis of studies of lung cancer among silicotics. Epidemiology 6(6):617–624.8589094
Snipes MB. 1996. Current information on lung overload in non-rodent mammals: Contrast with rats. In: Mauderly JL, McCunney RJ, eds. Particle overload in the rat lung and lung cancer. Implications for human risk assessment. Proceedings of a conference held at the Massachusetts Institute of Technology on March 29 and 30, 1995. Vol. 8. Taylor & Francis, 91–109.
Sobti RC, Bhardwaj DK. 1991. Cytogenetic damage and occupational exposure. I. Exposure to stone dust. Environ Res 56(1):25–30.1655400
Soutar CA, Robertson A, Miller BG, . 2000. Epidemiological evidence on the carcinogenicity of silica: factors in scientific judgement. Ann Occup Hyg 44(1):3–14.10689755
Starzynski Z, Marek K, Kujawska A, . 1996. Mortality among different occupational groups of workers with pneumoconiosis: Results from a register-based cohort study. Am J Ind Med 30(6):718–725. 10.1002/(sici)1097-0274(199612)30:6<718::aid-ajim8>3.0.co;2-m.8914718 (As cited in Erren et al. 2009a, 2009b; Pelucci et al. 2006)
Steenland K. 2005. One agent, many diseases: Exposure-response data and comparative risks of different outcomes following silica exposure. Am J Ind Med 48(1):16–23. 10.1002/ajim.20181.15940719
Steenland K, Beaumont J. 1986. A proportionate mortality study of granite cutters. Am J Ind Med 9(2):189–202.3963000 (As cited in Erren et al. 2009a, 2009b)
Steenland K, Brown D. 1995a. Silicosis among gold miners: Exposure-response analyses and risk assessment. Am J Public Health 85(10):1372–1377.7573620
Steenland K, Brown D. 1995b. Mortality study of gold miners exposed to silica and nonasbestiform amphibole minerals: An uptake with 14 more years of follow-up. Am J Ind Med 27(2):217–229.7755012
Steenland K, Goldsmith DF. 1995. Silica exposure and autoimmune diseases. Am J Ind Med 28(5):603–608.8561170
Steenland K, Sanderson W. 2001. Lung cancer among industrial sand workers exposed to crystalline silica. Am J Epidemiol 153(7):695–703.11282798
Steenland K, Ward E. 2014. Silica: a lung carcinogen. CA Cancer J Clin 64(1):63–69. 10.3322/caac.21214.24327355
Steenland K, Sanderson W, Calvert GM. 2001b. Kidney disease and arthritis in a cohort study of workers exposed to silica. Epidemiology 12(4):405–412.11416778
Steenland K, Attfield M, Mannejte A. 2002a. Pooled analyses of renal disease mortality and crystalline silica exposure in three cohorts. Ann Occup Hyg 46(Suppl 1):4–9.
Steenland NK, Thun MJ, Ferguson CW, . 1990. Occupational and other exposures associated with male end-stage renal disease: a case/control study. Am J Public Health 80(2):153–157.2153349
Steenland K, Nowlin S, Ryan BM, . 1992. Use of multiple-cause mortality data in epidemiologic analyses: U.S. rate and proportion files developed by the National Institute for Occupational Safety and Health and the National Cancer Institute. Am J Epidemiol 136(7):855–862.1442751
Steenland K, Mannetje A, Boffetta P, . 2001a. Pooled exposure-response analyses and risk assessment for lung cancer in 10 cohorts of silica-exposed workers: An IARC multicentre study. Cancer Causes Control 12(9):773–784.11714104
Steenland K, Rosenman K, Socie E, . 2002b. Silicosis and end-stage renal disease. Scand J Work Environ Health 28(6):439–442.12539804
Stober W. 1999. POCK model simulations of pulmonary quartz dust retention data in extended inhalation exposures of rats. Inhal Toxicol 11(4):269–292.10380170
Stolt P, Kallberg H, Lundberg I, . 2005. Silica exposure is associated with increased risk of developing rheumatoid arthritis: results from the Swedish EIRA study. Ann Rheum Dis 64(4):582–586. 10.1136/ard.2004.022053.15319232
Stolt P, Yahya A, Bengtsson C, . 2010. Silica exposure among male current smokers is associated with a high risk of developing ACPA-positive rheumatoid arthritis. Ann Rheum Dis 69(6):1072–1076. 10.1136/ard.2009.114694.19966090
Stone RA, Youk AO, Marsh GM, . 2004. Historical cohort study of U.S. man-made vitreous fiber production workers IX: Summary of 1992 mortality follow up and analysis of respiratory system cancer among female workers. J Occup Environ Med 46(1):55–67. 10.1097/01.jom.0000105905.60844.e1.14724479 (As cited in Pelucci et al. 2006)
Stopford W. 1994. Carbonate fusion to determine quartz in respirable and bulk earth samples. Anal Chim Acta 286(1):67–73.
Stopford CM, Stopford W. 1995. Potential for respirable quartz exposure from North Carolina farm soils. Scand J Work Environ Health 21 Suppl 2:44–46.8929688
Stormer A, Bott J, Kemmer D, . 2017. Critical review of the migration potential of nanoparticles in food contact plastics. Trends Food Sci Technol 63:39–50.
Stratta P, Canavese C, Messuerotti A, . 2001a. Silica and renal diseases: No longer a problem in the 21st century? J Nephrol 14(4):228–247.11506245
Stratta P, Messuerotti A, Canavese C, . 2001b. The role of metals in autoimmune vasculitis: Epidemiological and pathogenic study. Sci Total Environ 270(1–3):179–190.11327392
Strelec F. 2010. OSHA compliance issues. Silica exposure in an iron foundry furnace cleaning operation. J Occup Environ Hyg 7(5):D23–26. 10.1080/15459621003640460.20213569
Swanepoel AJ, Kromhout H, Jinnah ZA, . 2011. Respirable dust and quartz exposure from three South African farms with sandy, sandy loam, and clay soils. Ann Occup Hyg 55(6):634–643. 10.1093/annhyg/mer025.21685408
Swensson A, Kvarnstrom K, Bruce T, . 1971. Pneumoconiosis in ferrosilicon workers--A follow-up study. J Occup Med 13(9):427–432.5115234
Szadkowska-Stanczyk I, Szymczak W. 2001. Nested case-control study of lung cancer among pulp and paper workers in relation to exposure to dusts. Am J Ind Med 39(6):547–556.11385638 (As cited in Kurihara and Wada 2004; Pelucci et al. 2006)
Taeger D, McCunney R, Bailer U, . 2016. Cross-sectional study on nonmalignant respiratory morbidity due to exposure to synthetic amorphous silica. J Occup Environ Med 58(4):376–384. 10.1097/jom.0000000000000666.27058478
+Takizawa Y, Hirasawa F, Noritomi E, . 1988. Oral ingestion of syloid to mice and rats and its chronic toxicity and carcinogenicity. Acta Med Biol (Niigata) 36(1):27–56.
+Tebbens BD, Beard RR. 1957. Experiments on diatomaceous earth pneumoconiosis. AMA Arch Ind Health 16:55–63.13434498
teWaterNaude JM, Ehrlich RI, Churchyard GJ, . 2006. Tuberculosis and silica exposure in South African gold miners. Occup Environ Med 63(3):187–192. 10.1136/oem.2004.018614.16497860
Theriault GP, Peters JM, Johnson WM. 1974. Pulmonary function and roentgenographic changes in granite dust exposure. Arch Environ Health 28(1):23–27.4357263
Thibodeau MS, Giardina C, Knecht DA, . 2004. Silica-induced apoptosis in mouse alveolar macrophages is initiated by lysosomal enzyme activity. Toxicol Sci 80(1):34–48 10.1093/toxsci/kfh121.15056807
Thomas TL, Stewart PA. 1987. Mortality from lung cancer and respiratory disease among pottery workers exposed to silica and talc. Am J Epidemiol 125(1):35–43.3024482
Thomeer M, Demedts M, Wuyts W. 2005. Epidemiology of sarcoidosis. Eur Respir Monogr 32:13–22.
Tornling G, Hogstedt C, Westerholm P. 1990. Lung cancer incidence among Swedish ceramic workers with silicosis. IARC Sci Publ (97):113–119. (As cited in Erren et al. 2009a, 2009b)
Treguer PJ, De La Rocha CL. 2013. The world ocean silica cycle. Ann Rev Mar Sci 5:477–501. 10.1146/annurev-marine-121211-172346.
Treguer P, Nelson DM, Van Bennekom AJ, . 1995. The silica balance in the world ocean: a reestimate. Science 268(5209):375–379. 10.1126/science.268.5209.375.17746543
Tse LA, Yu ITS, Leung CC, . 2007. Mortality from non-malignant respiratory diseases among people with silicosis in Hong Kong: Exposure-response analyses for exposure to silica dust. Occup Environ Med 64(2):87–92.16973737
Tse LA, Yu IT, Qiu H, . 2014. Joint effects of smoking and silicosis on diseases to the lungs. PLoS ONE 9(8):e104494. 10.1371/journal.pone.0104494.25105409
Tsuda T, Mino Y, Babazono A, . 2002. A case-control study of lung cancer in relation to silica exposure and silicosis in a rural area in Japan. Ann Epidemiol 12(5):288–294.12062914 (As cited in Erren et al. 2009a, 2009b; Pelucci et al. 2006)
Tsugita M, Morimoto N, Tashiro M, . 2017. SR-B1 Is a Silica Receptor that Mediates Canonical Inflammasome Activation. Cell Reports 18(5):1298–1311. 10.1016/j.celrep.2017.01.004.28147282
Turci F, Pavan C, Leinardi R, . 2016. Revisiting the paradigm of silica pathogenicity with synthetic quartz crystals: the role of crystallinity and surface disorder. Part Fibre Toxicol 13(1):32. 10.1186/s12989-016-0136-6.27286702
Turner S, Cherry N. 2000. Rheumatoid arthritis in workers exposed to silica in the pottery industry. Occup Environ Med 57(7):443–447.10854495
Uhrlandt S. 2006. Silica. In: Kirk-Othmer encyclopedia of chemical technology. Vol. 22. John Wiley & Sons, Inc., 1–17.
Ulm K, Waschulzik B, Ehnes H, . 1999. Silica dust and lung cancer in the German stone, quarrying, and ceramics industries: Results of a case-control study. Thorax 54(4):347–351.10092697 (As cited in Kurihara and Wada 2004; Lacasse et al. 2009; Pelucci et al. 2006)
Ulm K, Gerein P, Eigenthaler J, . 2004. Silica, silicosis and lung-cancer: Results from a cohort study in the stone and quarry industry. Int Arch Occup Environ Health 77(5):313–318. 10.1007/s00420-004-0513-6.15156325
Ulvestad B, Bakke B, Eduard W, . 2001. Cumulative exposure to dust causes accelerated decline in lung function in tunnel workers. Occup Environ Med 58(10):663–669.11555688
USDA. 2018. Nonagricultural (nonorganic) substances allowed as ingredients in or on processed products labeled as “organic” or “made with organic (specified ingredients or food group(s)). Synthetics allowed. U.S. Department of Agriculture. Code of Federal Regulations 7 CFR 205605(b) https://www.ecfr.gov/cgi-bin/text-idx?c=ecfr&SID=9874504b6f1025eb0e6b67cadf9d3b40&rgn=div6&view=text&node=7:3.1.1.9.32.7&idno=7#se7.3.205_1605. December 17, 2018.
USGS. 1987. Metals, atomic emission spectrometry, inductively coupled plasma (ICP). U.S. Geological Survey. I-1472-87. https://www.nemi.gov/methods/method_summary/8896/. March 14, 2019.
USGS. 1992. Crystalline silica primer. U.S. Geological Survey. http://minerals.usgs.gov/minerals/pubs/commodity/silica/780292.pdf. October 6, 2015.
USGS. 2014a. 2012 Minerals yearbook. Gemstones [advance release]. U.S. Geological Survey. http://minerals.usgs.gov/minerals/pubs/commodity/gemstones/myb1-2012-gemst.pdf. October 7, 2015.
USGS. 2014b. 2012 Minerals yearbook. Silica [advance release]. U.S. Geological Survey. http://minerals.usgs.gov/minerals/pubs/commodity/silica/myb1-2012-silic.pdf. October 7, 2015.
USGS. 2014c. 2012 Minerals yearbook. Sand and gravel, construction [advance release]. U.S. Geological Survey. http://minerals.usgs.gov/minerals/pubs/commodity/sand_&_gravel_construction/myb1-2012-sandc.pdf. October 7, 2015.
USGS. 2015. Mineral commodity summaries 2015. U.S. Geological Survey. http://minerals.usgs.gov/minerals/pubs/mcs/2015/mcs2015.pdf. October 6, 2015.
Vacek PM, Hemenway DR, Absher MP, . 1991. The translocation of inhaled silicon dioxide: an empirically derived compartmental model. Fundam Appl Toxicol 17(3):614–626 1665463
Vacek PM, Verma DK, Graham WG, . 2011. Mortality in Vermont granite workers and its association with silica exposure. Occup Environ Med 68(5):312–318. 10.1136/oem.2009.054452.20855299
van Deurssen E, Pronk A, Spaan S, . 2014. Quartz and respirable dust in the Dutch construction industry: a baseline exposure assessment as part of a multidimensional intervention approach. Ann Occup Hyg 58(6):724–738. 10.1093/annhyg/meu021.24723463
Varela SN, Schwerk J, Forero A, . 2017. Post-transcriptional elements within NLRP3 mRNA set the activation threshold of the inflammasome. J Immunol 198(Suppl 1):67.69.
Vayias BJ, Athanassiou CG, Korunic Z, . 2009. Evaluation of natural diatomaceous earth deposits from south-eastern Europe for stored-grain protection: the effect of particle size. Pest Manag Sci 65(10):1118–1123. 10.1002/ps.1801.19544360
Vearrier D, Greenberg MI. 2011. Occupational health of miners at altitude: adverse health effects, toxic exposures, pre-placement screening, acclimatization, and worker surveillance. Clin Toxicol (Phila) 49(7):629–640. 10.3109/15563650.2011.607169.21861588
Verma DK, Rajhans GS, Malik OP, . 2014. Respirable dust and respirable silica exposure in Ontario gold mines. J Occup Environ Hyg 11(2):111–116. 10.1080/15459624.2013.843784.24369933
Vigliani EC, Mottura G. 1948. Diatomaceous earth silicosis. Br J Ind Med 5(3):148–160.18873553
Vihlborg P, Bryngelsson IL, Andersson L, . 2017. Risk of sarcoidosis and seropositive rheumatoid arthritis from occupational silica exposure in Swedish iron foundries: a retrospective cohort study. BMJ Open 7(7):e016839. 10.1136/bmjopen-2017-016839.
Vitums VC, Edwards MJ, Niles NR, . 1977. Pulmonary fibrosis from amorphous silica dust, a product of silica vapor. Arch Environ Health 32(2):62–68.192157
Voice TC, Long DT, Radovanovic Z, . 2006. Critical evaluation of environmental exposure agents suspected in the etiology of Balkan endemic nephropathy. Int J Occup Environ Health 12:369–376.17168225
Volk H. 1960. The health of workers in a plant making highly dispersed silica. Arch Environ Health 1:125–128.
Vupputuri S, Parks CG, Nylander-French LA, . 2012. Occupational silica exposure and chronic kidney disease. Ren Fail 34(1):40–46. 10.3109/0886022x.2011.623496.22032652
Waddell WH. 2006. Silica, amorphous. In: Kirk-Othmer encyclopedia of chemical technology. Vol. 22. John Wiley & Sons, Inc. http://onlinelibrary.wiley.com/doi/10.1002/0471238961.0113151823010404.a01.pub2/abstract. September 22, 2015.
Wall GR, Phillips PJ, Riva-Murray K. 1998. Seasonal and spatial patterns of nitrate and silica concentrations in Canajoharie Creek, New York. J Environ Qual 27(2):381–389.
Walsh SJ. 1999. Effects of non-mining occupational silica exposure on proportional mortality from silicosis and systemic sclerosis. J Rheumatol 26(10):2179–2185.10529136
Wang Z, Dong D, Liang X, . 1996. Cancer mortality among silicotics in China’s metallurgical industry. Int J Epidemiol 25(5):913–917.8921475 (As cited in Erren et al. 2009a, 2009b; Lacrasse et al. 2005)
Wang SX, Liu P, Wei MT, . 2007. Roles of serum Clara cell protein 16 and surfactant protein-D in the early diagnosis and progression of silicosis. J Occup Environ Med 49(8):834–839. 10.1097/JOM.0b013e318124a927.17693780
Ward MM. 2004. Prevalence of physician-diagnosed systemic lupus erythematosus in the United States: Results from the Third National Health and Nutrition Examination Survey. Journal of Women’s Health 13(6):713–718.
+Warheit DB, McHugh TA, Hartsky MA. 1995. Differential pulmonary responses in rats inhaling crystalline, colloidal or amorphous silica dusts. Scand J Work Environ Health 21 Suppl 2:19–21.8929682
+Warheit DB, Carakostas MC, Kelly DP, . 1991. Four-week inhalation toxicity study with Ludox colloidal silica in rats: pulmonary cellular responses. Fundam Appl Toxicol 16(3):590–601.1649779
Warheit DB, Webb TR, Colvin VL, . 2007. Pulmonary bioassay studies with nanoscale and fine-quartz particles in rats: toxicity is not dependent upon particle size but on surface characteristics. Toxicol Sci 95(1):270–280 10.1093/toxsci/kfl128.17030555
Watkins DK, Chiazze L, Jr., Fryar CD, . 2002. A case control study of lung cancer and non-malignant respiratory disease among employees in asphalt roofing manufacturing and asphalt production. J Occup Environ Med 44(6):551–558.12085482 (As cited in Pelucci et al. 2006)
Watts WF, Jr., Huynh TB, Ramachandran G. 2012. Quartz concentration trends in metal and nonmetal mining. J Occup Environ Hyg 9(12):720–732. 10.1080/15459624.2012.733566.23092305
Weeks JL, Rose C. 2006. Metal and non-metal miners’ exposure to crystalline silica, 1998-2002. Am J Ind Med 49(7):523–534. 10.1002/ajim.20323.16691611
Weissman DN, Ma JKH, Rojanasakul Y, . 1996. Immune dysfunction in silicosis: A Hypothesis. Appl Occup Environ Hyg 11(7):962–965.
Weng S, Wang L, Rong Y, . 2015. Effects of the Interactions between dust exposure and genetic polymorphisms in Nalp3, Caspase-1, and IL-1β on the risk of silicosis: A case-control study. PLoS ONE 10(10):e0140952. 10.1371/journal.pone.0140952.26496436
Westberg HB, Bellander T. 2003. Epidemiological adaptation of quartz exposure modeling in Swedish aluminum foundries: Nested case-control study on lung cancer. Appl Occup Environ Hyg 18(12):1006–1013. 10.1080/10473220390244676.14612297 (As cited in Lacasse et al. 2009; Pelucci et al. 2006)
Westerholm P. 1980. Silicosis. Observations on a case register. Scand J Work Environ Health 6 Suppl 2:1–86. (As cited in Erren et al. 2009a, 2009b; Poinen-Rughooputh et al. 2016)
Westerholm P, Ahlmark A, Maasing R, . 1986. Silicosis and risk of lung cancer or lung tuberculosis: a cohort study. Environ Res 41(1):339–350.3757978
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
Wickman AR, Middendorf PJ. 2002. An evaluation of compliance with occupational exposure limits for crystalline silica (quartz) in ten Georgia granite sheds. Appl Occup Environ Hyg 17(6):424–429. 10.1080/10473220290035444.12049432
Wilson MJ, Jones D, McHardy WJ. 1981. The weathering of serpentinite by Lecanora atra. Lichenologist (Oxf) 13(2):167–176
Wilson RK, Stevens PM, Lovejoy HB, . 1979. Effects of chronic amorphous silica exposure on sequential pulmonary function. J Occup Med 21(6):399–402.224156
+Wolterbeek A, Oosterwijk T, Schneider S, . 2015. Oral two-generation reproduction toxicity study with NM-200 synthetic amorphous silica in Wistar rats. Reprod Toxicol 56:147–154. 10.1016/j.reprotox.2015.03.006.25817409
Woskie SR, Kalil A, Bello D, . 2002. Exposures to quartz, diesel, dust, and welding fumes during heavy and highway construction. AIHA J (Fairfax, Va) 63(4):447–457.12486778
Wu JJ, Schiff KR. 2004. Sarcoidosis. Am Fam Physician 70:312–322.15291090
Wyndham CH, Bezuidenhout BN, Greenacre MJ, . 1986. Mortality of middle aged white South African gold miners. Br J Ind Med 43:677–684.3778838
Yassin A, Yebesi F, Tingle R. 2005. Occupational exposure to crystalline silica dust in the United States, 1988-2003. Environ Health Perspect 113(3):255–260.15743711
Yingratanasuk T, Seixas N, Barnhart S, . 2002. Respiratory health and silica exposure of stone carvers in Thailand. Int J Occup Environ Health 8(4):301–308. 10.1179/107735202800338722.12412846
Yu IT, Tse LA, Chi CL, . 2008. [A retrospective cohort study on mortality among silicotic workers in Hong Kong with emphasis on lung cancer]. Zhonghua Lao Dong Wei Sheng Zhi Ye Bing Za Zhi 26(1):29–33.18302888 (As cited in Poinen-Rughooputh et al. 2016 - Chinese)
Yucesoy B, Vallyathan V, Landsittel DP, . 2002. Cytokine polymorphisms in silicosis and other pneumoconioses. Mol Cell Biochem 234–235(1):219–224.12162437
Zambon P, Simonato L, Mastrangelo G, . 1987. Mortality of workers compensated for silicosis during the period 1959-1963 in the Veneto region of Italy. Scand J Work Environ Health 13(2):118–123.3602965
Zhang Z, Shen HM, Zhang QF, . 1999. Critical role of GSH in silica-induced oxidative stress, cytotoxicity, and genotoxicity in alveolar macrophages. Am J Physiol 277(4 Pt 1):L743–748.10516215
Zhang Z, Shen HM, Zhang QF, . 2000. Involvement of oxidative stress in crystalline silica-induced cytotoxicity and genotoxicity in rat alveolar macrophages. Environ Res 82(3):245–252. 10.1006/enrs.1999.4025.10702332
Zheng H, Hogberg J, Stenius U. 2017. ATM-activated autotaxin (ATX) propagates inflammation and DNA damage in lung epithelial cells: a new mode of action for silica-induced DNA damage? Carcinogenesis 38(12):1196–1206. 10.1093/carcin/bgx100.28968864
Zhong BZ, Ong T, Whong WZ. 1997a. Studies on the relationship between treatment condition and micronucleus induction in V79 cells exposed to silica and glass fibers. Mutat Res 391(1–2):111–116.9219555
Zhong BZ, Whong WZ, Ong TM. 1997b. Detection of mineral-dust-induced DNA damage in two mammalian cell lines using the alkaline single cell gel/comet assay. Mutat Res 393(3):181–187.9393610
Zhuravlev LT. 2000. The surface chemistry of amorphous silica. Zhuravlev model. Colloids Surf A Physicochem Eng Asp 173(1–3):1–38. 10.1016/S0927-7757(00)00556-2.
Ziegler V, Enderlein G, Mehlorn J, . 1997. [Retrospective epidemiological analysis of the relation between progressive systemic scleroderma and the exposure to quartz dust not from uranium ore mining in East Germany]. Zbl Arbeitsmed 47:7–13. (As cited in McCormic et al. 2010 - German)
Zuhl RW, Amjad Z. 2013. Solution chemistry impact on silica polymerization by inhibitors. In: Amjad Z, ed. Mineral scales in biological and industrial systems. Boca Raton, FL: CRC Press, 173–200.
Zumwalde R, Ludwig H, Dement J. 1981. Industrial hygiene report, Homestake Mining Company, Lead, South Dakota [USA]. Industry-wide studies branch, DSHEFS, NIOSH, Cincinnati, Ohio (As cited in Mannetje et al. 2002b)