# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Malcolm Williams, D.V.M., Ph.D. (Lead)
  Nickolette Roney, M.P.H.
  Obaid Faroon, D.V.M., Ph.D.
  Dennis Jones, D.V.M., Ph.D.
- ATSDR, Division of Toxicology and Human Health Sciences, Atlanta, GA
- Julie M. Klotzbach, Ph.D.
  Mary Kawa, M.A.
  Kimberly Zaccaria, Ph.D., D.A.B.T.
- SRC, Inc., North Syracuse, NY

## REVIEWERS

- Interagency Minimal Risk Level Workgroup:
  Includes ATSDR; National Center for Environmental Health (NCEH); National Institute of Occupational Health and Safety (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).
- Additional reviews for science and/or policy:
  ATSDR, Division of Community Health Investigations; ATSDR, Office of Science; NCEH, Division of Laboratory Science; NCEH, Division of Environmental Health Science and Practice.

## PEER REVIEWERS

1. Michael Greenberg, M.D., MPH, FACEP, Emergency Medicine, Drexel University, Philadelphia, Pennsylvania
2. Kyle Steenland, Ph.D., MS, Department of Environmental and Occupational Health, Emory University, Atlanta, Georgia
3. Kenneth D. Rosenman, M.D., Department of Medicine, Michigan State University, East Lansing, Michigan

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.