# VERSION HISTORY

Date | Description
September 2019 | Final toxicological profile released
April 2017 | Draft for public comment toxicological profile released