# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding silica in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for silica.

Table 7-1 Regulations and Guidelines Applicable to Silica

Agency | Description | Information | Reference
Air
EPA | RfC | No data | IRIS 2018
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | Not listed | EPA 2018a
EPA | National primary drinking water regulations | Not listed | EPA 2009
EPA | RfD | No data | IRIS 2018
EPA | Tolerance exemptions for minimal risk active and inert ingredients in pesticides | | EPA 2018b
EPA | Silica, amorphous, fumed (crystalline free) | Yes | EPA 2018b
EPA | Silica gel | Yes | EPA 2018b
EPA | Silica, vitreous | Yes | EPA 2018b
WHO | Drinking water quality guidelines | Not listed | WHO 2017
FDA | Substances added to food^a^
FDA | Silicon dioxide | Approved under food additive, GRAS, and color additive regulations | FDA 2018a
FDA | Diatomaceous earth | Approved under food additive and GRAS regulations | FDA 2018b
USDA | Nonagricultural (nonorganic) substances allowed as ingredients in or on processed products labeled as “organic” or “made with organic (specified ingredients or food group(s))” | | USDA 2018
USDA | Silicon dioxide | Permitted as a defoamer. Allowed for other uses when organic rice hulls are not commercially available | USDA 2018
USDA | Diatomaceous earth | Food filtering aid only | USDA 2018
Cancer
HHS | Carcinogenicity classification | | NTP 2016
HHS | Silica, crystalline (respirable size) | Known to be a human carcinogen | NTP 2016
EPA | Carcinogenicity classification | No data | IRIS 2018
IARC | Carcinogenicity classification
IARC | Silica, amorphous | Group 3^b^ | IARC 1997
IARC | Silica dust, crystalline, in the form of quartz or cristobalite | Group 1^c^ | IARC 2012
Occupational
OSHA | PEL (8-hour TWA) for general industry, construction or shipyard employment
OSHA | Respirable crystalline silica (quartz, cristobalite, and/or tridymite)^d^ | 0.05 mg/m^3^ | OSHA 2018a, OSHA 2018b, OSHA 2018c, OSHA 2018d
OSHA | Amorphous silica, including natural diatomaceous earth | 80 mg/m^3^/%SiO2 | OSHA 2018c
OSHA | PEL (8-hour TWA) for any operations or sectors where the exposure limit in 29 CFR 1910.1053 is stayed or is otherwise not in effect | | OSHA 2018c
OSHA | Quartz (respirable) | 10 mg/m^3^/(%SiO2+2) | OSHA 2018c
OSHA | Cristoballite, tridymite | Use 1⁄2 the value calculated from the formula for quartz | OSHA 2018c
NIOSH | REL (up to 10-hour TWA)
NIOSH | Silica, amorphous | 6 mg/m^3^ | NIOSH 2016a
NIOSH | Silica, crystalline (as respirable dust) | 0.05 mg/m^3e^ | NIOSH 2016b
NIOSH | IDLH
NIOSH | Silica, amorphous | 3,000 mg/m^3^ | NIOSH 1994a
NIOSH | Silica, crystalline (as respirable dust; cristobalite, tridymite) | 25 mg/m^3^ | NIOSH 1994b
NIOSH | Silica, crystalline (as respirable dust; quartz, tripoli) | 50 mg/m^3^ | NIOSH 1994b
Emergency Criteria
EPA | AEGLs-air | Not listed | EPA 2016
DOE | PACs-air | | DOE 2018b
DOE | PAC-1^f^ | | DOE 2018b
DOE | Silica amorphous hydrated | 18 mg/m^3^ | DOE 2018b
DOE | Silica, crystalline-quartz (silicon dioxide) | 0.075 mg/m^3^ | DOE 2018b
DOE | Cristobalite | 0.075 mg/m^3^ | DOE 2018b
DOE | Silica, amorphous fumed | 18 mg/m^3^ | DOE 2018b
DOE | Silica gel, amorphous synthetic | 18 mg/m^3^ | DOE 2018b
DOE | Silica gel | 18 mg/m^3^ | DOE 2018b
DOE | PAC-2^f^ | | DOE 2018b
DOE | Silica amorphous hydrated | 740 mg/m^3^ | DOE 2018b
DOE | Silica, crystalline-quartz (silicon dioxide) | 33 mg/m^3^ | DOE 2018b
DOE | Cristobalite | 33 mg/m^3^ | DOE 2018b
DOE | Silica, amorphous fumed | 100 mg/m^3^ | DOE 2018b
DOE | Silica gel, amorphous synthetic | 200 mg/m^3^ | DOE 2018b
DOE | Silica gel | 200 mg/m^3^ | DOE 2018b
DOE | PAC-3^f^ | | DOE 2018b
DOE | Silica amorphous hydrated | 4,500 mg/m^3^ | DOE 2018b
DOE | Silica, crystalline-quartz (silicon dioxide) | 200 mg/m^3^ | DOE 2018b
DOE | Cristobalite | 200 mg/m^3^ | DOE 2018b
DOE | Silica, amorphous fumed | 630 mg/m^3^ | DOE 2018b
DOE | Silica gel, amorphous synthetic | 1,200 mg/m^3^ | DOE 2018b
DOE | Silica gel | 1,200 mg/m^3^ | DOE 2018b

a The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited in food, delisted color additives, and some substances “no longer FEMA GRAS.”

b Group 3: Not classifiable as to its carcinogenicity to humans.

c Group 1: Carcinogenic to humans.

d In addition to limiting exposures, employers must take other steps to protect workers. The construction standard includes specific exposure control methods.

e Potential occupational carcinogen.

f Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018a).

AEGL = acute exposure guideline level; CFR = Code of Federal Regulations; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; mppcf = millions of particles per cubic foot; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; USDA = U.S. Department of Agriculture; WHO = World Health Organization