# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR SILICA

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to silica.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen was conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for silica. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of silica have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of silica are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Health Effects; Species; Human; Laboratory mammals; Route of exposure; Inhalation; Oral; Dermal (or ocular); Parenteral (these studies will be considered supporting data); Health outcome; Death; Systemic effects; Body weight effects; Respiratory effects; Cardiovascular effects; Gastrointestinal effects; Hematological effects; Musculoskeletal effects; Hepatic effects; Renal effects; Dermal effects; Ocular effects; Endocrine effects; Immunological effects; Neurological effects; Reproductive effects; Developmental effects; Other noncancer effects; Cancer
Toxicokinetics; Absorption; Distribution; Metabolism; Excretion; PBPK models; Biomarkers; Biomarkers of exposure; Biomarkers of effect; Interactions with other chemicals; Potential for human exposure; Releases to the environment; Air; Water; Soil; Environmental fate; Transport and partitioning; Transformation and degradation; Environmental monitoring; Air; Water; Sediment and soil; Other media; Biomonitoring; General populations; Occupation populations

### B.1.1 Literature Search

The current literature search was intended to update the draft toxicological profile for silica released for public comment in 2017. The following main databases were searched in January 2018:

- PubMed
- National Library of Medicine’s TOXLINE
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for silica. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to silica were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
01/2018 | ((2014/02/01:3000[dp] OR 2015/02/01:3000[mhda]) AND (((“silicon dioxide”[mh] AND silicosis[mh]) AND (amorphous[tw] OR calcined[tw])) OR ((“silicon dioxide”[mh:noexp]) AND ((“Silicon Dioxide/toxicity”[MeSH Terms] OR “Silicon Dioxide/adverse effects”[MeSH Terms] OR “Silicon Dioxide/poisoning”[MeSH Terms] OR “Silicon Dioxide/pharmacokinetics”[MeSH Terms] OR “Silicon Dioxide/blood”[MeSH Terms] OR “Silicon Dioxide/cerebrospinal fluid”[MeSH Terms] OR “Silicon Dioxide/urine”[MeSH Terms] OR “Silicon Dioxide/antagonists and inhibitors”[MeSH Terms]) OR (“Silicon Dioxide”[MeSH Terms] AND (“chemically induced”[MeSH Subheading] OR “environmental exposure”[MeSH Terms] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Silicon Dioxide”[MeSH Terms] AND (“Computational biology”[mh] OR “Medical Informatics”[mh] OR Genomics[mh] OR Genome[mh] OR Proteomics[mh] OR Proteome[mh] OR Metabolomics[mh] OR Metabolome[mh] OR Genes[mh] OR “Gene expression”[mh] OR Phenotype[mh] OR genetics[mh] OR genotype[mh] OR Transcriptome[mh] OR (“Systems Biology”[mh] AND (“Environmental Exposure”[mh] OR “Epidemiological Monitoring”[mh] OR analysis[sh])) OR “Transcription, Genetic ”[mh] OR “Reverse transcription”[mh] OR “Transcriptional activation”[mh] OR “Transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, Messenger”[mh] OR “RNA, Transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “Reverse Transcriptase Polymerase Chain Reaction”[mh] OR “Base Sequence”[mh] OR “Trans-activators”[mh] OR “Gene Expression Profiling”[mh])) OR (“Silicon Dioxide/metabolism”[MeSH Terms] AND (“humans”[MeSH Terms] OR “animals”[MeSH Terms])) OR (“Silicon Dioxide/pharmacology”[Majr]))) OR (“Quartz/toxicity”[MeSH Terms] OR “Quartz/adverse effects”[MeSH Terms] OR “Quartz/poisoning”[MeSH Terms] OR “Quartz/pharmacokinetics”[MeSH Terms] OR “Quartz/blood”[MeSH Terms] OR “Quartz/cerebrospinal fluid”[MeSH Terms] OR “Quartz/urine”[MeSH Terms] OR “Quartz/antagonists and inhibitors”[MeSH Terms]) OR (“Quartz”[MeSH Terms] AND (“chemically induced”[MeSH Subheading] OR “environmental exposure”[MeSH Terms] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Quartz”[MeSH Terms] AND (“Computational biology”[mh] OR “Medical Informatics”[mh] OR Genomics[mh] OR Genome[mh] OR Proteomics[mh] OR Proteome[mh] OR Metabolomics[mh] OR Metabolome[mh] OR Genes[mh] OR “Gene expression”[mh] OR Phenotype[mh] OR genetics[mh] OR genotype[mh] OR Transcriptome[mh] OR (“Systems Biology”[mh] AND (“Environmental Exposure”[mh] OR “Epidemiological Monitoring”[mh] OR analysis[sh])) OR “Transcription, Genetic ”[mh] OR “Reverse transcription”[mh] OR “Transcriptional activation”[mh] OR “Transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, Messenger”[mh] OR “RNA, Transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “Reverse Transcriptase Polymerase Chain Reaction”[mh] OR “Base Sequence”[mh] OR “Trans-activators”[mh] OR “Gene Expression Profiling”[mh])) OR (“Quartz/metabolism”[MeSH Terms] AND (“humans”[MeSH Terms] OR “animals”[MeSH Terms])) OR (“Quartz/pharmacology”[Majr]) OR (“Diatomaceous earth/toxicity”[MeSH Terms] OR “Diatomaceous earth/adverse effects”[MeSH Terms] OR “Diatomaceous earth/poisoning”[MeSH Terms] OR “Diatomaceous earth/pharmacokinetics”[MeSH Terms] OR “Diatomaceous earth/blood”[MeSH Terms] OR “Diatomaceous earth/cerebrospinal fluid”[MeSH Terms] OR “Diatomaceous earth/urine”[MeSH Terms] OR “Diatomaceous earth/antagonists and inhibitors”[MeSH Terms]) OR (“Diatomaceous earth”[MeSH Terms] AND (“chemically induced”[MeSH Subheading] OR “environmental exposure”[MeSH Terms] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Diatomaceous earth”[MeSH Terms] AND (“Computational biology”[mh] OR “Medical Informatics”[mh] OR Genomics[mh] OR Genome[mh] OR Proteomics[mh] OR Proteome[mh] OR Metabolomics[mh] OR Metabolome[mh] OR Genes[mh] OR “Gene expression”[mh] OR Phenotype[mh] OR genetics[mh] OR genotype[mh] OR Transcriptome[mh] OR (“Systems Biology”[mh] AND (“Environmental Exposure”[mh] OR “Epidemiological Monitoring”[mh] OR analysis[sh])) OR “Transcription, Genetic ”[mh] OR “Reverse transcription”[mh] OR “Transcriptional activation”[mh] OR “Transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, Messenger”[mh] OR “RNA, Transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “Reverse Transcriptase Polymerase Chain Reaction”[mh] OR “Base Sequence”[mh] OR “Trans-activators”[mh] OR “Gene Expression Profiling”[mh])) OR (“Diatomaceous earth/metabolism”[MeSH Terms] AND (“humans”[MeSH Terms] OR “animals”[MeSH Terms])) OR (“Diatomaceous earth/pharmacology”[Majr]) OR (“Silica Gel/toxicity”[MeSH Terms] OR “Silica Gel/adverse effects”[MeSH Terms] OR “Silica Gel/poisoning”[MeSH Terms] OR “Silica Gel/pharmacokinetics”[MeSH Terms] OR “Silica Gel/blood”[MeSH Terms] OR “Silica Gel/cerebrospinal fluid”[MeSH Terms] OR “Silica Gel/urine”[MeSH Terms] OR “Silica Gel/antagonists and inhibitors”[MeSH Terms]) OR (“Silica Gel”[MeSH Terms] AND (“chemically induced”[MeSH Subheading] OR “environmental exposure”[MeSH Terms] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Silica Gel”[MeSH Terms] AND (“Computational biology”[mh] OR “Medical Informatics”[mh] OR Genomics[mh] OR Genome[mh] OR Proteomics[mh] OR Proteome[mh] OR Metabolomics[mh] OR Metabolome[mh] OR Genes[mh] OR “Gene expression”[mh] OR Phenotype[mh] OR genetics[mh] OR genotype[mh] OR Transcriptome[mh] OR (“Systems Biology”[mh] AND (“Environmental Exposure”[mh] OR “Epidemiological Monitoring”[mh] OR analysis[sh])) OR “Transcription, Genetic ”[mh] OR “Reverse transcription”[mh] OR “Transcriptional activation”[mh] OR “Transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, Messenger”[mh] OR “RNA, Transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “Reverse Transcriptase Polymerase Chain Reaction”[mh] OR “Base Sequence”[mh] OR “Trans-activators”[mh] OR “Gene Expression Profiling”[mh])) OR (“Silica Gel/metabolism”[MeSH Terms] AND (“humans”[MeSH Terms] OR “animals”[MeSH Terms])) OR (“Silica Gel/pharmacology”[Majr]) OR (“Beta-Quartz glass-ceramic”[nm]) OR ((“17679-64-0”[tw] OR “Keatite”[tw] OR “13778-38-6”[tw] OR “Coesite”[tw] OR “13778-37-5”[tw] OR “Stishovite”[tw] OR “92283-58-4”[tw] OR “Moganite”[tw] OR “Dioxosilane”[tw] OR “Dioxo-silane”[tw]) AND (to[sh] OR po[sh] OR ae[sh] OR pk[sh] OR (me[sh] AND (“humans”[mh] OR “animals”[mh])) OR ci[sh] OR bl[sh] OR cf[sh] OR ur[sh] OR “environmental exposure”[mh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR ((“Computational biology”[mh] OR “Medical Informatics”[mh] OR Genomics[mh] OR Genome[mh] OR Proteomics[mh] OR Proteome[mh] OR Metabolomics[mh] OR Metabolome[mh] OR Genes[mh] OR “Gene expression”[mh] OR Phenotype[mh] OR genetics[mh] OR genotype[mh] OR Transcriptome[mh] OR (“Systems Biology”[mh] AND (“Environmental Exposure”[mh] OR “Epidemiological Monitoring”[mh] OR analysis[sh])) OR “Transcription, Genetic ”[mh] OR “Reverse transcription”[mh] OR “Transcriptional activation”[mh] OR “Transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, Messenger”[mh] OR “RNA, Transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “Reverse Transcriptase Polymerase Chain Reaction”[mh] OR “Base Sequence”[mh] OR “Trans-activators”[mh] OR “Gene Expression Profiling”[mh])) OR “pharmacology”[Majr] OR silicon dioxide/ai)) OR (“Silicosis/analysis”[Mesh] OR “Silicosis/anatomy and histology”[Mesh] OR “Silicosis/blood”[Mesh] OR “Silicosis/chemically induced”[Mesh] OR “Silicosis/classification”[Mesh] OR “Silicosis/complications”[Mesh] OR “Silicosis/cytology”[Mesh] OR “Silicosis/diagnosis”[Mesh] OR “Silicosis/enzymology”[Mesh] OR “Silicosis/epidemiology”[Mesh] OR “Silicosis/ethnology”[Mesh] OR “Silicosis/etiology”[Mesh] OR “Silicosis/genetics”[Mesh] OR “Silicosis/history”[Mesh] OR “Silicosis/immunology”[Mesh] OR “Silicosis/metabolism”[Mesh] OR “Silicosis/microbiology”[Mesh] OR “Silicosis/mortality”[Mesh] OR “Silicosis/pathology”[Mesh] OR “Silicosis/physiology”[Mesh] OR “Silicosis/physiopathology”[Mesh] OR “Silicosis/prevention and control”[Mesh] OR “Silicosis/psychology”[Mesh] OR “Silicosis/radiography”[Mesh] OR “Silicosis/radionuclide imaging”[Mesh] OR “Silicosis/statistics and numerical data”[Mesh] OR “Silicosis/ultrasonography”[Mesh] OR “Silicosis/urine”[Mesh] OR “Silicosis/veterinary”[Mesh] OR “Silicosis/virology”[Mesh]) OR (“silicosis”[mh] NOT silicosis/*[mh]))) OR ((2014/02/01:3000[dp] OR 2015/02/01:3000[crdat] OR 2015/02/01:3000[edat]) AND (“Accusand”[ti] OR “Aerosil”[ti] OR “Agate”[ti] OR “alpha-Cristobalite”[ti] OR “alpha-Crystobalite”[ti] OR “alpha-Quartz”[ti] OR “alpha-Tridymite”[ti] OR “Amethyst”[ti] OR “beta-Quartz”[ti] OR “Cab-O-sil”[ti] OR “Celatom”[ti] OR “Celite”[ti] OR “Chalcedony”[ti] OR “Cherts”[ti] OR “Chromaton”[ti] OR “Chromosorb G”[ti] OR “Chromosorb P”[ti] OR “Coesite”[ti] OR “Corasil II”[ti] OR “Cristobalit”[ti] OR “Cristobalite”[ti] OR “Cristoballite”[ti] OR “Crystobalite”[ti] OR “Crystoballite”[ti] OR “cuarzo”[ti] OR “Diatomaceous earth”[ti] OR “Diatomite”[ti] OR “Dicalite”[ti] OR “Dioxosilane”[ti] OR “DQ12”[ti] OR “Dri-Die”[ti] OR “Extrelut”[ti] OR “FIBROUS GLASS”[ti] OR “Flint”[ti] OR “Infusorial earth”[ti] OR “Kieselguhr”[ti] OR “Ludox”[ti] OR “Micro-cel”[ti] OR “Min-U-Sil”[ti] OR “Moganite”[ti] OR “Nalcoag”[ti] OR “Neosyl”[ti] OR “Novaculite”[ti] OR “Nyacol”[ti] OR “Porasil”[ti] OR “Quartz”[ti] OR “Quartz-beta”[ti] OR “Quarz”[ti] OR “Siderite”[ti] OR “Sikron F 600”[ti] OR “Silica”[ti] OR “Siliceous earth”[ti] OR “Silicic anhydride”[ti] OR “Silicon dioxide”[ti] OR “Silicon oxide”[ti] OR “Silicone dioxide”[ti] OR “Siloxid”[ti] OR “Siltex”[ti] OR “sio2”[ti] OR “Sipernat”[ti] OR “Snowit”[ti] OR “Spectrosil”[ti] OR “Suprasil”[ti] OR “Tridimite”[ti] OR “Tridymit”[ti] OR “Tridymite”[ti] OR (“Tripoli”[ti] NOT (“libya”[tw] OR “lebanon”[tw])) OR “Zipax”[ti] OR “Zorbax sil”[ti] OR “a-Cristobalite”[ti] OR “a-Crystobalite”[ti] OR “a-Quartz”[ti]) NOT medline[sb])); “Acticel”[tw] OR “Admafine SO 25H”[tw] OR “Admafine SO 25R”[tw] OR “Admafine SO 32H”[tw] OR “Admafine SO-C 2”[tw] OR “Admafine SO-C 3”[tw] OR “Aerogel 200”[tw] OR “AF-SO 25R”[tw] OR “Aquafil”[tw] OR “Armsorb GKhI”[tw] OR “As 1 (silica)”[tw] OR “Belcron B 6000”[tw] OR “BF 100”[tw] OR “Borsil P”[tw] OR “Cab-O-grip II”[tw] OR “Cab-O-sperse”[tw] OR “Cabosil N 5”[tw] OR “Cabosil st-1”[tw] OR “Calofrig FJ”[tw] OR “Carplex”[tw] OR “Cataloid”[tw] OR “Christensenite”[tw] OR “Chromatron N Super”[tw] OR “Corning 7940”[tw] OR “CP-SilicaPLOT”[tw] OR “cristobalita”[tw] OR “CRS 1101-17”[tw] OR “CRS 1102RD8”[tw] OR “Crystalite 5K”[tw] OR “Crystalite A 1”[tw] OR “Crystalite A 2”[tw] OR “Crystalite AA”[tw] OR “Crystalite C”[tw] OR “Crystalite CRS”[tw] OR “Crystalite SS”[tw] OR “Crystalite VX-S”[tw] OR “Crystalite VX-SR”[tw] OR “Crystalite VX-X”[tw] OR “Crysvarl”[tw] OR “Denka F 90”[tw] OR “Denka FB 30”[tw] OR “Denka FB 44”[tw] OR “Denka FB 74”[tw] OR “Denka FS 30”[tw] OR “Elsil 100”[tw] OR “Elsil BF 100”[tw] OR “ENT 25,550”[tw] OR “EQ 912”[tw] OR “Extrusil”[tw] OR “Flintshot”[tw] OR “Fossil flour”[tw] OR “Fuselex”[tw] OR “Gold bond R”[tw] OR “GP 11I”[tw] OR “GP 7I”[tw] OR “HK 400”[tw] OR “Inducarb 0.5-1”[tw] OR “Keatite (SiO2)”[tw] OR “Manosil vn 3”[tw] OR “Marshalite”[tw] OR “Metacristobalite”[tw] OR “Mikrosil LM 300”[tw] OR “Mikrosil SP 10”[tw] OR “Mikrosil SP 3”[tw] OR “Millisil W 12”[tw] OR “Millisil W 3”[tw] OR “Millisil W 6”[tw] OR “Millisil W 6EST”[tw] OR “N1030”[tw] OR “Nalcast”[tw] OR “Nalco 1050”[tw] OR “Nalfloc N 1050”[tw] OR “Neosil”[tw] OR “Optocil”[tw] OR “Pigment White 27”[tw] OR “Plastorit”[tw] OR “Positive sol 130M”[tw] OR “Positive sol 232”[tw] OR “QG 100”[tw] OR “Quso 51”[tw] OR “Quso G 30”[tw] OR “Rancosil”[tw] OR “Randanite”[tw] OR “Rock crystal”[tw] OR “Santocel”[tw] OR “Sg-67”[tw] OR “Sibelco B 0012”[tw] OR “Sibelco M 10”[tw] OR “Sibelite M 3000”[tw] OR “Sibelite M 4000”[tw] OR “Sibelite M 6000”[tw] OR “Sicron F 300”[tw] OR “Sifraco C 10”[tw] OR “Sifraco C 600”[tw] OR “Sihelco B 2500”[tw] OR “Sikron 3000”[tw] OR “Sikron F 100”[tw] OR “Sikron H 200”[tw] OR “Sikron H 500”[tw] OR “Sikron H 600”[tw] OR “Sikron SF 300”[tw] OR “Sikron SF 500”[tw] OR “Sikron SF 600”[tw] OR “Sikron SF 6000”[tw] OR “Sikron SF 800”[tw] OR “Sil-Co-Sil”[tw] OR “Silane, dioxo-”[tw] OR “Silanox 101”[tw] OR “Silbond 006MST”[tw] OR “Silbond 3000MST”[tw] OR “Silbond 600EST”[tw] OR “Silbond FW 600EST”[tw] OR “Silbond FW 61EST”[tw] OR “Silbond VP 810-10/1EST”[tw] OR “Silcron F 600”[tw] OR “Silikil”[tw] OR “Silikill”[tw] OR “Sillikolloid”[tw] OR “Silver bond B”[tw] OR “Silverbond 200”[tw] OR “Silverbond 325”[tw] OR “Snowtex 30”[tw] OR “Snowtex O”[tw] OR “Stishovite (SiO2)”[tw] OR “Syton 2X”[tw] OR “TGL 16319”[tw] OR “Tokusil TPLM”[tw] OR “tridimita”[tw] OR “Ultrasil VH 3”[tw] OR “Ultrasil VN 3”[tw] OR “Vitasil 220”[tw] OR “Vitreosil IR”[tw] OR “Vulkasil”[tw] OR “W 006”[tw] OR “Wessalon”[tw] OR “WGL 300”[tw] OR “Zeofree 80”[tw]
Toxline
01/2018 | ( 7631-86-9 [rn] OR 14808-60-7 [rn] OR 61790-53-2 [rn] OR 68855-54-9 [rn] OR 99439-28-8 [rn] OR 14464-46-1 [rn] OR 1317-95-9 [rn] OR 15468-32-3 [rn] OR 112945-52-5 [rn] OR 112926-00-8 [rn] OR 60676-86-0 [rn] OR 17679-64-0 [rn] OR 13778-38-6 [rn] OR 13778-37-5 [rn] OR 92283-58-4 [rn] ) AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]; ( “accusand” OR “aerosil” OR “agate” OR “alpha cristobalite” OR “alpha crystobalite” OR “alpha quartz” OR “alpha tridymite” OR “beta quartz” OR “cab o sil” OR “celatom” OR “celite” OR “chalcedony” OR “cherts” OR “chromaton” OR “chromosorb g” OR “chromosorb p” OR “coesite” OR “corasil ii” OR “cristobalit” OR “cristobalite” OR “cristoballite” OR “crystobalite” OR “crystoballite” OR “cuarzo” OR “diatomaceous earth” OR “diatomaceous silica” OR “diatomite” OR “dicalite” OR “dioxosilane” OR “dq12” OR “dri die” OR “extrelut” OR “fibrous glass” OR “flint” OR “infusorial earth” OR “kieselguhr” ) AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org]) AND NOT PubMed [org] AND NOT pubdart [org]; ( “acticel” OR “admafine so 25h” OR “admafine so 25r” OR “admafine so 32h” OR “admafine so c 2” OR “admafine so c 3” OR “aerogel 200” OR “af so 25r” OR “aquafil” OR “armsorb gkhi” OR “as 1 ( silica ) ” OR “belcron b 6000” OR “bf 100” OR “borsil p” OR “cab o grip ii” OR “cab o sperse” OR “cabosil n 5” OR “cabosil st 1” OR “calofrig fj” OR “carplex” OR “cataloid” OR “christensenite” OR “chromatron n super” OR “corning 7940” OR “cp silicaplot” OR “cristobalita” OR “crs 1101 17” OR “crs 1102rd8” OR “crystalite 5k” OR “crystalite a 1” OR “crystalite a 2” OR “crystalite aa” OR “crystalite c” OR “crystalite crs” OR “crystalite ss” OR “crystalite vx s” OR “crystalite vx sr” OR “crystalite vx x” OR “crysvarl” ) AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ); ( “denka f 90” OR “denka fb 30” OR “denka fb 44” OR “denka fb 74” OR “denka fs 30” OR “elsil 100” OR “elsil bf 100” OR “ent 25 550” OR “eq 912” OR “extrusil” OR “flintshot” OR “fossil flour” OR “fuselex” OR “gold bond r” OR “gp 11i” OR “gp 7i” OR “hk 400” OR “inducarb 0 5 1” OR “keatite ( sio2 ) ” OR “manosil vn 3” OR “marshalite” OR “metacristobalite” OR “mikrosil lm 300” OR “mikrosil sp 10” OR “mikrosil sp 3” OR “millisil w 12” OR “millisil w 3” OR “millisil w 6” OR “millisil w 6est” OR “Moganite” OR “n1030” OR “nalcast” OR “nalco 1050” OR “nalfloc n 1050” OR “neosil” OR “optocil” OR “pigment white 27” OR “plastorit” OR “positive sol 130m” OR “positive sol 232” OR “qg 100” OR “quso 51” OR “quso g 30” ) AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]; ( “ludox” OR “micro cel” OR “min u sil” OR “nalcoag” OR “neosyl” OR “novaculite” OR “nyacol” OR “porasil” OR “quartz” OR “quartz beta” OR “quarz” OR “siderite” OR “sikron f 600” OR “silica” OR “siliceous earth” OR “silicic anhydride” OR “silicon dioxide” OR “silicon oxide” OR “silicone dioxide” OR “siloxid” OR “siltex” OR “sipernat” OR “snowit” OR “spectrosil” OR “suprasil” OR “tridimite” OR “tridymit” OR “tridymite” OR “tripoli” OR “zipax” OR “zorbax sil” OR “a cristobalite” OR “a crystobalite” OR “a quartz” ) AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]; ( “rancosil” OR “randanite” OR “rock crystal” OR “santocel” OR “sg 67” OR “sibelco b 0012” OR “sibelco m 10” OR “sibelite m 3000” OR “sibelite m 4000” OR “sibelite m 6000” OR “sicron f 300” OR “sifraco c 10” OR “sifraco c 600” OR “sihelco b 2500” OR “sikron 3000” OR “sikron f 100” OR “sikron h 200” OR “sikron h 500” OR “sikron h 600” OR “sikron sf 300” OR “sikron sf 500” OR “sikron sf 600” OR “sikron sf 6000” OR “sikron sf 800” OR “sil co sil” OR “silane dioxo ” OR “silanox 101” OR “silbond 006mst” OR “silbond 3000mst” OR “silbond 600est” OR “silbond fw 600est” OR “silbond fw 61est” OR “silbond vp 810 10 1est” OR “silcron f 600” OR “silikil” OR “silikill” OR “sillikolloid” OR “silver bond b” OR “silverbond 200” OR “silverbond 325” OR “snowtex 30” OR “snowtex o” OR “stishovite ( sio2 ) ” OR “syton 2x” OR “tgl 16319” OR “tokusil tplm” OR “tridimita” OR “ultrasil vh 3” OR “ultrasil vn 3” OR “vitasil 220” OR “vitreosil ir” OR “vulkasil” OR “w 006” OR “wessalon” OR “wgl 300” OR “zeofree 80” ) AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]
Toxcenter
01/2018 | => d hist full; (FILE ‘HOME’ ENTERED AT 12:14:48 ON 18 JAN 2018); FILE ‘TOXCENTER’ ENTERED AT 12:16:10 ON 18 JAN 2018; CHARGED TO COST=EH011.05.LB.02.05; L1 101729 SEA 7631-86-9 OR 14808-60-7 OR 61790-53-2 OR 68855-54-9 OR 99439-28-8 OR 14464-46-1 OR 1317-95-9 OR 15468-32-3 OR 112945-52-5 OR 112926-00-8 OR 60676-86-0 OR 17679-64-0 OR 13778-38-6 OR 13778-37-5 OR 92283-58-4; L2 11170 SEA SILICOSIS/TI,CT,ST,IT; L3 110260 SEA L1 OR L2; L4 66684 SEA L3 NOT (PATENT/DT OR TSCATS/FS); L5 12750 SEA L4 AND PY>=2014; ACT TOXQUERY/Q; -------; L6 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L7 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L8 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L9 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L10 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L11 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L12 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L13 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L14 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L15 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L16 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L17 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L18 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L19 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L20 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L21 QUE (ENDOCRIN? AND DISRUPT?); L22 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L23 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L24 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L25 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L26 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L27 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L28 QUE (NEPHROTOX? OR HEPATOTOX?); L29 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L30 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L31 QUE L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30; L32 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L33 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L34 QUE L31 OR L32 OR L33; L35 QUE (NONHUMAN MAMMALS)/ORGN; L36 QUE L34 OR L35; L37 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L38 QUE L36 OR L37; -------; L39 5004 SEA L5 AND L36; L40 1410 SEA L39 AND MEDLINE/FS; L41 453 SEA L39 AND BIOSIS/FS; L42 3124 SEA L39 AND CAPLUS/FS; L43 17 SEA L39 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L44 4295 DUP REM L40 L41 L43 L42 (709 DUPLICATES REMOVED); L*** DEL 1410 S L39 AND MEDLINE/FS; L*** DEL 1410 S L39 AND MEDLINE/FS; L45 1410 SEA L44; L*** DEL 453 S L39 AND BIOSIS/FS; L*** DEL 453 S L39 AND BIOSIS/FS; L46 270 SEA L44; L*** DEL 3124 S L39 AND CAPLUS/FS; L*** DEL 3124 S L39 AND CAPLUS/FS; L47 2601 SEA L44; L*** DEL 17 S L39 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L*** DEL 17 S L39 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L48 14 SEA L44; L49 2885 SEA (L45 OR L46 OR L47 OR L48) NOT MEDLINE/FS D SCAN L49

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS ^a^
02/2019 | Compounds searched: 7631-86-9; 14808-60-7; 99439-28-8; 14464-46-1; 1317-95-9; 15468-32-3; 112945-52-5; 112926-00-8; 61790-53-2; 60676-86-0; 68855-54-9; 17679-64-0; 13778-38-6; 13778-37-5; 92283-58-4
NTP
01/2018 | “7631-86-9” OR “14808-60-7” OR “61790-53-2” OR “68855-54-9” OR “99439-28-8” OR “14464-46-1” OR “1317-95-9” OR “15468-32-3” OR “112945-52-5” OR “112926-00-8” OR “60676-86-0” OR “17679-64-0” OR “13778-38-6” OR “13778-37-5” OR “92283-58-4”; “Accusand” OR “Aerosil” OR “Agate” OR “alpha-Cristobalite” OR “alpha-Crystobalite” OR “alpha-Quartz” OR “alpha-Tridymite” OR “beta-Quartz” OR “Cab-O-sil” OR “Celatom” OR “Celite” OR “Chalcedony” OR “Cherts” OR “Chromaton” OR “Chromosorb G” OR “Chromosorb P” OR “Coesite” OR “Corasil II” OR “Cristobalit” OR “Cristobalite” OR “Cristoballite” OR “Crystobalite” OR “Crystoballite” OR “cuarzo” OR “Diatomaceous earth” OR “Diatomaceous silica” OR “Diatomite” OR “Dicalite” OR “Dioxosilane” OR “DQ12” OR “Dri-Die” OR “Extrelut” OR “FIBROUS GLASS” OR “Flint” OR “Infusorial earth” OR “Kieselguhr” OR “Ludox” OR “Micro-cel” OR “Min-U-Sil” OR “Moganite” OR “Nalcoag” OR “Neosyl” OR “Novaculite” OR “Nyacol” OR “Porasil” OR “Quartz” OR “Quartz-beta” OR “Quarz” OR “Siderite” OR “Sikron F 600” OR “Silica” OR “Siliceous earth” OR “Silicic anhydride” OR “Silicon dioxide” OR “Silicon oxide” OR “Silicone dioxide” OR “Siloxid” OR “Siltex” OR “Sipernat” OR “Snowit” OR “Spectrosil” OR “Suprasil” OR “Tridimite” OR “Tridymit” OR “Tridymite” OR “Tripoli” OR “Zipax” OR “Zorbax sil” OR “a-Cristobalite” OR “a-Crystobalite” OR “a-Quartz”
regulations.gov
02/2019 | Compounds searched: 7631-86-9; 14808-60-7; 99439-28-8; 14464-46-1; 1317-95-9; 15468-32-3; 112945-52-5; 112926-00-8; 61790-53-2; 60676-86-0; 68855-54-9; 17679-64-0; 13778-38-6; 13778-37-5; 92283-58-4
NIH RePORTER
02/2019 | Active projects: “Accusand” OR “Aerosil” OR “Agate” OR “alpha-Cristobalite” OR “alpha-Crystobalite” OR “alpha-Quartz” OR “alpha-Tridymite” OR “Amethyst” OR “beta-Quartz” OR “Cab-O-sil” OR “Celatom” OR “Celite” OR “Chalcedony” OR “Cherts” OR “Chromaton” OR “Chromosorb G” OR “Chromosorb P” OR “Coesite” OR “Corasil II” OR “Cristobalit” OR “Cristobalite” OR “Cristoballite” OR “Crystobalite” OR “Crystoballite” OR “cuarzo” OR “Diatomaceous earth” OR “Diatomite” OR “Dicalite” OR “Dioxosilane” OR “DQ12” OR “Dri-Die” OR “Extrelut” OR “FIBROUS GLASS” OR “Flint” OR “Infusorial earth” OR “Kieselguhr” OR “Ludox” OR “Micro-cel” OR “Min-U-Sil” OR “Moganite” OR “Nalcoag” OR “Neosyl” OR “Novaculite” OR “Nyacol” OR “Porasil” OR “Quartz” OR “Quartz-beta” OR “Quarz” OR “Siderite” OR “Sikron F 600” OR “Silica” OR “Siliceous earth” OR “Silicic anhydride” OR “Silicon dioxide” OR “Silicon oxide” OR “Silicone dioxide” OR “Siloxid” OR “Siltex” OR “sio2” OR “Sipernat” OR “Snowit” OR “Spectrosil” OR “Suprasil” OR “Tridimite” OR “Tridymit” OR “Tridymite” OR “Zipax” OR “Zorbax sil” OR “a-Cristobalite” OR “a-Crystobalite” OR “a-Quartz”; Active projects: “Acticel” OR “Admafine SO 25H” OR “Admafine SO 25R” OR “Admafine SO 32H” OR “Admafine SO-C 2” OR “Admafine SO-C 3” OR “Aerogel 200” OR “AF-SO 25R” OR “Aquafil” OR “Armsorb GKhI” OR “As 1 (silica)” OR “Belcron B 6000” OR “BF 100” OR “Borsil P” OR “Cab-O-grip II” OR “Cab-O-sperse” OR “Cabosil N 5” OR “Cabosil st-1” OR “Calofrig FJ” OR “Carplex” OR “Cataloid” OR “Christensenite” OR “Chromatron N Super” OR “Corning 7940” OR “CP-SilicaPLOT” OR “cristobalita” OR “CRS 1101-17” OR “CRS 1102RD8” OR “Crystalite 5K” OR “Crystalite A 1” OR “Crystalite A 2” OR “Crystalite AA” OR “Crystalite C” OR “Crystalite CRS” OR “Crystalite SS” OR “Crystalite VX-S” OR “Crystalite VX-SR” OR “Crystalite VX-X” OR “Crysvarl” OR “Denka F 90” OR “Denka FB 30” OR “Denka FB 44” OR “Denka FB 74” OR “Denka FS 30” OR “Elsil 100” OR “Elsil BF 100” OR “ENT 25,550” OR “EQ 912” OR “Extrusil” OR “Flintshot” OR “Fossil flour” OR “Fuselex” OR “Gold bond R” OR “GP 11I” OR “GP 7I” OR “HK 400” OR “Inducarb 0.5-1” OR “Keatite (SiO2)” OR “Manosil vn 3” OR “Marshalite” OR “Metacristobalite” OR “Mikrosil LM 300” OR “Mikrosil SP 10” OR “Mikrosil SP 3” OR “Millisil W 12” OR “Millisil W 3” OR “Millisil W 6” OR “Millisil W 6EST” OR “N1030” OR “Nalcast” OR “Nalco 1050” OR “Nalfloc N 1050” OR “Neosil” OR “Optocil” OR “Pigment White 27” OR “Plastorit” OR “Positive sol 130M” OR “Positive sol 232” OR “QG 100” OR “Quso 51” OR “Quso G 30” OR “Rancosil” OR “Randanite” OR “Rock crystal” OR “Santocel” OR “Sg-67” OR “Sibelco B 0012” OR “Sibelco M 10” OR “Sibelite M 3000” OR “Sibelite M 4000” OR “Sibelite M 6000” OR “Sicron F 300” OR “Sifraco C 10” OR “Sifraco C 600” OR “Sihelco B 2500” OR “Sikron 3000” OR “Sikron F 100” OR “Sikron H 200” OR “Sikron H 500” OR “Sikron H 600” OR “Sikron SF 300” OR “Sikron SF 500” OR “Sikron SF 600” OR “Sikron SF 6000” OR “Sikron SF 800” OR “Sil-Co-Sil” OR “Silane, dioxo-” OR “Silanox 101” OR “Silbond 006MST” OR “Silbond 3000MST” OR “Silbond 600EST” OR “Silbond FW 600EST” OR “Silbond FW 61EST” OR “Silbond VP 810-10/1EST” OR “Silcron F 600” OR “Silikil” OR “Silikill” OR “Sillikolloid” OR “Silver bond B” OR “Silverbond 200” OR “Silverbond 325” OR “Snowtex 30” OR “Snowtex O” OR “Stishovite (SiO2)” OR “Syton 2X” OR “TGL 16319” OR “Tokusil TPLM” OR “tridimita” OR “Ultrasil VH 3” OR “Ultrasil VN 3” OR “Vitasil 220” OR “Vitreosil IR” OR “Vulkasil” OR “W 006” OR “Wessalon” OR “WGL 300” OR “Zeofree 80”
Other | Identified throughout the assessment process

a Several versions of the TSCATS database were searched, as needed, by CASRN including TSCATS1 via Toxline (no date limit), TSCATS2 via https://yosemite.epa.gov/oppts/epatscat8.nsf/ReportSearch?OpenForm (date restricted by EPA receipt date), and TSCATS via CDAT (date restricted by ‘Mail Received Date Range’), as well as google for recent TSCA submissions.

The 2018 results were:

- Number of records identified from PubMed, TOXLINE, and TOXCENTER (after duplicate removal): 6,522
- Number of records identified from other strategies: 103
- Total number of records to undergo literature screening: 6,625

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on silica:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 6,625
- Number of studies considered relevant and moved to the next step: 169

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 169
- Number of studies cited from the search results of the pre-public draft of the toxicological profile: 459
- Total number of studies cited in the profile: 543

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 January 2018 Literature Search Results and Screen for Silica

Figure B-1. January Literature Search Results and Screen for Silica