# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

## Crystalline silica (c-silica) Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Crystalline silica (c-silica)
CAS Numbers: | Various
Date: | September 2019
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for c-silica.

Rationale for Not Deriving an MRL: No adverse effects or critical targets have been associated with acute-duration exposure to inhaled c-silica. Therefore, an acute-duration inhalation MRL for c-silica was not derived.

Agency Contacts (Chemical Managers): Malcolm Williams

## Crystalline silica (c-silica) Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Crystalline silica (c-silica)
CAS Numbers: | Various
Date: | September 2019
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for c-silica.

Rationale for Not Deriving an MRL: Silicosis has been observed in workers exposed to “intense exposure” of fine c-silica dusts, such as those generated during sandblasting and denim sand blasting, for intermediate durations. However, no estimates of quantitative exposure data has been defined for “intense exposure.” Furthermore, silicosis is a serious adverse effect that has the potential to cause death due to respiratory failure or lung cancer. Consistent with ATSDR’s practice, LOAELs for serious health effects are not used as a basis for establishing MRLs. Therefore, an intermediate-duration inhalation MRL for c-silica was not derived.

Agency Contacts (Chemical Managers): Malcolm Williams

## Crystalline silica (c-silica) Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Crystalline silica (c-silica)
CAS Numbers: | Various
Date: | September 2019
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for c-silica.

Rationale for Not Deriving an MRL: Silicosis is the most sensitive effect of chronic-duration inhalation exposure to c-silica (see results of numerous studies summarized in Section 2.4). However, no NOAEL or threshold level for silicosis have been identified. In occupational studies, silicosis was observed for the lowest reported cumulative exposure range of 0–0.2 mg/m^3^-year (Steenland and Brown 1995a). Although several studies have identified LOAEL values for silicosis, silicosis is a serious adverse effect that has the potential to cause death due to respiratory failure or lung cancer. Consistent with ATSDR’s practice, LOAELs for serious health effects are not used as a basis for establishing MRLs. Given the serious nature of silicosis, a chronic-duration inhalation MRL for c-silica was not derived.

Agency Contacts (Chemical Managers): Malcolm Williams

## Crystalline silica (c-silica) Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Crystalline silica (c-silica)
CAS Numbers: | Various
Date: | September 2019
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for c-silica.

Rationale for Not Deriving an MRL: Few studies on acute oral exposure to c-silica were identified and the available studies in laboratory animals do not identify critical effects (Oner et al. 2005, 2006). Given the ubiquitous nature of c-silica in the environment, it is assumed that incidental oral exposure of humans commonly occurs. No reports of adverse effects associated with incidental oral exposure to c-silica in the environment were identified. An acute-duration oral MRL for c-silica was not derived due to the lack of data identifying sensitive targets of the toxicity and the lack of dose-response data.

Agency Contacts (Chemical Managers): Malcolm Williams

## Crystalline silica (c-silica) Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Crystalline silica (c-silica)
CAS Numbers: | Various
Date: | September 2019
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL for c-silica.

Rationale for Not Deriving an MRL: Only one intermediate-duration oral exposure study on c-silica was identified (Dobbie and Smith 1982), and this study did not identify any critical effects associated with intermediate oral exposure. Given the ubiquitous nature of c-silica in the environment, it is assumed that incidental oral exposure of humans commonly occurs. No reports of adverse effects associated with incidental oral exposure to c-silica in the environment were identified. Therefore, an intermediate-duration oral MRL for c-silica was not derived.

Agency Contacts (Chemical Managers): Malcolm Williams

## Crystalline silica (c-silica) Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Crystalline silica (c-silica)
CAS Numbers: | Various
Date: | September 2019
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for c-silica.

Rationale for Not Deriving an MRL: Two epidemiological studies evaluating effects of oral silica in drinking water on cognitive function did not find decreased cognitive function (Gillette-Guyonnet et al. 2005; Jacqmin-Gadda et al. 1996). However, these studies did not report the identity of the silica compound in water (e.g., c-silica or a-silica). No chronic-duration oral exposure studies on c-silica in animals were identified. Given the ubiquitous nature of c-silica in the environment, it is assumed that incidental oral exposure of humans commonly occurs. No reports of adverse effects associated with incidental oral exposure to c-silica in the environment were identified. The lack of toxicity data precludes derivation of a chronic-duration oral MRL for c-silica.

Agency Contacts (Chemical Managers): Malcolm Williams

## Amorphous silica (a-silica) Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Amorphous silica (a-silica)
CAS Numbers: | Various
Date: | September 2019
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for a-silica.

Rationale for Not Deriving an MRL: Results of the animal studies provide evidence that toxicological potency for respiratory effects can differ between different a-silica polymorphs (Arts et al. 2007; ECHA 2019; Johnson et al. 2000; Lee and Reuzel et al. 1991; Reuzel et al. 1991; Schepers et al. 1957b; Warheit et al. 1991, 1995). For example, serious respiratory distress and inflammation were observed in rats exposed to 17 mg/m^3^ of fumed hydrophilic silica (Aerosil 200) for 6 hours/day, 5 days/week for 2 weeks (Reuzel et al. 1991), whereas under the same exposure conditions, the only adverse respiratory effect observed for colloidal silica (Ludox) was an increase in neutrophils in bronchoalveolar lavage fluid at 50.5 mg/m^3^ (Warheit et al. 1991, 1995). Given the potentially important role of surface chemistry characteristics in the toxicological potency of silica compounds, there is considerable uncertainty regarding identification of NOAEL or LOAEL values that could serve as the basis of development of inhalation MRLs, as values based on a single a-silica polymorph may not apply to all forms of a-silica. Therefore, an acute-duration inhalation MRL for a-silica was not derived.

Agency Contacts (Chemical Managers): Malcolm Williams

## Amorphous silica (a-silica) Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Amorphous silica (a-silica)
CAS Numbers: | Various
Date: | September 2019
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for a-silica.

Rationale for Not Deriving an MRL: Results of the animal studies provide evidence that toxicological potency for respiratory effects can differ between different a-silica polymorphs (ECHA 20019; Johnson et al. 2000; Lee and Kelly 1992; Reuzel et al. 1991; Rosenbrunch 1992; Warheit et al. 1991, 1995; Schepers et al. 1957a,b,c; Tebbens et al. 1957; Warheit et al. 1991, 1995). For example, serious respiratory inflammation and fibrosis were observed in rats exposed to 1 mg/m^3^ of pyrogenic hydrophilic silica (Aerosil 200) for 6 hours/day, 5 days/week for 13 weeks (Reuzel et al. 1991), whereas under the same exposure conditions, the only adverse respiratory effect observed for colloidal silica (Ludox) was an increase in neutrophils in bronchoalveolar lavage fluid at 50.5 mg/m^3^ (Warheit et al. 1991, 1995). Given the potentially important role of surface chemistry characteristics in the toxicological potency of silica compounds, there is considerable uncertainty regarding identification of NOAEL or LOAEL values that could serve as the basis of development of inhalation MRLs, as values based on a single a-silica polymorph may not apply to all forms of a-silica. Therefore, an intermediate-duration inhalation MRL for a-silica was not derived.

Agency Contacts (Chemical Managers): Malcolm Williams

## Amorphous silica (a-silica) Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Amorphous silica (a-silica)
CAS Numbers: | Various
Date: | September 2019
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for a-silica.

Rationale for Not Deriving an MRL: As discussed above for the acute- and chronic-duration inhalation MRLs for a-silica, results of the animal studies provide evidence that toxicological potency for respiratory effects can differ between different a-silica polymorphs. However, available chronic-duration inhalation studies in animals do not provide sufficient information to determine if the toxicological potency for respiratory effects can differ between different a-silica polymorphs. Studies have reported NOAEL values for respiratory effects of 6.9–15 mg/m^3^ (Groth et al. 1981; Schepers 1962); however, these studies did not examine effects of higher exposures. In a series of studies conducted by Schepers (1981), adverse respiratory effects were observed at 126 mg/m^3^; however, lower exposures were not evaluated. Given the potentially important role of surface chemistry characteristics in the toxicological potency of silica compounds, there is considerable uncertainty regarding identification of NOAEL or LOAEL values that could serve as the basis of development of inhalation MRLs, as values based on a single a-silica polymorph may not apply to all forms of a-silica. Therefore, a chronic-duration inhalation MRL for a-silica was not derived.

Agency Contacts (Chemical Managers): Malcolm Williams

## Amorphous silica (a-silica) Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Amorphous silica (a-silica)
CAS Numbers: | Various
Date: | September 2019
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for a-silica.

Rationale for Not Deriving an MRL: Published and unpublished studies have evaluated the effects of acute-duration oral exposure of animals to a-silica (ECHA 2016; Lewison et al. 1994). These studies, which examined numerous toxicological endpoints, have not identified critical effects associated with acute-duration oral exposure. Therefore, an acute-duration oral MRL for a-silica was not derived.

Agency Contacts (Chemical Managers): Malcolm Williams

## Amorphous silica (a-silica) Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Amorphous silica (a-silica)
CAS Numbers: | Various
Date: | September 2019
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL for a-silica.

Rationale for Not Deriving an MRL: Published and unpublished studies have evaluated the effects of intermediate-duration oral exposure of animals to a-silica (ECHA 2019; Lewison et al. 1994; Newberne and Wilson 2970; Takizawa et al. 1988; Woterbeek et al. 2015). These studies, which examined numerous toxicological endpoints, have not identified critical effects associated intermediate-duration oral exposure. Therefore, an intermediate-duration oral MRL for a-silica was not derived.

Agency Contacts (Chemical Managers): Malcolm Williams

## Amorphous silica (a-silica) Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Amorphous silica (a-silica)
CAS Numbers: | Various
Date: | September 2019
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for a-silica.

Rationale for Not Deriving an MRL: Few published and unpublished animal studies have evaluated the effects of chronic-duration oral exposure of animals to a-silica (ECHA 2019; Takizawa et al. 1988). These studies, which examined numerous toxicological endpoints, have not identified critical effects associated chronic-duration oral exposure. Therefore, a chronic-duration oral MRL for a-silica was not derived.

Agency Contacts (Chemical Managers): Malcolm Williams