# 8 REGULATIONS AND ADVISORIES

Because of its potential to cause adverse health effects in exposed people, a number of regulations and guidelines have been established for selenium by various national and state agencies. These values are summarized in Table 8-1.

The current Recommended Dietary Allowances (RDAs) for selenium, established by the Food and Nutrition Board of the National Research Council (National Academy of Sciences) (NAS 2000), are listed below. The recommended Tolerable Upper Intake Level (UL) for selenium in adults is 0.4 mg/day (NAS 2000). The UL is defined as the highest level of daily nutrient intake that is likely to pose no risk of adverse health effects to almost all individuals in the general population.

- Men: 0.055 mg/day
- Women: 0.055 mg/day
- Pregnant women: 0.060 mg/day
- Lactating women: 0.070 mg/day
- Infants (0–6 months): 0.015 mg/day
- Infants (7–12 months): 0.020 mg/day
- Children (1–3 years): 0.020 mg/day
- Children (4–8 years): 0.030 mg/day
- Children (9–18 years): 0.040 mg/day

A chronic oral MRL of 0.005 mg/kg/day was derived for selenium based on a NOAEL of 0.015 mg/kg/day for disappearance of symptoms of selenosis in recovering individuals (Yang and Zhou 1994), as discussed in Section 2.3. The NOAEL was divided by an uncertainty factor of three to account for sensitive individuals. The EPA used the same human NOAEL for clinical selenosis (0.015 mg/kg/day) (Yang et al. 1989a, 1989b) and an uncertainty factor of three to derive a chronic oral reference dose (RfD) of 0.005 mg/kg/day for selenium (EPA 2003).

Table 8-1 Regulations and Guidelines Applicable to Selenium

Agency | | Description | Information | References
INTERNATIONAL
Guidelines:
| IARC | Carcinogenicity classification | Group 3^a^ | IARC 2001
| WHO | Guideline for drinking water | 0.01 mg/L | WHO 2001
| WHO | Recommended daily intake for adults | 0.9 µg/kg body weight
NATIONAL
Regulations and Guidelines:
a. | Air
a. | ACGIH | TLV (8-hour TWA) | | ACGIH 2000
a. | ACGIH | Selenium and compounds | 0.2 mg/m^3^ | ACGIH 2000
a. | ACGIH | Selenium hexafluoride | 0.16 mg/m^3^ | ACGIH 2000
a. | EPA | Hazard rank under Section 112(g) of the Clean Air Act Amendments | 42 out of 1–100, with 100 being the most toxic | EPA 2001a
a. | EPA | Reference air concentration | 3.0 µg/m^3^ | EPA 2001b; 40CFR 266, Appendix IV
a. | NIOSH | REL (TWA) | | NIOSH 2001
a. | NIOSH | Selenium and compounds, except selenium hexafluoride | 0.2 mg/m^3^ | NIOSH 2001
a. | NIOSH | IDLH
a. | NIOSH | Selenium and compounds | 1.0 mg/m^3^
a. | OSHA | General industry PEL (TWA) | | OSHA 2001; 29CFR1910.1000, Table Z
a. | OSHA | Selenium and compounds | 0.2 mg/m^3^ | OSHA 2001; 29CFR1910.1000, Table Z
a. | OSHA | Selenium hexafluoride | 0.4 mg/m^3^ | OSHA 2001; 29CFR1910.1000, Table Z
a. | OSHA | Hydrogen selenide | 0.2 mg/m^3^ | OSHA 2001; 29CFR1910.1000, Table Z
a. | OSHA | Construction industry PEL (TWA) | | OSHA 2001
a. | OSHA | Selenium and compounds | 0.2 mg/m^3^ | OSHA 2001
a. | OSHA | Selenium hexafluoride | 0.16 mg/m^3^ | OSHA 2001
b. | Water
b. | EPA | MCLG | 0.05 mg/L | EPA 2001c; 40CFR141.51
b. | EPA | MCL | 0.05 mg/L | EPA 2001d; 40CFR141.62
b. | EPA | DWEL | 0.2 mg/L | EPA 2000
b. | EPA | Health advisory—lifetime | 0.05 mg/L
b. | EPA | Groundwater monitoring (PQL) | 750 µg/L | EPA 2001e; 40CFR264, Appendix IX
b. | EPA | Groundwater monitoring—concentration limits | 0.01 mg/L | EPA 2001f; 40CFR264.94
b. | EPA | Water quality standards | | EPA 2001g; 40CFR131.36
b. | EPA | Freshwater | | EPA 2001g; 40CFR131.36
b. | EPA | Maximum concentration | 20 µg/L | EPA 2001g; 40CFR131.36
b. | EPA | Continuous concentration | 5.0 µg/L | EPA 2001g; 40CFR131.36
b. | EPA | Saltwater | | EPA 2001g; 40CFR131.36
b. | EPA | Maximum concentration | 290 µg/L | EPA 2001g; 40CFR131.36
b. | EPA | Continuous concentration | 71 µg/L | EPA 2001g; 40CFR131.36
c. | Food
c. | FDA | Approved use of selenium as a food additive in animal feeds—added to feed for chickens, swine, turkeys, sheep, cattle, and ducks | ≤0.3 ppm | FDA 2001a; 21CFR573.920
c. | FDA | Bottled water—allowable level | 0.05 mg/L | FDA 2001b; 21CFR165.110
c. | FDA | RDA (mg/day) | | NAS 2000
c. | FDA | Men | 0.055 | NAS 2000
c. | FDA | Women | 0.055 | NAS 2000
c. | FDA | Pregnant women | 0.060 | NAS 2000
c. | FDA | Lactating women | 0.070 | NAS 2000
c. | FDA | Infants (0–6 months) | 0.015 | NAS 2000
c. | FDA | Infants (7–12 months) | 0.020 | NAS 2000
c. | FDA | Children (1–3 years) | 0.020 | NAS 2000
c. | FDA | Children (4–8 years) | 0.030 | NAS 2000
c. | FDA | Children (9–18 years) | 0.040 | NAS 2000
d. | Other
d. | EPA | Carcinogenicity classification | | IRIS 2001
d. | EPA | Selenium and compounds | Group D^b^ | IRIS 2001
d. | EPA | Selenium sulfide | Group B2^c^ | IRIS 2001
d. | EPA | Designation of hazardous substances | | EPA 2001h; 40CFR116.4
d. | EPA | Selenium oxide | | EPA 2001h; 40CFR116.4
d. | EPA | Sodium selenite | | EPA 2001h; 40CFR116.4
d. | EPA | Determination of reportable quantities | | EPA 2001i; 40CFR117.3
d. | EPA | Selenium oxide | 10 pounds | EPA 2001i; 40CFR117.3
d. | EPA | Sodium selenite | 100 pounds | EPA 2001i; 40CFR117.3
d. | EPA | Extremely hazardous substance | | EPA 2001j; 40CFR355, Appendix B
d. | EPA | Reportable quantity | | EPA 2001j; 40CFR355, Appendix B
d. | EPA | Hydrogen selenide | 10 pounds | EPA 2001j; 40CFR355, Appendix B
d. | EPA | Selenious acid | 10 pounds | EPA 2001j; 40CFR355, Appendix B
d. | EPA | Selenium oxychloride | 500 pounds | EPA 2001j; 40CFR355, Appendix B
d. | EPA | Threshold planning quantity | | EPA 2001j; 40CFR355, Appendix B
d. | EPA | Hydrogen selenide | 10 pounds | EPA 2001j; 40CFR355, Appendix B
d. | EPA | Selenious acid | 1,000/10,000 pounds | EPA 2001j; 40CFR355, Appendix B
d. | EPA | Selenium oxychloride | 500 pounds | EPA 2001j; 40CFR355, Appendix B
d. | EPA | Identification and listing of hazardous waste | | EPA 2001k; 40CFR261, Appendix VIII
d. | EPA | Selenium | | EPA 2001k; 40CFR261, Appendix VIII
d. | EPA | Selenium and compounds | | EPA 2001k; 40CFR261, Appendix VIII
d. | EPA | Selenium dioxide | | EPA 2001k; 40CFR261, Appendix VIII
d. | EPA | Selenium sulfide | | EPA 2001k; 40CFR261, Appendix VIII
d. | EPA | Selenium tetrakis, (dimethyldithiocarbamate) | | EPA 2001k; 40CFR261, Appendix VIII
d. | EPA | Selenious acid | | EPA 2001k; 40CFR261, Appendix VIII
d. | EPA | Selenourea | | EPA 2001k; 40CFR261, Appendix VIII
d. | EPA | Thallium selenite | | EPA 2001k; 40CFR261, Appendix VIII
d. | EPA | Protection standards at inactive uranium processing sites—listed constituents | | EPA 2001l; 40CFR192, Appendix I
d. | EPA | Selenium and compounds | | EPA 2001l; 40CFR192, Appendix I
d. | EPA | Selenium dioxide | | EPA 2001l; 40CFR192, Appendix I
d. | EPA | Selenium sulfide | | EPA 2001l; 40CFR192, Appendix I
d. | EPA | Recommended daily allowances | | EPA 2001m
d. | EPA | Selenium and compounds | | EPA 2001m
d. | EPA | Men | 0.7×10^−1^ mg/kg/day | EPA 2001m
d. | EPA | Women | 0.55×10^−1^ mg/kg/day | EPA 2001m
d. | EPA | Infants | 8.7×10^−4^ mg/kg/day | EPA 2001m
d. | EPA | Reportable quantity | | EPA 2001n; 40CFR302.4, Appendix A
d. | EPA | Selenium and compounds | 1 pound | EPA 2001n; 40CFR302.4, Appendix A
d. | EPA | Selenium dioxide | 1,000 pounds | EPA 2001n; 40CFR302.4, Appendix A
d. | EPA | Selenium sulfide | 1 pound | EPA 2001n; 40CFR302.4, Appendix A
d. | EPA | Selenious acid | 1 pound | EPA 2001n; 40CFR302.4, Appendix A
d. | EPA | Selenourea | 1 pound | EPA 2001n; 40CFR302.4, Appendix A
d. | EPA | Sodium selenite | 1,000 pounds | EPA 2001n; 40CFR302.4, Appendix A
d. | EPA | Thallium selenite | 1 pound | EPA 2001n; 40CFR302.4, Appendix A
d. | EPA | Reportable quantity | | EPA 2001o; 40CFR117.3
d. | EPA | Selenium oxide | 10 pounds | EPA 2001o; 40CFR117.3
d. | EPA | Sewer sludge—disposal or use standards | | EPA 2001p; 40CFR503.13
d. | EPA | Ceiling concentration | 100 mg/kg | EPA 2001p; 40CFR503.13
d. | EPA | Cumulative pollutant loading rate | 100 kg/hectare | EPA 2001p; 40CFR503.13
d. | EPA | Pollutant concentration^d^ | 100 mg/kg | EPA 2001p; 40CFR503.13
d. | EPA | Annual pollutant loading rate | 5.0 kg/hectare per 365-day period | EPA 2001p; 40CFR503.13
d. | EPA | Toxic chemical release reporting; Community Right-to-Know; effective date | 01/01/87 | EPA 2001q; 40CFR372.65
STATE
Regulations and Guidelines:
a. | Air
a. | Hawaii | HAP | | BNA 2001
a. | Illinois | Toxic air contaminant | | BNA 2001
a. | Kansas | HAP | | BNA 2001
a. | Kentucky | HAP | | BNA 2001
a. | Maryland | Toxic air pollutant | | BNA 2001
a. | Maryland | Selenium sulfide | | BNA 2001
a. | Minnesota | HAP threshold—de minimis level | | BNA 2001
a. | Minnesota | Selenium compounds | 0.1 ton/year | BNA 2001
a. | Minnesota | Selenium sulfide | 0.1 ton/year | BNA 2001
a. | Nebraska | HAP—effective date | 12/15/98 | BNA 2001
a. | New Hampshire | Regulated toxic air pollutant | | BNA 2001
a. | New Mexico | Toxic air pollutant | | BNA 2001
a. | New Mexico | OEL | 0.2 mg/m^3^ | BNA 2001
a. | New Mexico | Emissions | 0.0133 mg/m^3^ | BNA 2001
a. | New York | HAP—selenium compounds | | BNA 2001
a. | Rhode Island | HAP | | BNA 2001
a. | South Carolina | Toxic air emissions—maximum allowable concentration | | BNA 2001
a. | South Carolina | Selenium compounds | 1 µg/m^3^ | BNA 2001
a. | Vermont | Hazardous ambient air standards | | BNA 2001
a. | Vermont | Annual average | 4.80 µg/m^3^ | BNA 2001
a. | Vermont | Action level | 0.40 pounds/8-hours | BNA 2001
a. | Washington | HAP—threshold levels | | BNA 2001
a. | Washington | Selenium and compounds | 0.5 tons/year | BNA 2001
a. | Washington | Selenium hexafluoride | 0.5 tons/year | BNA 2001
a. | Washington | Selenium sulfides | 0.5 tons/year | BNA 2001
b. | Water
b. | Alabama | Aquatic life criteria | | BNA 2001
b. | Alabama | Freshwater | | BNA 2001
b. | Alabama | Acute | 20 µg/L | BNA 2001
b. | Alabama | Chronic | 5.0 µg/L | BNA 2001
b. | Alabama | Marine | | BNA 2001
b. | Alabama | Acute | 300 µg/L | BNA 2001
b. | Alabama | Chronic | 71 µg/L | BNA 2001
b. | Alabama | MCL | 0.05 mg/L | BNA 2001
b. | Alabama | Primary drinking water standard | 0.01 mg/L | BNA 2001
b. | Alaska | Groundwater cleanup level | 0.05 mg/L | BNA 2001
b. | Alaska | MCL | 0.05 mg/L | BNA 2001
b. | Arizona | Aquifer water quality standards | 0.05 mg/L | BNA 2001
b. | Arizona | Drinking water guideline | 45 µg/L | HSDB 2001
b. | Arizona | MCL | 0.05 mg/L | BNA 2001
b. | Arizona | Water quality standards | | EPA 2001r; 40CFR131.38
b. | Arizona | Conversion factor^e^ for saltwater—acute criteria | 0.998 | EPA 2001r; 40CFR131.38
b. | Arizona | Conversion factor^e^ for saltwater—chronic criteria | 0.998 | EPA 2001r; 40CFR131.38
b. | Colorado | Groundwater protection—MCL | 0.01 mg/L | BNA 2001
b. | Colorado | MCL | 0.05 mg/L | BNA 2001
b. | Colorado | Primary drinking water standard | 0.01 mg/L | BNA 2001
b. | Connecticut | MCL | 0.05 mg/L | BNA 2001
b. | Delaware | Groundwater protection—MCL | 0.01 mg/L | BNA 2001
b. | Delaware | Primary drinking water standard | 0.01 mg/L | BNA 2001
b. | Florida | MCL | 0.05 mg/L | BNA 2001
b. | Georgia | MCL | 0.05 mg/L | BNA 2001
b. | Hawaii | MCL | 0.05 mg/L | BNA 2001
b. | Hawaii | Water quality criteria applicable to all waters | | BNA 2001
b. | Hawaii | Freshwater | | BNA 2001
b. | Hawaii | Acute | 20 µg/L | BNA 2001
b. | Hawaii | Chronic | 5.0 µg/L | BNA 2001
b. | Hawaii | Saltwater | | BNA 2001
b. | Hawaii | Acute | 300 µg/L | BNA 2001
b. | Hawaii | Chronic | 71 µg/L | BNA 2001
b. | Illinois | Concentration shall not be exceeded in water | 1.0 mg/L | BNA 2001
b. | Illinois | Groundwater quality standard | 0.01 mg/L | BNA 2001
b. | Illinois | MCL | 0.05 mg/L | BNA 2001
b. | Indiana | MCLG | 0.05 mg/L | BNA 2001
b. | Indiana | MCL | 0.05 mg/L
b. | Iowa | MCL | 0.05 mg/L | BNA 2001
b. | Kansas | Surface water quality standard | | BNA 2001
b. | Kansas | Aquatic life | | BNA 2001
b. | Kansas | Acute | 20 µg/L | BNA 2001
b. | Kansas | Chronic | 5.0 µg/L | BNA 2001
b. | Kansas | Agriculture | | BNA 2001
b. | Kansas | Livestock | 50 µg/L | BNA 2001
b. | Kansas | Irrigation | 20 µg/L | BNA 2001
b. | Kansas | Public health food | | BNA 2001
b. | Kansas | Procurement | 6,800 µg/L | BNA 2001
b. | Kansas | Domestic water supply | 50 µg/L | BNA 2001
b. | Kentucky | Domestic water supply use—maximum allowable instream concentration | 0.05 mg/L | BNA 2001
b. | Kentucky | MCL | 0.05 mg/L | BNA 2001
b. | Kentucky | Maximum groundwater contaminant level | 0.01 mg/L | BNA 2001
b. | Kentucky | Primary drinking water standard | 0.01 mg/L | BNA 2001
b. | Kentucky | Warm water aquatic habitat criteria | | BNA 2001
b. | Kentucky | Acute | | BNA 2001
b. | Kentucky | Chronic | 20 µg/L | BNA 2001
b. | Kentucky | Chronic | 5.0 µg/L | BNA 2001
b. | Louisiana | Groundwater protection—MCL | 0.01 mg/L | BNA 2001
b. | Maine | Drinking water guideline | 10 µg/L | HSDB 2001
b. | Maryland | Criteria for toxic substances in surface waters | | BNA 2001
b. | Maryland | Freshwater | | BNA 2001
b. | Maryland | Acute | 20 µg/L | BNA 2001
b. | Maryland | Chronic | 5.0 µg/L | BNA 2001
b. | Maryland | Saltwater | | BNA 2001
b. | Maryland | Acute | 300 µg/L | BNA 2001
b. | Maryland | Chronic | 71 µg/L | BNA 2001
b. | Maryland | Drinking water | 50 µg/L | BNA 2001
b. | Maryland | MCL | 0.05 mg/L | BNA 2001
b. | Maryland | Primary drinking water standard | 0.01 mg/L | BNA 2001
b. | Massachusetts | Environmental toxicity values | | BNA 2001
b. | Massachusetts | Freshwater | 20 µg/L | BNA 2001
b. | Massachusetts | Acute | 5.0 µg/L | BNA 2001
b. | Massachusetts | Chronic | | BNA 2001
b. | Massachusetts | Marine | | BNA 2001
b. | Massachusetts | Acute | 300 µg/L | BNA 2001
b. | Massachusetts | Chronic | 71 µg/L | BNA 2001
b. | Massachusetts | Groundwater protection—MCL | 0.01 mg/L | BNA 2001
b. | Massachusetts | MCL | 0.05 mg/L | BNA 2001
b. | Michigan | MCL | 0.05 mg/L | BNA 2001
b. | Michigan | Effective date | 07/30/92 | BNA 2001
b. | Minnesota | Drinking water guideline | 30 µg/L | HSDB 2001
b. | Mississippi | Groundwater standard | 50 ppb | BNA 2001
b. | Mississippi | Water quality criteria—concentration shall not exceed | 0.01 mg/L | BNA 2001
b. | Montana | MCL | 0.05 mg/L | BNA 2001
b. | North Carolina | Fresh surface water quality standard for Class C waters | 5.0 ug/L | BNA 2001
b. | North Carolina | Groundwater quality standard | 0.05 mg/L | BNA 2001
b. | Nebraska | Aquatic life | | BNA 2001
b. | Nebraska | Acute | 20 µg/L | BNA 2001
b. | Nebraska | Chronic | 5.0 µg/L | BNA 2001
b. | Nebraska | Water supply | 0.05 mg/L | BNA 2001
b. | Nebraska | MCL | 0.05 mg/L | BNA 2001
b. | New Hampshire | Groundwater quality standard | 0.05 mg/L
b. | New Hampshire | MCLG | 0.05 mg/L | BNA 2001
b. | New Hampshire | MCL | 0.05 mg/L
b. | New Hampshire | Water quality criteria | | BNA 2001
b. | New Hampshire | Protection of aquatic life
b. | New Hampshire | Fresh
b. | New Hampshire | acute | 5.0 µg/L
b. | New Hampshire | chronic | 290µg/L
b. | New Hampshire | Marine
b. | New Hampshire | acute | 71 µg/L
b. | New Hampshire | chronic | 170 µg/L
b. | New Hampshire | Protection of human health
b. | New Hampshire | Water and fish ingestion | 11,000 µg/L
b. | New Mexico | MCL | 0.05 mg/L | BNA 2001
b. | Nevada | Domestic water supply | | BNA 2001
b. | Nevada | Dissolved selenium | 0.05 mg/L | BNA 2001
b. | New York | MCL | 0.05 mg/L | BNA 2001
b. | North Dakota | MCL | 0.05 mg/L | BNA 2001
b. | Ohio | Groundwater concentration limit | 0.01 mg/L | BNA 2001
b. | Oklahoma | Public and private water supplies | 0.01 mg/L | BNA 2001
b. | Oklahoma | Fish and wildlife propagation | | BNA 2001
b. | Oklahoma | Acute | 20 µg/L | BNA 2001
b. | Oklahoma | Chronic | 5.0 µg/L | BNA 2001
b. | Rhode Island | Groundwater quality standard | 0.05 mg/L | BNA 2001
b. | Rhode Island | Preventive action limit | 0.025 mg/L | BNA 2001
b. | South Carolina | MCL | 0.05 mgL | BNA 2001
b. | South Dakota | Groundwater maximum allowable concentration | 0.05 mg/L | BNA 2001
b. | South Dakota | Aquatic life value | | BNA 2001
b. | South Dakota | Acute | 20 µg/L | BNA 2001
b. | South Dakota | Chronic | 5.0 µg/L | BNA 2001
b. | Tennessee | Groundwater criteria concentration | 0.05 mg/L | BNA 2001
b. | Tennessee | MCL | 0.05 mg/L | BNA 2001
b. | Texas | MCL | 0.05 mg/L | BNA 2001
b. | Utah | MCL | 0.05 mg/L | BNA 2001
b. | Utah | Water quality | | BNA 2001
b. | Utah | Domestic | 0.01 mg/L | BNA 2001
b. | Utah | Agriculture | 0.05 mg/L | BNA 2001
b. | Vermont | Groundwater quality standards | | BNA 2001
b. | Vermont | Enforcement standard | 50 µg/L | BNA 2001
b. | Vermont | Preventive action level | 25 µg/L | BNA 2001
b. | Vermont | MCLG | 0.05 mg/L | BNA 2001
b. | Vermont | MCL | 0.05 mg/L
b. | Vermont | Water quality criteria for protection of aquatic organisms | | BNA 2001
b. | Vermont | Maximum allowable concentration | | BNA 2001
b. | Vermont | Acute | 20 µg/L | BNA 2001
b. | Vermont | Average allowable concentration | | BNA 2001
b. | Vermont | Chronic | 5.0 µg/L | BNA 2001
b. | Virginia | Groundwater protection levels | | BNA 2001
b. | Virginia | Protection level | 10 µg/L | BNA 2001
b. | Virginia | Monitoring level | 5.0 µg/L | BNA 2001
b. | Virginia | MCL | 0.01 mg/L | BNA 2001
b. | Virginia | Surface water criteria | | BNA 2001
b. | Virginia | Freshwater | | BNA 2001
b. | Virginia | Acute | 20 µg/L | BNA 2001
b. | Virginia | Chronic | 5.0 µg/L | BNA 2001
b. | Virginia | Saltwater | | BNA 2001
b. | Virginia | Acute | 300 µg/L | BNA 2001
b. | Virginia | Chronic | 71 µg/L | BNA 2001
b. | Virginia | Human health | | BNA 2001
b. | Virginia | Public water supplies | 170 µg/L | BNA 2001
b. | Virginia | All other surface waters | 11,000 µg/L | BNA 2001
b. | Washington | MCL | 0.05 mg/L | BNA 2001
b. | Wisconsin | Groundwater quality standards | | BNA 2001
b. | Wisconsin | Enforcement standard | 50 µg/L | BNA 2001
b. | Wisconsin | Preventive action limit | 10 µg/L | BNA 2001
b. | Wisconsin | MCL | 0.05 mg/L | BNA 2001
b. | Wyoming | Water quality | | BNA 2001
b. | Wyoming | Aquatic life | | BNA 2001
b. | Wyoming | Acute | 20 µg/L | BNA 2001
b. | Wyoming | Chronic | 5.0 µg/L | BNA 2001
b. | Wyoming | Human health | 10 µg/L | BNA 2001
c. | Food
c. | New York | Bottled water sampling requirements—MCL | 0.01 mg/L | BNA 2001
d. | Other
d. | Alabama | Identification and listing of hazardous waste | | BNA 2001
d. | Arizona | Soil remediation levels | | BNA 2001
d. | Arizona | Residential | 380 mg/kg | BNA 2001
d. | Arizona | Non-residential | 8,500 mg/kg | BNA 2001
d. | California | Hazardous waste injection restrictions—waste specific prohibitions | | EPA 2001s; 40CFR148.12 (b)(2)
d. | California | Selenium and/or compounds | 100 mg/L | EPA 2001s; 40CFR148.12 (b)(2)
d. | California | Known to cause cancer or reproductive toxicity—initial appearance of chemical on list | | BNA 2001
d. | California | Selenium sulfide | 10/01/89 | BNA 2001
d. | California | Total threshold limit concentration | 10,000 mg/kg | BNA 2001
d. | Delaware | Regulated toxic substance—sufficient quantity | | BNA 2001
d. | Delaware | Selenium hexafluoride | 900 pounds/hour | BNA 2001
d. | Florida | Toxic substance in the workplace | | BNA 2001
d. | Florida | Hydrogen selenium | | BNA 2001
d. | Florida | Selenium | | BNA 2001
d. | Florida | Selenium hexafluoride | | BNA 2001
d. | Florida | Selenium oxychloride | | BNA 2001
d. | Florida | Selenium sulfide | | BNA 2001
d. | Hawaii | Restricted use pesticides | | BNA 2001
d. | Hawaii | Selenium compounds | All concentrations | BNA 2001
d. | Kentucky | Threshold planning quantity | 10 pounds | BNA 2001
d. | Kentucky | Hydrogen selenide | 1,000/10,000 pounds | BNA 2001
d. | Kentucky | Selenious acid | 500 pounds | BNA 2001
d. | Kentucky | Selenium oxychloride | | BNA 2001
d. | Massachusetts | Oil and hazardous material | | BNA 2001
d. | Massachusetts | Selenious acid | | BNA 2001
d. | Massachusetts | Selenium and compounds | | BNA 2001
d. | Massachusetts | Selenium dioxide | | BNA 2001
d. | Massachusetts | Selenium disulfide | | BNA 2001
d. | Massachusetts | Selenium oxide | | BNA 2001
d. | Massachusetts | Selenium oxychloride | | BNA 2001
d. | Massachusetts | Selenium sulfide | | BNA 2001
d. | Massachusetts | Selenourea | | BNA 2001
d. | Minnesota | RfD | 0.005 mg/kg/day | BNA 2001
d. | Minnesota | Health risk limit | 30 µg/L
d. | New Hampshire | Restricted use pesticide | All concentrations | BNA 2001
d. | New Jersey | Extraordinary hazardous substance—threshold quantity | | BNA 2001
d. | New Jersey | Selenium hexafluoride | 700 pounds | BNA 2001
d. | Oregon | Toxic substance—de minimis concentration | 1.0 percent | BNA 2001
d. | Vermont | Restricted use pesticide | All concentrations | BNA 2001
d. | Vermont | Selenium and compounds | | BNA 2001

a Group 3: not classifiable as to its carcinogenicity to humans

b Group D: not classifiable as to its carcinogenicity to humans

c Group B2: probable human carcinogen

d Monthly average concentrations

e Conversion factors are based on a hardness of 100 mg/L as calcium carbonate

ACGIH = American Conference of Governmental Industrial Hygienists; BNA = Bureau of National Affairs; CFR = Code of Federal Regulations; DWEL = drinking water equivalent level; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; HAP = hazardous air pollutant; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life and health; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; MCLG = maximum contaminant level goal; NIOSH = National Institute for Occupational Safety and Health; OEL = occupational exposure limit; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; PQL = practical quantitation limit; RDA = recommended daily allowance; REL = recommended exposure limit; RfD = reference dose; TLV = threshold limit value; TWA = time-weighted average; WHO = World Health Organization