# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of selenium and selenium compounds is presented in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Selenium is a non-metal element with atomic number 34 and an atomic mass of 78.96 (Lide 2000). Selenium belongs to Group 6 (Group VIA) of the periodic table, located between sulfur and tellurium, and resembles sulfur both in its various forms and in its compounds. The six stable isotopes of selenium are ^74^Se, ^76^Se, ^77^Se, ^78^Se, ^80^Se, and ^82^Se. These isotopes occur naturally with approximate abundances of 0.87, 9.02, 7.58, 23.52, 49.82, and 9.19%, respectively (Hoffmann and King 1997). Artificial radioactive isotopes of selenium have also been created by neutron activation. The gamma-emitting isotope ^75^Se has been used in diagnostic applications of medicine (Hoffmann and King 1997). Selenium exists in several allotropic forms. Three are generally recognized, but as many as six have been claimed (Lide 2000). The stable form at ordinary room temperatures is the grey or hexagonal form with a melting point of 220.5 EC (Lide 2000). The other two important forms are red (monoclinic) with a melting point of 221 EC and amorphous selenium, which exists in black and red forms. Black amorphous selenium is vitreous and is formed by the rapid cooling of liquid selenium. Red amorphous selenium is colloidal and is formed in reduction reactions (Hoffmann and King 1997). Important selenium oxidation states are −2, 0, +4, and +6.

The chemical properties of selenium are similar to sulfur. Selenium combines with metals and many nonmetals directly or in aqueous solution. The selenides resemble sulfides in appearance, composition, and properties (Hoffmann and King 1997). Selenium may form halides by reacting vigorously with fluorine and chlorine, but the reactions with bromine and iodide are not as rapid. Selenium does not react directly with hydrogen fluoride or hydrogen chloride, but decomposes hydrogen iodide to liberate iodine and yield hydrogen selenide (Hoffmann and King 1997). Selenium reacts with oxygen to form a number of oxides, the most stable of which is selenium dioxide.

Information regarding the physical and chemical properties of selenium and selenium compounds is located in Table 4-2.

Table 4-1 Chemical Identity of Selenium and Selected Compounds^a^

Characteristic | Selenium | Hydrogen selenide | Selenic acid | Selenious acid
Synonyms | Elemental selenium; selenium base; selenium dust; colloidal selenium; selenium homopolymer^b^; selenium alloy | Dihydrogen selenide; hydrogen selenide [H_2_Se]; selenium anhydride; selenium dihydride; selenium hydride; selane | Selenic acid, liquid^DOT,b^ | Monohydrated selenium dioxide; selenous
Registered trade name(s) | C.I. 77805; VANDEX^b^
Chemical formula | Se | H_2_Se | H_2_SeO_4_ | H_2_SeO_3_
Wisewesser line notation | SE | H2 SE | H2.SE-04 | H2SE-03
Identification numbers:
CAS | 7782-49-2 | 7783-07-5 | 7783-08-6 | 7783-00-8
NIOSH RTECS | VS7700000 | MX1050000 | VS6575000 | VS7175000
EPA hazardous waste | No data | No data | No data | U204^c^
OHM/TADS | 7216880 | No data | No data | No data
DOT/UN/NA/IMCO shipping | UN 2658^b^ | UN 2202; Hydrogen selenide; anhydrous | UN 1905; IMCO 8.0 | No data
HSDB | 4493 | 548 | 675 | 6065
NCI | No data | No data | No data | No data

Characteristic | Sodium selenate | Potassium selenate | Sodium selenide | Sodium selenite
Synonyms | Disodium selenate | Selenic acid, dipotassium salt^b^ | Disodium monoselenide^b^ | Disodium selenite; disodium selenium trioxide; selenious acid disodium salt; sodium selenium oxide
Registered trade name(s) | P-40^b^; Sel-Tox SS02 and SS-20^c^ | No data | No data
Chemical formula | Na_2_SeO_4_^d^ | K_2_SeO_4_ | Na_2_Se^b^ | Na_2_SeO_3_^d^
Wisewesser line notation | NA2 SE-04^b^ | KA2 SE-04 | NA2 SE | NAS SE-03
Identification numbers:
CAS | 13410-01-0 | 7790-59-2 | 1313-85-5^b^ | 10102-18-8
NIOSH RTECS | No data | VS6600000 | WE0350000^b^ | VS7350000
EPA hazardous waste | No data | No data | No data | No data
OHM/TADS | No data | No data | No data | 7217299
DOT/UN/NA/IMCO shipping | No data | No data | No data | UN 2630^b^
HSDB | No data | No data | No data | 768
NCI | No data | No data | No data | No data

Characteristic | Selenium dioxide | Selenium trioxide | Selenocystine | Selenomethionine
Synonyms | Selenious anhydride; selenium oxide; selenium oxide [SeO_2_]; selenous acid anhydride | No data | Selenium cystine^b^; 3,3-diselenodi-DL-alanine^b^; seleno-DL-cystine^b^; DL-selenocystine^b^ | Methionine, seleno^b^; 2-amino-4-(methylselenyl) butyric acid; 2-amino-4-(methylseleno)
Registered trade name(s) | No data | No data
Chemical formula | SeO_2_ | SeO_3_^e^ | C_2_H_4_NO_2_(CH_2_)Se_2_(CH_2_)C_2_; H_4_NO_2_ | (CH_3_)Se(CH_2_)2C_2_H_4_NO_2_
Identification numbers:
CAS | 7446-08-04 | 13768-86-0^f^ | 1464-43-3^b^ | 1464-42-2
NIOSH RTECS | VS8575000 | No data | AY6030000^b^ | ES100000
EPA hazardous waste | V204^c^ | No data | No data | No data
OHM/TADS | 7800105 | No data | No data | No data
DOT/UN/NA/IMCO shipping | No data | No data | No data | No data
HSDB | 677 | No data | No data | No data
NCI | No data | No data | No data | No data

Characteristic | Selenium sulfide | Selenium disulfide
Synonyms | Selenium monosulfide; selenium sulfide [SeS]; selensulfid (German); sulfur selenide (SSe) | Selenium disulphide; selenium sulfide^b^; sulfur selenide
Registered trade name(s) | No data | Exsel; Selsun Blue; Selsum^b^; Seleen
Chemical formula | SeS | SeS_2_^b^
Wisewesser line notation | SE S | SE S2^b^
Identification numbers:
CAS | 744-34-6 | 7488-56-4
NIOSH RTECS | VTO525OOO | VS8925000
EPA hazard waste | V205^b^ | V205
OHM/TADS | 8400272 | 8400272
DOT/UN/NA/IMCO shipping | No data | UN 2657
HSDB | 679 | No data
NCI | NCI-C50033 | No data

a All information obtained from HSDB 2001, except where noted

b RTECS 2001

c EPA 1980a, 1980b (40 CFR 261.33)

d Budavari et al. 1996

e Lide 2000

f ChemIDplus 3003

CAS = Chemical Abstracts Service; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Selenium and Selenium Compounds^a^

Property | Selenium | Hydrogen selenide | Selenic acid | Selenious acid
Molecular weight | 78.96 | 80.98 | 144.97 | 128.97
Color/form | Red, grey, or black | Colorless^b^ | White hexagonal prisms; hygroscopic^b^ | White hygroscopic prisms^b^
Physical state | Solid | Gas | Solid | Solid
Melting point | 221 °C(red); 220.5 °C (grey); 180 °C (black)^b^ | −65.73 °C | 58 °C | 70 °C (decomposes)^b^
Boiling point | 685 °C | −41.3 °C | 260 °C | None, loses water upon heating
Density (g/cm^3^) | 4.39 (red); 4.81 (grey); 4.28 (black)^b^ | 2.12 (−42 °C) | 2.9508 (15 °C) | 3.004 (15 °C)
Odor | Unknown; upon combustion, smells like rotten horseradish | Disagreeable odor | No data | No data
Odor threshold:
Water (mg/m^3^) | No data | No data | No data | No data
Air | No data | No data | No data | No data
Solubility: | Insoluble | 377 mL/100 mL at 4 °C;; 270 mL/100 mL at 22.5 °C;; 0.73 mL/100 mL at 20 °C^c^ | Very soluble in hot water | 90 parts dissolve in 100 parts of water at 0 °C; 400 parts in 100 parts at 90 °C
Water | | 377 mL/100 mL at 4 °C;; 270 mL/100 mL at 22.5 °C;; 0.73 mL/100 mL at 20 °C^c^ | Very soluble in hot water | 90 parts dissolve in 100 parts of water at 0 °C; 400 parts in 100 parts at 90 °C
Organic solvent(s) | Insoluble in alcohol, slightly soluble in carbon disulfide (2 mg/100 mL, room temperature), soluble in ether | Soluble in carbon disulfide, carbonyl chloride | Decomposes in alcohol^b^ | Very soluble in alcohol
Partion coefficients:
Log K_ow_ | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data
Vapor pressure | 1 mmHg at 356 °C (grey) | 1,330 mmHg at −30 °C; 3,420 mmHg at 0.2 °C; 9,120 mmHg at 30.8 °C | No data | 2 mmHg at 15 °C; 4.5 mmHg at 33 °C; 7mmHg at 40.3 °C
Henry’s Law constant | Not applicable | No data | Not applicable | Not applicable
Autoignition temperature | No data | No data | No data | No data
Flashpoint | No data | Not applicable | No data | No data
Flammability limits | No data | No data | No data | No data
Conversion factors | No data | ppm selenium to mg Selenium/m^3^ in air (20 °C): ppm selenium × 3.23=mg selenium/m^3^ to ppm selenium in air (20 °C): mg selenium/m^3^ × 0.31=ppm selenium (v/v) | No data | No data
Explosive limits | Unknown^d^ | No data | No data | No data

Property | Sodium selenate | Potassium selenate | Sodium selenide | Sodium selenite
Molecular weight | 188.94 | 221.15 | 124.94 | 172.94
Color/form | White crystals | Colorless crystals or white powder | Crystalline; turns red on exposure to air and deliquesces | White tetragonal crystals^b^
Physical state | Solid | Solid | Solid | Solid
Melting point | No data | No data | >875 °C | No data
Boiling point | No data | No data | No data | No data
Density (g/cm^3^) | 1.61^b^ | 3.07 | 2.625 (10 °C) | No data
Odor | No data | No data | No data | No data
Odor threshold:
Water (mg/m^3^) | No data | No data | No data | No data
Air | No data | No data | No data | No data
Solubility:
Water | Very soluble in water | Soluble in about 1 part of water | Decomposes in water | Freely soluble in water
Organic solvent(s) | No data | No data | No data | No data
Partition coefficients:
Log K_ow_ | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data
Vapor pressure | No data | No data | No data | No data
Henry’s Law constant | No data | No data | No data | No data
Autoignition temperature | No data | No data | Not flammable^e^ | Not flammable^e^
Flashpoint | No data | No data | Not flammable^e^ | Not flammable^e^
Flammability limits | No data | No data | Not flammable^e^ | Not flammable^e^
Conversion factors | No data | No data | No data | No data
Explosive limits | No data | No data | No data | No data

Property | Selenium dioxide | Selenium trioxide | Selenocystine | Selenomethionine
Molecular weight | 110.96 | 126.96^b^ | 334.12^c^ | 196.11
Color/form | Lustrous, tetragonal needles; yellowish-green vapor | White crystals^b^ | No data | Transparent, hexagonal sheets or plates; metallic luster or crystals
Physical state | Solid | Solid | No data | Solid
Melting point | 340 °C; sublimes at 315 °C^b^ | 118 °C^b^ | No data | DL form: 265 °C (decomposes); L form: 266–268 °C
Boiling point | None^b^ | Sublimes^b^ | No data | Not applicable
Density (g/cm^3^) | 3.954 (15 °C) | 3.44^b^ | No data | No data
Odor | Pungent sour smell | No data | No data | No data
Odor threshold:
Water (mg/m^3^) | 0.0002^e^ | No data | No data | No data
Air | No data | No data | No data | No data
Solubility:
Water (g/100 mL) | 38.4 at 14 °C; in methanol: 10.16 at 11.8 °C; in 93% ethanol: 6.67 at 14 °C; in acetone: 4.35 at 15.3 °C; in acetic acid: 1.11 at 13.9 °C; soluble in benzene | Soluble in water | No data | No data
Organic solvent(s) (parts/100 parts solvent) | 38.4 at 14 °C; in methanol: 10.16 at 11.8 °C; in 93% ethanol: 6.67 at 14 °C; in acetone: 4.35 at 15.3 °C; in acetic acid: 1.11 at 13.9 °C; soluble in benzene | No data | No data | No data
Partition coefficients:
Log K_ow_ | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data
Vapor pressure | 12.5 mm Hg at 70 °C; 20.2 mm Hg at 94 °C; 39.0 mm Hg at 181 °C; 760 mm Hg at 315 °C; 848 mm Hg at 320 °C | No data | No data | No data
Vapor pressure | 12.5 mm Hg at 70 °C; 20.2 mm Hg at 94 °C; 39.0 mm Hg at 181 °C; 760 mm Hg at 315 °C; 848 mm Hg at 320 °C | | No data | No data
Henry’s Law constant | Not applicable | Not applicable | No data | No data
Autoignition temperature | Not flammable^e^ | Not flammable^e^ | No data | No data
Flashpoint | Not flammable^e^ | Not flammable^e^ | No data | No data
Flammability limits | Not flammable^e^ | Not flammable^e^ | No data | No data
Conversion factors | ppm (v/v) to mg/m^3^ in air (20 °C): ppm (v/v) × 4.53=mg/m^3^; mg/m^3^ to ppm (v/v) in air (20 °C): mg/m^3^ × 0.22=ppm (v/v) | No data | No data | No data
Explosive limits | No data | No data | No data | No data

Property | Selenium sulfide | Selenium disulfide
Molecular weight | 111.02^f^ | 143.08^f^
Color/form | Orange-yellow tablets or powder^f^ | Bright red-yellow powder^f^
Physical state | Solid^f^ | Solid^f^
Melting point | 118–119 °C (decomposes)^f^ | <100 °C^f^
Boiling point | No data | No data
Density (g/cm^3^) | 3.056 (0 °C)^f^ | No data
Odor | No data | No data
Odor threshold:
Water (mg/m^3^) | No data | No data
Air | No data | No data
Solubility:
Water | Insoluble | Insoluble
Organic solvent(s) | Insoluble in ether; decomposes in alcohol^f^ | No data
Partition coefficients:
Log K_ow_ | Not applicable | No data
Log K_oc_ | Not applicable | No data
Vapor pressure | Not applicable | Not applicable
Henry’s Law constant | Not applicable | Not applicable
Autoignition temperature | No data | No data
Flashpoint | No data | No data
Flammability limits | No data | No data
Conversion factors | No data | No data
Explosive limits | No data | No data

a All information obtained from Budavari et al. 1996, unless otherwise noted.

b Lide 2000

c RTECS 2001

d NIOSH/OSHA 1981

e Weiss 1986

f Lide 1993

Note: The gray metallic form is the most stable form of selenium (Budavari et al. 1996).