# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as a hundredfold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agency wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop E-29, Atlanta, Georgia 30333.

## Selenium Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Selenium
CAS Number: | 7782-49-2 (elemental)
Date: | June 5, 2003
Profile Status: | Post Public Comments, Draft 3
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 101
Species: | Human

[underlined: Minimal Risk Level]: 0.005 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Yang G, Zhou R. 1994. Further observations on the human maximum safe dietary selenium intake in a seleniferous area of China. J Trace Elem Electrolytes Health Dis 8:159–165 7599506 .

[underlined: Experimental design]: This study was an examination of a group of five individuals who were recovering from selenosis, and who had been drawn from a larger population studied by the same authors (Yang et al. 1989a, 1989b). Yang et al. (1989a, 1989b) examined a population in an area of China where selenosis occurred. Data were collected on selenium levels in the diet, blood, nails, hair, urine, and milk of residents, and the incidence of clinical symptoms of selenosis (morphological changes in fingernails) was compared with dietary intake of selenium and selenium levels in blood. Selenium levels in blood corresponded to the dietary intake of selenium, and symptoms of selenosis occurred at or above a selenium intake level of 910 µg/day (0.016 mg/kg/day) (Yang et al 1989a). In 1992, Yang and Zhou (1994) reexamined five individuals from the high selenium site who had been suffering from symptoms of selenosis (loss of fingernails and hair), but were recovering (nails were regrowing). Since their earlier report, the living conditions of the population had improved; they had been cautioned against consuming high selenium foods and parts of their locally produced corn had been replaced with rice or cereals. Yang and Zhou (1994) found that the mean concentration of selenium in the blood of these selenosis patients had fallen from 1,346 µg/L (measured in 1986) to 968 µg/L (measured in 1992). Using a regression equation derived from the data in their earlier report (Yang et al. 1989b) and average body weights of 55 kg, Yang and Zhou (1994) calculated that the mean dietary intake of selenium associated with selenosis in these individuals was 1,270 µg/day (LOAEL of 0.023 mg/kg/day), while a mean intake of 819 µg selenium/day (NOAEL of 0.015 mg/kg/day) was associated with recovery.

[underlined: Effects noted in study and corresponding doses]: A NOAEL of 0.015 mg/kg/day for nail disease based on recovery from symptoms of selenosis, and a LOAEL of 0.023 mg/kg/day based on nail damage were calculated from selenium concentrations in blood using average body weights of 55 kg and the regression equation: Yblood-Se (mg/L) = 8230 x 10^−4^ Xse-intake (µg) + 0.176 derived in Yang et al. (1989b).

[underlined: Dose and end point used for MRL derivation]: 0.015 mg/kg/day; nail disease (selenosis)

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [ ] 10 for extrapolation from animals to humans
- [X] 3 for human variability

A factor of 3 was considered appropriate because the individuals in this report were sensitive individuals drawn from the larger population in the Yang et al. (1989a, 1989b) studies and because of the supporting studies described below.

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose]? No.

If so, explain:

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose]: NA

[underlined: Other additional studies or pertinent information which lend support to this MRL]:

Yang et al. (1989a, 1989b) examined a population of 349 individuals in an area of China where selenosis occurred. They collected data on selenium levels in the diet, blood, nails, hair, urine, and milk of residents at three sites with low, medium, and high selenium, and compared the incidence of clinical symptoms of selenosis (morphological changes in finger nails) with dietary intake of selenium and selenium levels in blood. They found that selenium levels in blood corresponded to the dietary intake of selenium, and that symptoms of selenosis were found at or above a selenium intake level of 910 µg/day (0.016 mg/kg/day) (Yang et al 1989a). The population included adult men and women, teenagers, children, and infants. High selenium levels were found in individuals of all ages, but symptoms of selenosis were generally confined to adults (97% of cases) and were never observed in children younger than 12 years of age (Yang et al. 1989b). The manifestation of symptoms of selenosis was not solely dependent on selenium intake, but was subject to individual variability, as individuals who exhibited selenosis did not necessarily have the highest blood selenium levels.

Longnecker et al. (1991) examined two groups of adults (142 individuals) in areas of Wyoming and South Dakota with elevated selenium intake. The average daily intake of selenium in this population was 239 µg/day (0.003 mg/kg/day) and some individuals consumed as much as 724 µg/day (0.01 mg/kg/day). The highest blood concentration of selenium noted in this population was 0.67 mg/kg, a concentration lower than the 1.05 mg/L concentration associated with effects in China. No symptoms of selenosis or any other significant health effects associated with selenium exposure were reported for individuals in this study. This study suggests that the estimates of dietary intake of selenium produced by the regression equation in Yang et al. (1989b) may be conservative. Longnecker et al. (1991) reported doses of 68–724 µg/day associated with blood concentrations of 0.18–0.67 mg/kg. If the doses from the Longnecker et al. (1991) study are placed in the regression equation from Yang et al. (1989b), blood concentrations of 0.14 and 0.88 mg/L are calculated. If it is assumed that a liter of blood weighs approximately 1 kg, then this regression equation overpredicts blood levels of selenium at the higher doses in the population from North Dakota. This provides support for additional exposure (e.g., inhalation exposure) in the Chinese population that was not accounted for in the regression equation.

Selenium is a component of all three members of the deiodinase enzyme family, the enzymes responsible for deiodination of the thyroid hormones (St. Germain and Galton 1997). Two human studies were located that describe significant decreases in triiodothyronine levels in response to elevated selenium; however, the hormone levels observed in these studies were subclinical within the normal human range and the biological significance of the effect is not clear. In the first study, Brätter and Negretti De Brätter (1996) examined a Venezuelan population with high selenium intake. Serum, erythrocyte, toenail, and breast milk selenium concentrations were determined for 65 women living in three seleniferous regions of Venezuela. Selenium dietary intakes were determined from the selenium concentration of breast milk by regression (Bratter et al. 1991), and free thyroxine (T_4_), free triiodothyronine (T_3_), and human thyroid stimulating hormone (TSH) levels were measured. Selenium intake ranged from 170 to 980 µg/day. There was a significant inverse correlation between free T_3_ and selenium levels in serum (Spearman R test), but free T_3_, free T_4_, and TSH levels were found to be within normal ranges. No symptoms of selenosis were found in the women included in this study.

In the second human study, serum hormone, semen, immunological, and hematological status was evaluated in a 120-day double blind study of healthy men (20–45 years old) who consumed a controlled diet of foods naturally low or high in selenium (Hawkes and Turek 2001; Hawkes et al. 2001). Eleven subjects were fed a diet that provided 47 µg Se/day (0.0006 mg/kg/day) for the first 21 days of the study. For the following 99 days, six of the subjects were fed a diet providing 13 µg Se/day (0.0002 mg/kg/day), and five of the remaining subjects were fed a diet providing 297 µg/day (0.004 mg/kg/day). Comprehensive evaluations were performed at weeks 3 (baseline), 17 (ending value), and several interim time points on end points that included selenium levels (in blood plasma, erythrocytes, seminal plasma, and sperm); thyroid hormone levels (serum T_3_ and TSH); reproductive hormone levels (serum testosterone, follicle-stimulating hormone, luteinizing hormone, prolactin, estradiol, and progesterone); semen quality (sperm concentration, semen volume, sperm total number, fraction motile sperm, percent progressive sperm, mean forward velocity, and various sperm morphology parameters); immunological indices (complete blood counts, lymphocyte phenotypes, serum immunoglobulins (IgA, IgG, IgM); complement fractions; peripheral blood mononuclear cell (PBMNC) in vitro proliferative responses to mitogenic stimulation with phytohemagglutinin (PHA), concanavalin A (ConA), and pokeweed; natural-killer cell (NKC) activity; delayed-type hypersensitivity (DHS) skin responses to recall antigens (tuberculin purified-protein derivative, mumps, tetanus toxoid, candida, trichophyton, streptokinase strepase, and coccidioidin); antibody responses to diptheria-tetanus and influenza vaccines); and hematological indices (complete blood counts, white blood cells, lymphocytes, granulocytes, platelets, erythrocytes, hematocrit, and hemoglobin concentration). For measurements repeated more than twice, the baseline value was subtracted from the value at each time point to calcuate within-subject changes, and two-way repeated measures analysis of variance was used to test for significant effects of dietary selenium and time. When the selenium main effect or the selenium x time interaction was significant, the Student-Newman-Keuls comparison test was used to identify significant differences between the low-selenium and high-selenium groups at individual time points. For measurements obtained only twice (during baseline and at end of study), within-subject changes were compared between groups with a two-tailed ttest. Measurements obtained only at the end of the study were compared between groups with a two-tailed t-test without any correction. A probability of ≤0.05 was considered significant in all tests.

Selenium levels in blood plasma began to change within 3 days of starting the low- and high-selenium diets and progressively continued throughout the study (Hawkes and Turek 2001). By week 17, mean plasma selenium concentrations had increased by 109% in the high-selenium group and decreased by 38.5% in the low-selenium group. Group mean serum T_3_ concentrations (averages of within-subject changes from baseline) were significantly different in the low-selenium subjects and high-selenium subjects at all time points, but the magnitudes of the changes are insufficient to be considered biologically significant in either group. In the low-selenium group, serum T_3_ levels increased an average of 14 and 8% from baseline during weeks 8 and 17, respectively. In the high-selenium group, serum T_3_ levels decreased an average of 23 and 11% from baseline during weeks 8 and 17, respectively. Analysis of variance (ANOVA) indicated a significant effect of dietary selenium on serum T_3_ concentrations and that the magnitude of the effect was modified by the duration of exposure (i.e., the group changes in T_3_ levels decreased over time). Although the decreases in serum T_3_ in the high selenium group and increases in serum T_3_ in the low selenium group lessened in magnitude during the study, all group mean values appear to have remained within the normal range (only week 17 values were actually reported). The respective baseline and week 17 serum T_3_ values (mean±SD) were 1.82±0.36 and 1.57±0.07 nmol/L in the high-selenium group and 1.57±0.25 and 1.64±0.16 nmol/L in the low-selenium group, compared to a normal human range of 1.1–2.7 nM/L for total T_3_, indicating that the changes were subclinical and not biologically significant. Serum TSH concentrations increased significantly by 32% over its baseline concentration in the high-selenium group but did not change significantly in the low-selenium group.

Baseline and ending TSH values in the high-selenium group were 2.25±0.81 and 2.96±1.05 mU/L, respectively, both of which are in the normal range of 0.3–4.0 mU/L (Stockigt 2000). There were no significant changes in the serum levels, nor any significant differences between groups in free or total testosterone, follicle-stimulating hormone, luteinizing hormone, prolactin, estradiol, or progesterone.

The pattern of changes in seminal plasma selenium levels was similar to that observed for blood selenium, although selenium levels in sperm did not change significantly in either group (Hawkes and Turek 2001). Mean sperm motility (average of within-subject changes from baseline in fraction of motile sperm) was significantly different in the low-selenium subjects and high-selenium subjects at week 13, but not at weeks 8 or 17. The fraction of motile sperm increased an average of 10% in the low-selenium group at week 13, and was essentially the same as baseline at week 17. Sperm motility decreased an average of 32% in the high-selenium group at week 13, and ended 17% lower than the baseline value at week 17. The ANOVA indicated a significant effect of dietary selenium on sperm motility and that the effect of selenium was modified by duration of exposure (the groups diverged over time). Baseline and ending motile sperm fractions in the high-selenium group were 0.588±0.161 and 0.488±0.193, respectively; >50% motility is considered normal (FDA 1993). The decrease in sperm motility in the high-selenium group cannot be clearly attributed to exposure because the effect was not related to duration of treatment, and is unlikely to be adverse because the effect is at the low end of the normal range and not accompanied by any significant significant effects of high- or low-selenium treatment on sperm progression, concentration, total number, or morphology. Additionally, there were no effects of selenium on serum levels of the reproductive hormones, and changes in the thyroid hormones, which could also affect sperm function, were not outside normal ranges.

The immunological assessment showed that the high-selenium diet was not immunotoxic and had some mild and transient immune-enhancing properties (Hawkes et al. 2001). There is an indication that selenium supplementation increased the secondary immune response to diphtheria vaccine when rechallenged at the end of the study. The mean within-subject ratio of diphtheria antibody titers 14 days after reinoculation (day 116) to titers 14 days after the initial challenge at baseline (day 19) was significantly greater in the high-selenium group than in the low-selenium group (2.7±1.8-fold vs. 0.9±0.6-fold, p=0.03). Lymphocyte counts were significantly increased in the high-selenium group on day 45, but not at the end of the study, and there were no clear effects of selenium on numbers of activated or cytotoxic T-cells. The proliferative response of peripheral lymphocytes to stimulation with pokeweed mitogen (a B-cell mitogen) was significantly higher in the high-selenium group than in the low-selenium group on days 45 and 72, although not at the end of the study. There was no selenium-induced lymphocyte proliferation in response to the T-cell mitogens (phytohemagglutinin or concanavalin A) or changes in any of the other immunological end points. The hematological assessment (Hawkes et al. 2001) found minor mean within-subject changes from baseline in white blood cell counts that were significantly different in the low- and high-selenium groups at the last two time points (days 70 and 99); WBCs were decreased by 5% in the high-selenium group and increased by 10% in the low-selenium group at the end of the study. The changes in WBC counts were due mainly to changes in granulocytes. Lymphocyte counts were significantly increased in the high-selenium group on day 45, but not at the end of the study.

[underlined: Chemical Manager]: John Risher, Ph.D.