# DISCLAIMER

The use of company or product name(s) is for identification only and does not imply endorbement by the Agency for Toxic Substances and Disease Registry.