# 7 REGULATIONS AND ADVISORIES

International and national regulations and guidelines pertinent to human exposure to radium are summarized in Table 7-1. Recommendations for radiation protection for people in the general population as a result of exposure to radiation in the environment are found in the Federal Radiation Guidance (FRC 1960) and ICRP No. 26 (ICRP 1977). National guidelines for occupational radiation protection are found in the “Federal Radiation Protection Guidance for Occupational Exposure” (EPA 1987). This guidance for occupational exposure supercedes recommendations of the Federal Radiation Council for occupational exposure (FRC 1960). The new guidance presents general principles for the radiation protection of workers and specifies the numerical primary guides for limiting occupational exposure. These recommendations are consistent with the ICRP (ICRP 1977).

The basic philosophy of radiation protection is the concept of AURA (As Low As Reasonably Achievable). As a rule, all exposure should be kept as low as reasonably achievable, and the regulations and guidelines are meant to give an upper limit to exposure. Based on the primary guides (EPA 1987a), guides for Annual Limits on Intake (ALIs) and Derived Air Concentrations (DACS) have been calculated (EPA 1988). The AL1 is defined as “that activity of a radionuclide which, if inhaled or ingested by Reference Man (ICRP 1975), will result in a dose equal to the most limiting primary guide for committed dose” (EPA 1988; ICRP 1979) (see Appendix B). The DAC is defined as “the concentration of radionuclide in air which, if breathed by Reference Man (ICRP 1975) for a work-year, would result in the intake of one AL1 (EPA 1988). The ALIs and DACs refer to occupational situations but may be converted to apply to exposure of persons in the general population by application of conversion factors (Table 7-1).

TABLE 7-1 Regulations and Guidelines Applicable to Radium

Agency | Description | Value^a,*^ | | Reference
[underlined: International]
Guidelines:
ICRP | Occupational – whole body exposure | 5 rem/yr (50 mSv/yr) | | ICRP 1977
ICRP | Individual – short-term, to critical populations | 0.5 rem/yr (5 mSv/yr)
ICRP | Individual – chronic exposure | 0.1 rem/yr (1 mSv/yr)
WHO | Guideline values recommended | [underlined: pCi/L (Bq/L)] | | WHO 198A
WHO | Gross alpha activity | 2.7 (0.1)
WHO | Gross beta activity | 27 (1)
[underlined: National]
Regulations:
a. Air:
EPA | Hazardous Air Pollutant | NA | | EPA 1989a
OAQPS | NESHAPS (Radionuclides) (proposed)
b. Water:
EPA OWRS | Effluent limitations guidelines | NA | | EPA 1982a 40 CFR 440
EPA | MCL | [underlined: pCi/L (Bq/L)] | | EPA 1986c (40 CFR 1A1.15, 1A1.16)
ODW | Radium-226, radium-228 | 5 (2×10^−1^) | | EPA 1986c (40 CFR 1A1.15, 1A1.16)
ODW | Gross alpha particle activity (excluding radon and uranium) | 15 (6×10^−1^) | | EPA 1986c (40 CFR 1A1.15, 1A1.16)
c. Nonspecific media:
EPA | Reportable quantity | | | EPA 1989b 40 CFR 302
EPA | | [underlined: Ci (Bq)]
EPA | Radium-223 | 1 | (4×10^10^)
EPA | Radium-224 | 10 | (4×10^11^)
EPA | Radium-225 | 1 | (4×10^10^)
EPA | Radium-226 | 0.1 | (4×10^9^)
EPA | Radium-227 | 1000 | (4×10^13^)
EPA | Radium-228 | 0.1 | (4×10^9^)
EPA | Radiation protection:
ORP | Standards for nuclear power operations. Annual radiation dose equivalent to whole body | 25 mrem | | 40 CFR 190.10
ORP | Standards for management and disposal of spent fuel and wastes. Release limit, radium-226^b^ | 100 Ci (4×10^12^ Bq) | | 40 CFR 191 Appendix A Table 1
ORP | Standards for uranium and thorium mill tailings. Radium-226: | [underlined: pCi/g (Bq/g)] | | 40 CFR 192.12
ORP | First 15 cm of soil | 5 (2×10^−1^) | | 40 CFR 192.12
ORP | More than 15 cm below soil | 15 (6×10^−1^) | | 40 CFR 192.12
ORP | Groundwater protection | [underlined: pCi/L (Bq/L)] | | 40 CFR 192.32
ORP | Combined radium-226 and -228 | 5 (2×10^−1^) | | 40 CFR 192.32
ORP | Gross alpha particle activity (excluding radon and uranium) | 15 (6×10^−1^) | | 40 CFR 192.32
FDA | Levels in bottled water. | [underlined: pCi/L (Bq/L)] | | 21 CFR 103.35
FDA | Radium-226 and -228 | 5 (2×10^−1^) | | 21 CFR 103.35
FDA | Gross alpha particle activity | 15 (6×10^−1^) | | 21 CFR 103.35
NRC | Radiation standards for exposure levels, discharge, disposal | NA | | NRC 1988^c^ 10 CFR 20
NRC | Radium-226 | 0.01 μCi (4×10^2^ Bq) | | NRC 1988^c^ 10 CFR 20 Appendix C
Guidelines:
EPA | Carcinogenic classification | Group A^d^ | | IRIS 1988, 1989
EPA | Occupational - the committed effective dose equivalent (internal) and annual effective dose equivalent (external) combined | 5 rem/yr (50 mSv) | | EPA 1987a
FRC | Individual - whole body exposure | 0.5 rem/yr (5 mSv) | | FRC 1960 ^e^
FRC | Individual - operational guide for “suitable sample of population” when individual whole body doses are not known | 0.17 rem/yr (1.7 mSv) | | FRC 1960 ^e^
EPA | Liang clearance class^f,^ ^g^ | | | EPA 1988
EPA | All forms | W | | EPA 1988
EPA | Occupational ALI for inhalation of class W forms of^h^: | [underlined: pCi (Bq)] | | EPA 1988
EPA | Radium-223 | 7×10^5^ | (3×10^4^) | EPA 1988
EPA | Radium-224 | 2x10^6^ | (7×10^4^) | EPA 1988
EPA | Radium-225 | 7×10^5^ | (3×10^4^) | EPA 1988
EPA | Radium-226 | 6×10^5^ | (2×10^4^) | EPA 1988
EPA | Radium-227 | 1×10^10^ | (4×10^8^) | EPA 1988
EPA | Radium-228 | 1×10^6^ | (4×10^4^) | EPA 1988
EPA | Occupational ALI for ingestion of^i^: | [underlined: pCi (Bq)] | | EPA 1988
EPA | Radium-223 | 5×10^6^ | (2×10^5^) | EPA 1988
EPA | Radium-224 | 8×10^6^ | (3×10^5^) | EPA 1988
EPA | Radium-225 | 8×10^6^ | (3×10^5^) | EPA 1988
EPA | Radium-226 | 2×10^6^ | (7×10^4^) | EPA 1988
EPA | Radium-227 | 2×10^10^ | (7×10^8^) | EPA 1988
EPA | Radium-228 | 2×10^6^ | (7×10^4^) | EPA 1988
EPA | Occupational DAC for inhalation of class W forms of^j^: | [underlined: pCi/cm^3^ (Bq/m^3^)] | | EPA 1988
EPA | Radium-223 | 3×10^−4^ | (1×10^1^) | EPA 1988
EPA | Radium-224 | 7×10^−4^ | (3×10^1^) | EPA 1988
EPA | Radium-225 | 3×10^−4^ | (1×10^1^) | EPA 1988
EPA | Radium-226 | 3×10^−4^ | (1×10^1^) | EPA 1988
EPA | Radium-227 | 6 | (2×10^5^) | EPA 1988
EPA | Radium-228 | 5×10^−4^ | (2×10^1^) | EPA 1988

ALI = Annual Limit of Intake

DAC = Derived Air Concentration

EPA = Environmental Protection Agency

FDA = Food and Drug Administration

FRC = Federal Radiation Council

ICRP = International Commission on Radiological Protection

MCL = Maximum Contaminant Level

NA = Not applicable

NRC = Nuclear Regulatory Commission

OAQPS = Office of Air Quality Planning and Standards

ODW = Office of Drinking Water

ORP = Office of Radiation Programs

NESHAPS = National Emissions Standards for Hazardous Air Pollutants

WHO = World Health Organization

* See Glossary and Appendix B for definition of units

a Numerical values are provided in this column, when available. However, many regulations list chemicals and/or involve requirements too complex for inclusion here. In these case, NA (Not Applicable) is inserted in this column. The cited references provide details of the regulations.

b Cumulative release to the accessible environment for 10,000 years after disposal per 1,000 metric tons of Heavy Metal or other units of waste.

c The Nuclear Regulatory Commission limits in 10 CFR 20 are in the process of revision.

d Group A: Human carcinogen.

e FRC guidance for occupational exposure is superseded by EPA (1987) Federal Radiation Protection Guidance.

f Lung clearance class indicates the rate at which the element is cleared from the lung: D (days), W (weeks), Y (years).

g The ALIs and DACs recommended by the EPA are numerically identical to those recommended by the ICRP Publication 30 (ICRP 1979).

h Conversion of the ALI for occupational settings to apply to exposure of persons in the general population is :

ALI_i_ = ALI ∗ 0.1

where ALI_i_ is the intake for the general population, ALI is the intake for occupational exposures and 0.1 is the ratio of the dose limit to the individual (0.5 rem/yr) and the dose limit for occupational workers (5 rem/yr).

i Based on a fractional uptake from the small intestine to blood (f_1_) of 0.2.

j Conversion of the DAC for occupational exposure to apply to the general public is:

DAC_i_ = DAC ∗ 0.03

where DAC_i_ refers to the “Derived Air Concentration” for exposure to the general population and 0.03 represents the adjustment for hours of exposure (168 hrs per month occupational vs. 720 hrs per month of continuous exposure), breathing rate (29 m^3^/day for occupational vs. 22 m^3^/day for the general population) and dose limits (0.5 rem/yr for individuals vs. 5 rem/yr for occupational settings).