# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

The chemical formula and available identification numbers for radium are listed in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Table 3-2 lists important physical properties of radium and selected radium compounds. Radioactive properties of the four naturally-occurring radium isotopes are listed in Table 3-3. In addition to the naturally occurring isotopes, there are 12 other known isotopes of radium. The principal decay schemes of the uranium and thorium decay series that produce the naturally-occurring radium isotopes are presented in Figure 3-1.

TABLE 3-1 Chemical Identity of Radium

| Value | Reference
Chemical name | Radium | NLM 1988
Natural isotopes | Radium-223; Radium-224; Radium-226; Radium-228 | Windholz 1983
Trade name | No data
Chemical formula | Ra | NLM 1988
Chemical structure | Ra^+2^ | NLM 1988
Valence state | +2 | Windholz 1983
Identification numbers:
CAS Registry | 7440-14-4 | NLM 1988
NIOSH RTECS | No data
EPA Hazardous Waste | No data
OHM/TADS | No data
DOT/UN/NA/IMCO Shipping | No data
HSDB | 2146 | HSDB 1988
NCI | No data

CAS = Chemical Abstracts Service; NIOSH = National Institute for Occupational Safety and Health; RTECS = Registry of Toxic Effects of Chemical Substances; EPA = Environmental Protection Agency; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute.

TABLE 3-2 Physical and Chemical Properties of Selected Radium Compounds^a^

Property | Radium | Radium Bromide | Radium Carbonate | Radium Chloride | Radium Hydroxide | Radium Iodate | Radium Nitrate | Radium Sulfate
Chemical formula | Ra | RaBr_2_ | RaCO_3_ | RaCl_2_ | Ra(OH)_2_ | RaIO_3_ | RaNO_3_ | RaSO_4_
Molecular weight | 226.03 | 385.83 | 286.03 | 296.93 | No data | 575.83 | 350.04 | 382.08
Synonyms | No data | No data | Carbonic acid, radium salt | No data | No data | No data | Nitric acid, radium salt | Sulfuric acid, radium salt
CAS number | 7440-14-4 | 10031-23-9 | 7116-98-5 | 10025-66-8 | 98966-86-0 | No data | 10213-12-4 | 7446-16-4
Color | Silver-white | White | White | Yellowish-white | No data | No data | No data | White
Physical state | Solid | Solid | Solid | Solid | No data | No data | Solid | Solid
Melting point | 700°C | 728°C | No data | 1000°C | No data | No data | No data | No data
Boiling point | <1140°C | 900°C (sublimes) | No data | No data | No data | No data | No data | No data
Density at 20°C | 5 | 5.79 | No data | 4.91 | No data | No data | No data | No data
Odor | No data | No data | No data | No data | No data | No data | No data | No data
Odor threshold:
Water | No data | No data | No data | No data | No data | No data | No data | No data
Air | No data | No data | No data | No data | No data | No data | No data | No data
Solubility:
Water at 20°C | Decays | Soluble | Insoluble | Soluble | No data | Soluble | Soluble | Insoluble
Other solvents | Decays in acids | Soluble in alcohol | Decomposes in acids | Soluble in alcohol | No data | No data | No data | Insoluble in acids
Partition coefficients:
Log octanol/water | NA^b^ | NA | NA | NA | NA | NA | NA | NA
K_oc_ | NA | NA | NA | NA | NA | NA | NA | NA
Vapor pressure at 20°C | No data | No data | No data | No data | No data | No data | No data | No data
Henry’s law constant: | NA | NA | NA | NA | NA | NA | NA | NA
Autoignition temperature | No data | No data | No data | No data | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data | No data | No data | No data | No data
Flaomability limits | No data | No data | No data | No data | No data | No data | No data | No data
Conversion factors | No data | No data | No data | No data | No data | No data | No data | No data

a Sources: CHEMNAME 1989; Sax and Lewis 1987; Weast 1985; Windholz 1983.

b NA = not applicable

TABLE 3-3 Selected Radioactive Properties of Naturally OccurringIsotopes of Radium^a^

Isotope | Decay Mode | Decay Energy (MeV^b^) | Half-life
Radium-223 | alpha | 5.979 | 11.4 days
Radium-224 | alpha | 5.789 | 3.6 days
Radium-226 | alpha | 4.870 | 1600 years
Radium-228 | beta | 0.045 | 5.7 years

a Source: Weast 1985.

b Million electron volts

FIGURE 3-1 Uranium and Thorium Isotope Decay Series Showing the Sources and Decay Products of the Four Naturally-Occurring Radium Isotopes

Adapted from: Aieta et al. 1987.