# APPENDIX A PEER REVIEW

A peer review panel was assembled for radium. The panel consisted of the following members: Dr. Carmia Borek, Professor of Pathology, Columbia University; Dr. Douglas Crawford-Brown, Assistant Professor in the Department of Environmental Science, University of North Carolina; Dr. Haluk Ozkaynak, Lecturer, Harvard School of Public Health, Research Fellow, Energy and Environmental Policy Center, Kennedy School of Government, Harvard University; Dr. Ray Lloyd, Research Professor, Radiobiology Division, University of Utah. These experts collectively have knowledge of radium’s physical and chemical properties, toxicokinetics, key health end points, mechanisms of action, human and animal exposure, and quantification of risk to humans. All reviewers were selected in conformity with the conditions for peer review specified in Section 104(i)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

A joint panel of scientists from ATSDR and EPA has reviewed the peer reviewers’ comments and determined which comments will be included in the profile. A listing of the peer reviewers’ comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound. A list of databases reviewed and a list of unpublished documents cited are also included in the administrative record.

The citation of the peer review panel should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with the Agency for Toxic Substances and Disease Registry.