# 8 REFERENCES

*Cited in text

*Abe S, Sasaki M. 1977. Chromosome aberrations and sister chromatid exchanges in Chinese hamster cells exposed to various chemicals. J Nat1 Cancer Inst 58:1635–1641.
Abe S, Sasaki M. 1982. SCE as an index of mutagenesis and/or carcinogenesis. In: Sister chromatid exchanges. New York, NY: Alan R. Liss, Inc., 461–514.
*ACGIH. 1986. Documentation of the threshold limit values and biological exposure indices. 5th ed. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*Aeschbacher HU, Wolleb U, Loliger J, . 1989. Contribution of coffee aroma constituents to the mutagenicity of coffee. Food Chem ToxicOL 27:227–232.2659457
Ahlstrom R, Berglund B, Berglund U, . 1986. Impaired odor perception in tank cleaners. Stand J Work Environ Health 12:574–581.
*Albert A, Goldacre R, Phillips J. 1948. The strength of heterocyclic bases. J Chem Soc 2240–2249.
*Amoore JE, Hautala E. 1983. Odor as an aid to chemical safety: Odor thresholds compared with threshold limit values and volatilities for 214 industrial chemicals in air and water dilution. J Appl Toxicol 3:272–290.6376602
*Anderson RC. 1987. 90-Day subchronic oral toxicity in rats. Test material: Pyridine. Vol. I. Report to Dynamac Corporation, Rockville, MD, by Arthur D. Little, Inc., Cambridge, MA. EPA/530/SW-88/016A. NTIS No. PB88-176136.
Anonymous. 1957. Pyridine. Am Ind Hyg Assoc Quarterly 18:372–374.
Atkinson R. 1985. Kinetics and mechanisms of the gas-phase reactions of the hydroxyl radical with organic compounds under atmospheric conditions. Chem Rev 85:69–201.
*Atkinson R, Tuazon EC, Wallington TJ, . 1987. Atmospheric chemistry of aniline, N,N-dimethylaniline, pyridine, 1,3,5-triazine, and nitrobenzene. Environ Sci Technol 21:64–72.
*Audunsson G. 1988. Determination of low parts per billion levels of amines in urine by liquid membrane sample cleanup directly coupled to a gas-liquid chromatograph. Anal Chem 60:1340–1347.3213950
*Baker RA, Luh M-D. 1971. Pyridine sorption from aqueous solution by montmorillonite and kaolinite. Water Res 5:839–848.
Banerjee S, Howard PH. 1988. Improved estimation of solubility and partitioning through correction of UNIFAC-derived activity coefficients. Environ Sci Technol 22:839–841.22195671
*Barnes D, Bellin J, DeRosa C, . 1988. Reference dose (Rfd): Description and use in health risk assessments. Vol. I. Appendix A: Integrated risk information system supportive documentation. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA/600/8-86/032a.
*Battersby NS, Wilson V. 1989. Survey of the anaerobic biodegradation potential of organic chemicals in digesting sludge. Appl Environ Microbiol 55:433–439.16347851
Baxter JH. 1946. The mechanisms of the liver and kidney injury produced by toxic substances. I. Some effects of pyridine and their prevention by methionine [Abstract]. J Clin Invest 25:908.20282736
*Baxter JH. 1948. Hepatic and renal injury with calcium deposits and cirrhosis produced in rats by pyridine. Am J Pathol 24:503–525.18859356
Baxter JH. 1949. Pyridine liver and kidney injury in rats; the influence of diet, with particular attention to methionine, cystine, and choline. Bull Johns Hopkins Hospital 85:138–167.
*Baxter JH, Mason MF. 1947. Studies of the mechanisms of liver and kidney injury. IV. A comparison of the effects of pyridine and methyl pyridinium chloride in the rat. J Pharmacol Exp Ther 91:350–356.20273269
*Bayer CW, Black MS. 1987. Capillary chromatographic analysis of volatile organic compounds in the indoor environment. J Chromatogr Sci 25:60–64.3558698
Bederka JP, Davitiyananda D, Moses ML, . 1975. Drug-biomolecule interations: Drug toxicity and vitamin coenzyme depletion. J Pharm Sci 64:528–534.239196
*Bolonova LN. 1972. [Effect of acute pyridine poisoning on ammonia metabolism in the liver and kidneys.] Farmakol Toksikol 7:153–156. (Russian)
Bowra GT, Duffield DP, Osborn AJ, . 1982. Premalignant and neoplastic skin lesions associated with occupational exposure to “tarry” byproducts during manufacture of 4,4’-biphyridyl. Br J Ind Med 39:76–81.7066224
Bradish J. 1986. Pyridine spill. Fire Command 53:20–21.
*Brazda FG, Coulson RA. 1946. Toxicity of nicotinic acid and some of its derivatives. Proc Soc Exp Biol Med 62:19–20.20987553
*Bronstein AC, Currance PL. 1988. Emergency care for hazardous materials exposure. St. Louis, MO: The C.V. Mosby Company.
Browning E. 1965. Pyridine. In: Toxicity and metabolism of industrial solvents. New York, NY: Elsevier Publishing Company, 304–309.
*Brunnemann KD, Cox JE, Kagan MR, . 1991. Analysis of selected environmental tobacco smoke components in indoor air by thermal absorption-GCMS. Proc CORESTA 1990 Symposium (in press.)
*Cassidy RA, Birge WJ, Black JA. 1988. Biodegradation of three azaarene congeners in river water. Environ Toxicol Chem 7:99–105.
*CCTTE. 1988. Computerized listing of chemicals being tested for toxic effects. United Nations Environment Programme, International Programme on Chemical Safety, International Register of Potentially Toxic Chemicals, Geneva, Switzerland.
*Chao J, Lin CT, Chung TH. 1983. Vapor pressure of coal chemicals. J Phys Chem Ref Data 12:1033, 1059.
Chemical Manager. Test species include male and female B6C3F_1_ mice, Fischer-344N rats, and Wistar rats.
Chen TH, Kavanagh TJ, Chang CC, . 1984. Inhibition of metabolic cooperation in Chinese hamster V79 cells by various organic solvents and simple compounds. Cell Biol Toxic01 1:155–171.
Chiu CW, Lee LH, Wang CY, . 1978. Mutagenicity of some commercially available nitro compounds for [underlined: Salmonella tynhimurium]. Mutat Res 58:11–22.362191
Christensen HE, Luginbyhl TT, Carroll BS. 1974. The toxic substances list. Rockville, MD: U.S. Department of Health, Education, and Welfare, National Institute for Occupational Safety and Health, 673.
*Commoner H. 1976. Reliability of bacterial mutagenesis techniques to distinguish carcinogenic and noncarcinogenic chemicals. Report to U.S. Environmental Protection Agency, Office of Research and Development, Washington, DC, by Washington University, Center for the Biology of Natural Systems, St. Louis, MO. EPA-600/1-76-022. NTIS No. PB-259934.
*Cooper RL. Catchpole JR. 1973. The biological treatment of carbonization effluents - IV. The nitrification of coke-oven liquors and other trade wastes and the enhancement of biological oxidation of resistant organic compounds by the addition of growth factors to activated sludge. Water Res 7:1137–1153.
*Coulson RA, Brazda FG. 1948. Influence of choline, cystine, and methionine on toxic effects of pyridine and certain related compounds. Proc Soc Exp Biol Med 69:480–487.18122853
*Cupitt LT. 1980. Fate of toxic and hazardous materials in the air environment. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/3-80-084. NTIS No. PB80-221948.
*Curvall M, Enzell CR, Pettersson B. 1984. An evaluation of the utility of four [underlined: in vitro] short-term tests for predicting the cytotoxicity of individual compounds derived from tobacco smoke. Cell Biol Toxicol 1:173–193.6400922
*Damani LA, Crooks PA, Shaker MS . 1982. Species differences in the metabolic C- and N-oxidation, and N-methylation of [^14^C] pyridine in vivo. Xeniobiotica 12:527–534.
De Bruin A. 1976. Biochemical toxicology of environmental agents. Amsterdam, The Netherlands: Elsevier, 695, 869.
DeFlora S, Koch R, Strobe1 K, . 1985. A model based on molecular structure descriptors for predicting mutagenicity of organic compounds. Toxicol Environ Chem 10:157–170.
Derse PH. 1971. Injection of newborn mice with seven chemical adjuvants to help determine their safety in use in biologicals [Abstract]. Chem Abstr 75:242.
Dieter MP, Jameson CW, French JE, . 1989. Development and validation of a cellular transplant model for leukemia in Fischer rats: A short-term assay for potential anti-leukemic chemicals. Leuk Res 13:841–849.2796389
*Dobson KR, Stephenson M, Greenfield PF, . 1985. Identification and treatability of organics in oil shale retort water. Water Res 19:849–856.
*Donaldson EC, Cracker ME, Manning FS. 1975. Adsorption of organic compounds on cottage grove sandstone. Report to U.S. Energy Research and Development Administration, by Bartlesville Energy Research Center, Bartlesville, OK. BERG/RI-75/4.
*Dorfman IM, Adams GE. 1973. Reactivity of the hydroxyl radical in aqueous solutions. Washington, DC: U.S. Department of Commerce, National Bureau of Standards.
Dowden BF, Bennett HJ. 1965. Toxicity of selected chemicals to certain animals. J Water Pollut Control Fed 37:1308–1318.5825886
*D’Souza J, Caldwell J, Smith RL. 1980. Species variations in the N-methylation and quaternization of [^14^C] pyridine. Xenobiotica 10:151–157.7395267
*Dubowski KM. 1975. Organic volatile substances. In: Sunshine I, ed. Methodology for analytical toxicology. Cleveland, OH: CRC Press, 407–411.
*">Dumont J-P, Adda J. 1978. Occurrence of sesquiterpenes in mountain cheese volatiles. J Agric Food Chem 26:364–367.
*Eatough DJ, Benner CL, Bayona JM, . 1989. Chemical composition of environmental tobacco smoke: 1. Gas-phase acids and bases. Environ Sci Technol 23:679–687.
*Eckel WP. 1990. Written communication (January 5) to Linda A. Hashlamoun, Life Systems, Inc., regarding CLP Statistical Database information on pyridine. Viar and Company, Management Services Division, Alexandria, VA.
*EPA. 1978. Second report of the TSCA interagency testing committee to the administrator, Environmental Protection Agency. Washington, DC: Office of Toxic Substances.
*EPA. 1980. U.S. Environmental Protection Agency. Federal Register 45:33132–33133.
*EPA. 1982a. U.S. Environmental Protection Agency. Federal Register 47:26992, 27007–27008.
*EPA. 1982b. U.S. Environmental Protection Agency. Federal Register 47:58031–58035.
EPA. 1983. Reportable quantity document for pyridine. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. ECAO-CIN-R182.
*EPA. 1986a. Gas chromatography/mass spectrometry for volatile organics - method 8240. In: Test methods for evaluating solid waste. Vol. IA: Laboratory manual, physical/chemical methods. 3rd ed. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1986b. Gas chromatography/mass spectrometry for semivolatile organics: Capillary column technique - method 8270. In: Test methods for evaluating solid waste. SW-846. Washington, DC: U.S. Environmental Protection, Agency, Office of Solid Waste and Emergency Response.
*EPA. 1987. U.S. Environmental Protection Agency: Part II. Federal Register 52:25942–25951.
*EPA. 1988a. U.S. Environmental Protection Agency: Part II. Federal Register 53:4500–4501.
*EPA. 1988b. U.S. Environmental Protection Agency: Part V. Federal Register 53138642-38646.
*EPA. 1989a. Interim methods for development of inhalation reference doses Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA 600/8-88/066F.
*EPA. 1989b. U.S. Environmental Protection Agency: Part II. Federal Register 54:48372–48376, 48525–48528.
*EPA. 1989c. U.S. Environmental Protection Agency: Part V. Federal Register 54:33418–33421, 33464.
*Ettinger MB, Lishka RJ, Kroner RC. 1954. Persistence of pyridine bases in polluted water. Ind Eng Chem 46:791–793.
*Felice LJ, Zachara JM, Schmidt RL. 1984. Quinoline partitioning in subsurface materials - adsorption, desorption, and solute competition. Report to U.S. Department of Energy, by Pacific Northwest Laboratory, Richland, WA. DE84-01073.
Fisher AA. 1973. Contact dermatitis. 2nd ed. Philadelphia, PA: Lea and Febiger, 296, 402–403.
*Florin I, Rjuberg L, Durvall M, . 1980. Screening of tobacco smoke constituents for mutagenicity using the Ames’ Test. Toxicology 15:219–232.7008261
*Frei RW, Beall K, Cassidy RM, 1974. Determination of aromatic nitrogen heterocycles in air samples by high-speed liquid chromatography. Microchim Acta 5:859–869.
French JE, Dieter MP, Stefanski SA. 1987. Altered expression of transplanted leukemia in Fischer rats pretreated with pyridine (pyr) [Abstract]. Symposium on recent advances in leukemia and lymphoma held at the 16th annual meeting of the UCLA (University of California-Los Angeles) Symposia on molecular and cellular biology, Los Angeles, CA, January 25-31, 1987. J Cell Biochem (Suppl. 11A):192.
Gehring PJ. 1983. Pyridine, homologues and derivatives. In: Parmeggiani L, ed. Encyclopaedia of Occupational Health and Safety. Vol. 2. L-Z. 3rd ed. Geneva, Switzerland: International Labour Office, 1810–1812.
*Gerike P, Fischer WK. 1979. A correlation study of biodegradability determinations with various chemicals in various tests. Ecotoxicol Environ Safety 3:159–173.120246
*Gerike P, Fischer WK. 1981. A correlation study of biodegradability determinations with various chemicals in various tests. II. Additional results and conclusions. Ecotoxicol Environ Safety 5:45–55.7472255
Goe GL. 1978. Pyridine and pyridine derivatives. In: Kirk-Othmer encyclopedia of chemical technology. Vol. 19. Powder coatings to recycling. 3rd ed. New York, NY: John Wiley and Sons, 454–483.
*Gomolka B, Gomolka E. 1978. The effect of final products of pyridine biodegradation on chemical characteristics of aerated municipal wastewater. Environment Protection Engineering 4:339–357.
*Gorrod JW, Damani LA. 1980. The metabolic N-oxidation of 3-substituted pyridines in various animal species in vivo. Eur J Drug Metab Pharmacokinet 5:53–57.7389753
Gosselin RE, Smith RP, Hodge HC. 1984. Clinical toxicology of commercial products. 5th ed. Baltimore, MD: Williams and Wilkins, 11–408.
Govers H, de Voogt P. 1986. Indices for the prediction of environmental properties of heteroatomic polycyclic aromatic pollutants. Comm Eur Eur 10388 Org Micropollut Aquat Environ 475–483.
*Green DR, Le Pape D. 1987. Stability of hydrocarbon samples on solid-phase extraction columns. Anal Chem 59:699–703.
*Hakuta T, Negishi A, Goto T, . 1977. Vapor-liquid equilibria of some pollutants in aqueous and saline solutions. Part I: Experimental results. Desalination 21:11–21.
*Harper BL, Ramanujam VM, Gad-El-Karim MM, . 1984. The influence of simple aromatics on benzene clastogenicity. Mutat Res 128:105–114.6472309
*Harper D, Brown ES, Pratt J. 1985. Initial market profile of existing pyridines. Report to U.S. Environmental Protection Agency, Office of Toxic Substances, by Centaur Associates, Inc.
*Hassett JJ, Banwart WL, Griffin RA. 1983. Correlation of compound properties with sorption characteristics of nonpolar compounds by soils and sediments: Concepts and limitations. In: Francis CW, Auerbach SI, Jacobs VA, ed. Environment and solid wastes: Characterization, treatment, and disposal. Boston, MA: Butterworths, 161–176.
*Haugen DA, Peak MJ, Suhbler KM, . 1982. Isolation of mutagenic aromatic amines from a coal conversion oil by cation exchange chromatography. Anal Chem 54:32–37.
Haworth S, Lawlor T, Mortelmans K, . 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen (Suppl 1):3–142.
*Hawthorne SB, Sievers RE. 1984. Emission of organic air pollutants from shale oil wastewaters. Environ Sci Technol 18:483–490.22247953
*Hawthorne SB, Sievers RE, Barkley RM. 1985. Organic emissions from shale oil wastewaters and their implications for air quality. Environ Sci Technol 19:992–997.
Heene R. 1968. [Histochemische undmorphologische Befunde bei experimenteller Myopathie 2,1-Dichlorphenoxyacetate (2,4-D) beim Warmbluter]. Acta Neuropathologica 10:166–169. (German)4236801
*Helme GE. 1893. Reports on medical and surgical practice in the hospitals and asylums of Great Britain, Ireland, and The Colonies. A fatal case of pyridine poisoning, Brit Med J 2:844.
Heukelekian H, Rand MC. 1955. Biochemical oxygen demand of pure organic compounds: A report of the research committee, FSIWA. J Water Pollut Control Assoc 29:1040–1053.
His W. 1987. Ueber das stoffwechselproduct des pyridins. 254–260.
*">Ho C-T, Lee KN, Jin QZ. 1983. Isolation and identification of volatile flavor compounds in fried bacon. J Agric Food Chem 31:336–342.
*HSDB. 1989. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. December 15, 1989.
Huh K, Lee SI, Park JM, . 1986. Effect of glycyrrhetinic acid on pyridine toxicity in mouse. Korean J Toxicol 2:31–36.
Humenick MJ, Britton LN. 1982. Natural restoration of ground water in UCG. In Situ 6:107–125.
*IJC. 1983. An inventory of chemical substances identified in the Great Lakes ecosystem. Vol. 1. Summary. Windsor, Ontario: International Joint Commission, Great Lakes Regional Office.
*IRIS. 1989. Integrated Risk Information System. U.S. Environmental Protection Agency, Washington, DC. December 15, 1989.
IRPTC. 1990. International Register of Potentially Toxic Chemicals. United Nations Environment Programme, Geneva, Switzerland. February 1990.
*Ishidate M, Odashima S. 1977. Chromosome tests with 134 compounds on Chinese hamster cells in vitro - a screening for chemical carcinogens. Mutat Res 48:337–354.876270
*James RH, Adams RE, Finkel JM, . 1985. Evaluation of analytical methods for the determination of POHC in combustion products. J Air Pollut Control Assoc 35:959–969.
*Jori A, Calamari D, Cattabeni F, . 1983. Ecotoxicological profile of pyridine. Working party on ecotoxicological profiles of chemicals. Ecotoxicol Environ Safety 7:251–275.6872912
Junk GA, Ford CS. 1980. A review of organic emissions from selected combustion processes. Chemosphere 9:187–230.
Kaul KL, Novak RF. 1987. Inhibition and induction of rabbit liver microsomal cytochrome P-450 by pyridine. J Pharmacol Exp Ther 243:384–390.3668864
Kawachi T, Komatsu T, Kada T, . 1980a. Results of recent studies on the relevance of various short-term screening tests in Japan, In: The predictive value of short-term screening tests in carcinogenicity evaluation. Appl Methods Oncol 3:253–267.
Kawachi T, Yahagi T, Kada T, . 1980b. Cooperative program on short-term assays for carcinogenicity in Japan. In: IARC Scientific Publication 27. International Agency for Research on Cancer, 323–330.
*Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotoxicol Environ Safety 4:26–38.7379718
*Kenaga E, Goring CA. 1980. Relationship between water solubility, soil sorption, octanol-water partitioning, and concentration of chemicals in biota. In: Eaton JG, Parrish PR, Hendricks AC, ed. Aquatic toxicology, ASTM STP 707. Philadelphia, PA: American Society for Testing and Materials, 78–115.
*King JW. 1989. Fundamentals and applications of supercritical fluid extraction in chromatographic science. J Chromatogr Sci 27:355–364.
Klaassen CD, Amdur MO, Doull J, ed. 1986. Casarett and Doull’s toxicology: The basic science of poisons. 3rd ed. New York, NY: Macmillan Publishing Company, 78, 486.
Kobler AR, Wilkie MB, Wolff TJ, . 1981. Description of bioassay results and projection of bioassay study needs in support of a major synfuels industry. Proc Symp Process Meas Environ Assess, 2nd. U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/9-81-018, 17–40.
Kondratyuk VA. 1974. [Effect of pyridine dissolved in water on the gastric and intestinal mucosa of experimental animals.] Gig Sanit 87–88. (Russian)
*Krone CA, Burrows DG, Brown DW, . 1986. Nitrogen-containing aromatic compounds in sediments from a polluted harbor in Puget Sound. Environ Sci Technol 20:1144–1150.
*Krotoszynski BK, O’Neill HJ. 1982. Involuntary bioaccumulation of environmental pollutants in nonsmoking heterogenous human population. J Environ Sci Health 17:855–883.
Kutscher F, Lohmann A. 1907. [Das vorkommen von pyridinmethylchlorid im menschlichen harn und seine beziehungen zu den genu mitteln tabak und kaffee.] 2 Unters Nahr Genus 13:177–179. (German)
Kuzelova M, Kubenova K, Kovarik J. 1975. [Unusual picture of acute pyridine poisoning.] Pracov Lek 27:207–209. (Russian)
Landauer W, Salam N. 1973. Quantitative and qualitative distinctions in developmental interference produced by various substituted pyridines. Molecular shape and teratogenicity as studied on chicken embryos. Acta Embryo1 Exp (Issue 2):179–197.
*Landauer W, Salam N. 1974. Experimental production in chicken embryos of muscular hypoplasia and associated defects of beak and cervical vertebrae. Acta Embryo1 Exp (Issue 1):51–66.
*Leenheer JA, Stuber HA. 1981. Migration through soil of organic solutes in an oil-shale process water. Environ Sci Technol 15:1467–1475.
*Leo A, Hansch C, Elkins D. 1971. Partition coefficients and their uses. Chem Rev 71:525–563.
*Lucas SV. 1984. GC/MS analysis of organics in drinking water concentrates and advanced waste treatment concentrates: Vol. 1. Analysis results for 17 drinking water, 16 advanced waste treatment and 3 process blank concentrates. Report to U.S. Environmental Protection Agency, Office of Research and Development, Research Triangle Park, NC, by Battelle Columbus Laboratories, Columbus, OH. EPA-600/1-84-020a. NTIS No. PB85-128221.
*">Luh M-D, Baker RA. 1971. Sorption and desorption of pyridine-clay in aqueous solution. Water Res 5:849–859.
*MacLeod AJ, Snyder CH. 1988. Volatile components of mango preserved by deep freezing. J Agric Food Chem 36:137–139.
*Malaney GW. 1960. Oxidative abilities of aniline-acclimated activated sludge. J Water Pollut Control Fed 32:1300–1311.
*Mani I, Sauer MC. 1968. A pulsed-radiolysis study of the gas-phase reaction of oxygen atoms with benzene and related compounds: Rate constants and transient spectra. Adv Chem Series 82:142–152.
Mason MM. 1969. Toxicology and carcinogenesis of various chemicals used in the preparation of vaccines. Report to National Institutes of Health, Division of Biologics Standards, Bethesda, MD, by Mason Research Institute, Worcester, MA. NTIS No. PB195158.
*Mason MM, Cate CC, Baker J. 1971. Toxicology and carcinogenesis of various chemicals used in the preparation of vaccines. Clin Toxicol 4:185–204.
McGregor DB, Brown A, Cattanach P, . 1988. Responses of the L5178Y tk+/tk- mouse lymphoma cell forward mutation assay II: 18 coded chemicals. Environ Mol Mutagen 11:91–118.3338442
*Michael LC, Pellizari ED, Wiseman RW. 1988. Development and evaluation of a procedure for determining volatile organics in water. Environ Sci Technol 22:565–570.22195629
*Mill T, Hendry DG, Richardson H, . 1979. Chemical oxidation processes in aquatic systems: Oxidation of cumene, pyridine, and p-cresol. Report to Nation Science Foundation, Directorate for Applied Science and Research Applications, Washington, DC, by Stanford Research Institute International, Physical Organic Chemistry Department, Menlo Park, CA. NSF/RA-790085. NTIS No. 298088.
*Moore FW. 1949. The utilization of pyridine by micro-organisms. J Gen Microbial 3:143–147.
Moustacchi E, Carere A, Morpurgo G. 1986. Report 11: Assays for genetic changes in fungi. In: Montesano R, . ed. Long-term and short-term assays for carcinogens: A critical appraisal. IARC Sci Publ No. 83. New York, NY: Oxford University Press, 303–350.
Mukhtar H, Link CM, Cherniack E, . 1982. Effect of topical application of defined constituents of coal tar on skin and liver aryl hydrocarbon hydroxylase and 7-ethoxycoumarin deethylase activities. Toxicol Appl Pharmacol 64:541–549.6982545
*Naik MN, Jackson RB, Stokes J, . 1972. Microbial degradation and phytotoxicity of picloram and other substituted pyridines. Soil Biol Biochem 4:313–323.
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press.
*NATICH. 1989. National Air Toxics Information Clearinghouse: NATICH database report on state, local, and EPA air toxics activities. Report to U.S. Environmental Protection Agency, Research Triangle Park, NC, by Radian Corporation, Austin, TX.
*Neely WB, Branson DR, Blau GE. 1974. Partition coefficient to measure bioconcentration potential of organic chemicals in fish. Environ Sci Technol 8:113–115.
*Neff JS. 1886. Pyridine in the treatment of asthma. NY Med J (March 18):299–301.
*NIOSH. 1984. Pyridine-method 2505. In: NIOSH manual of analytical methods. 3rd ed. Cincinnati, OH: National Institute for Occupational Safety and Health. DHHS (NIOSH) Publication No. 84–100.
*NIOSH. 1985. Pocket guide to chemical hazards. Washington, DC: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health.
*NLM. 1989. Chemline. National Library of Medicine, Bethesda, MD. December 15, 1989.
*NOES. 1990. National Occupational Exposure Survey. National Institute of Occupational Safety and Health, Cincinnati, OH. January 3, 1990.
*NOHS. 1990. National Occupational Hazard Survey. National Institute of Occupational Safety and Health, Cincinnati, OH. January 23, 1990.
*NSC. 1978. Data sheet: Pyridine. Chicago, IL: National Safety Council
*OSHA. 1989. U.S. Department of Labor. Occupational Safety and Health Administration: Part III. Federal Register 54:2332–2335, 2950.
Pai V, Bloomfield SF, Jones J, . 1978. Mutagenicity testing of nitrogenous compounds and their N-oxidized products using TRP^+^ reversion in [underlined: E. coli] In: Gornod JW, ed. Biological oxidation of nitrogen. Gand Biomedical Press, 375–382. Elsevier/North-Holland Biomedical Press, 375–382.
*Pankow JF, Rosen ME. 1988. Determination of volatile compounds in water by purging directly to a capillary column with whole column cryotrapping. Environ Sci Technol 22:398–405.
*Pellizzari ED, Castillo NP, Willis S, . 1979. Identification of organic components in aqueous effluents from energy-related processes. In: Van Hall GE, ed. Measurement of organic pollutants in water and wastewater. American Society for Testing and Materials. ASTM STP 686, 256–274.
Perrin DD. 1964. The effect of temperature on pK values of organic bases. Aust J Chem 17:484–488.
Perrin DD. 1965. Dissociation constants of organic bases in aqueous solution. London, England: Butterworths, 178–183.
*Pinsky C, Bose R. 1988. Pyridine and other coal tar constituents as free radical-generating environmental neurotoxicants. Mol Cell Biochem 84:217–222.3231223
*Pollock LJ, Finkelman I, Arieff AJ. 1943. Toxicity of pyridine in man. Arch Intern Med 71:95–106.
Proctor NH, Hughes JP, Fischman ML. 1988. Chemical hazards of the workplace. 2nd ed. Philadelphia, PA: J.B. Lippincott Company.
*Reinhardt CF, Brittelli MR. 1981. Patty’s industrial hygiene and toxicology. Volume 2A: Toxicology. 3rd ed. New York, NY: John Wiley and Sons, 2727–2732.
*Riebe M, Westphal K, Fortnagel P. 1982. Mutagenicity testing, in bacterial test systems, of some constituents of tobacco. Mutat Res 101:39–43.7043247
Rivera RL. 1990. Written communication (March 13) to Barry L. Johnson, Agency for Toxic Substances and Disease Registry, regarding Oregon-specific information on hazardous substances. Department of Environmental Quality, State of Oregon, Portland, OR.
Roberts PV, Reinhard M, Valocchi AJ. 1982. Movement of organic contaminants in groundwater: Implications for water supply. J Am Water Works Assoc 74:408–413.
*Roeraade J, Blomberg S. 1989. New methodologies in trace analysis of volatile organic compounds. J High Resolut Chromatogr 12:138–141.
Roubickova J. 1986. [Biological treatment of waste water with higher concentrations of pyridine bases.] Vodni Hospod B 36:271–277. (Czech)
*Roy WR, Griffin RA. 1985. Mobility of organic solvents in water-saturated soil materials. Environ Geol Water Sci 7:241–247.
*Ruffo C, Galli E, Arpino A. 1984. Comparison of methods for the biodegradability evaluation of soluble and insoluble organ0 chemicals. Ecotoxicol Environ Safety 8:275–279.6734504
Ruth JH. 1986. Odor thresholds and irritation levels of several chemical substances: A review. Am Ind Hyg Assoc J 47:A-142–A-151.3706135
*Santodonato J, Bosch S, Meylan W, . 1985. Monograph on human exposure to chemicals in the workplace: Pyridine. Report to National Cancer Institute, Division of Cancer Etiology, Bethesda, MD, by Syracuse Research Corporation, Syracuse, NY. NTIS No. PB86-143385/AS.
*Sasai H, Tsukioka T. 1981. [Determination of trace amount of pyridine by gas chromatography.] Nagano-ken Eisei Kogai Kenkyusho Kenkyu Hokuku 3155–57. (Japanese)
*Sax NI. 1984. Dangerous properties of industrial materials. 6th ed. New York, NY: Van Nostrand Reinhold Company, 2325.
*Sax NI, Lewis RJ. 1987. Hawley’s condensed chemical dictionary. New York, NY: Van Nostrand Reinhold Company, 982.
Schultz TW, Allison TC. 1979. Toxicity and toxic interaction of aniline and pyridine. Bull Environ Contam Toxic01 23:814–819.
*Seixas GM, Andon BM, Hollingshead PG, . 1982. The aza-arenes as mutagens for [underlined: Salmonella typhimurium]. Mutat Res 102:201–212.6755231
*Shackelford WM, Keith LH. 1976. Frequency of organic compounds identified in water. Athens, GA: U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/4-76-062.
*Shah JJ, Heyerdahl EK. 1988. National ambient volatile organic compounds (VOCs) database update. Report to U.S. Environmental Protection Agency, Office of Research and Development, Research Triangle Park, NC, by Nero and Associates, Inc., Portland, OR. EPA/600/3-88/010a. NTIS No. PB88-195631.
*Shaker MS, Crooks PA, Damani LA. 1982. High-performance liquid chromatographic analysis of the [underlined: in vivo] metabolites of [^14^C]pyridine. J Chromatogr 237:489–495.7096490
*Shibamoto T, Kamiya Y, Mihara S. 1981. Isolation and identification of volatile compounds in cooked meat: Sukiyaki. J Agric Food Chem 29:57–63.
*Sims GK, Sommers LE. 1985. Degradation of pyridine derivatives in soil. J Environ Qua1 14:580–584.
Sittig M. 1985. Handbook of toxic and hazardous chemicals and carcinogens. 2nd ed: Park Ridge, NJ: Noyes Publications.
Sklarew DS, Hayes DJ. 1984. Trace nitrogen-containing species in the offgas from two oil shale retorting processes. Environ Sci Technol 18:600–603.22300057
*Smith JN. 1953. Studies in detoxication. 53. The glucoronic acid conjugation of hydroxyquinolines and hydroxypyridines in the rabbit. Biochem J 55:156–160.13093633
*Smith RM. 1988. Supercritical fluid chromatography. Letchworth, England. Royal Society of Chemistry.
*Smyth HF, Carpenter CP, Weil CS. 1951. Range-finding toxicity data: List IV. AMA Arch Ind Hyg Occup Med 4:119–122.14856438
*Spoerke DS. 1991. Pyridine MEDITEXT Medical Management. In: Hall AH, Rumack BH (eds.). TOMES Plus Information System, Micromedex, Inc.; Denver, co. (Edition expires 7/31/91).
*SRI. 1986. Directory of chemical producers: United States of America. Menlo Park, CA: SRI International, 957.
*SRI. 1987. Directory of chemical producers: United States of America. Menlo Park, CA: SRI International, 944–945.
*SRI. 1988. Directory of chemical producers: United States of America. Menlo Park, CA: SRI International, 924.
SRI. 1989. Directory of chemical producers: United States of America. Menlo Park, CA: SRI International, 930.
Stoeber H, Wacker L. 1910. [Ein weiterer beitrag zur erzeugung atypischer epithel-wucherungen mit eiweissfaulnisproducklen.] Munch Med Wochnschr 57:947–950. (German)
Stokinger, HE. 1981. Patty’s industrial hygiene and toxicology. Volume 2B: Toxicology. 3rd ed. New York, NY: John Wiley and Sons, 2886, 3291.
*Stuermer DH, Ng DJ, Morris CJ. 1982. Organic contaminants in groundwater near an underground coal gasification site in northeastern Wyoming. Environ Sci Technol 16:582–587.22284199
*Tang J, Jin QZ, Shen G-H, . 1983. Isolation and identification of volatile compounds from fried chicken. J Agric Food Chem 31:1287–1292.
Teisinger J. 1948. Mild chronic intoxication with pyridine [Abstract]. J Ind Hyg Toxicol 30:58.
Totani G, Hoshigi Z. 1910. [Uber das verhalten des pyridins im organismus der ziege und des schweins.] Hoppe-Seyl Z Physiol Chem 68:83–84. (German)
*TRI. 1989. Toxic Chemicals Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
Tsurumi K, Kyuki K, Nose T. 1987. [Acute toxicity and the ability to induce delayed type hypersensitivity in mice of pyridine derivatives.] Oyo Yakuri 33:825–830. (Japanese)
USITC. 1988, Synthetic organic chemicals: United States production and sales, 1987. Washington, DC: U.S. International Trade Commission. USITC Publication 2118.
Venkatakrishna-Bhatt H, Shah MP, Kashyap SK. 1975. Toxicological effects of intravenous administration of pyridine in anaesthetized dogs. Toxicology 4:165–169.1154421
*Vernot EH, MacEwen JD, Haun CC, . 1977. Acute toxicity and skin corrosion data for some organic and inorganic compounds and aqueous solutions. Toxicol Appl Pharmacol 42:417–423.595018
*View Database. 1989. Agency for Toxic Substances and Disease Registry (ATSDR), Office of External Affairs, Exposure and Disease Registry Branch, Atlanta, GA. September 25, 1989.
*Verschueren K. 1983. Handbook of environmental data on organic chemicals. 2nd ed. New York, NY: Van Nostrand Reinhold Company, 1035–1038.
*Weast RC, ed. 1985. CRC handbook of chemistry and physics. Boca Raton, FL: CRC Press, Inc., C-462.
*Wieboldt RC, Adams GE, Later DW. 1988. Sensitivity improvement in infrared detection for supercritical fluid chromatography. Anal Chem 60:2422–2427.
Windholz M, ed. 1983. The Merck index: An encyclopedia of chemicals, drugs, and biologicals. 10th ed. Rahway, NJ: Merck and Company, Inc., 1149–1150.
*Zachara JM, Ainsworth CC, Cowan CE, . 1987. Sorption of binary mixtures of aromatic nitrogen heterocyclic compounds on subsurface materials. Environ Sci Technol 21:397–402.22280181
Zimmermann FK, Groschel-Stewart U, Scheel I, . 1985. Genetic change may be caused by interference with protein-protein interactions. Mutat Res 150:203–210.3889615
Zimmermann FK, Henning JH, Scheel I, . 1986. Genetic and anti-tubulin effects induced by pyridine derivatives. Mutat Res 163:23–31.3528830