# 7 REGULATIONS AND ADVISORIES

Because of its potential to cause adverse health effects in exposed people, a number of regulations and guidelines have been established for pyridine by various national and state agencies. These values are summarized in Table 7-1.

TABLE 7-1 Regulations and Guidelines Applicable to Pyridine

Agency | Description | Information | References
[underlined: NATIONAL]
Regulations:
a. Air:
OSHA | PEL TWA | 5 ppm (15 mg/m^3^) | OSHA 1989 (29 CFR 1910.1000) Table Z-1-A
b. Food:
FDA | Food additive - synthetic flavoring substance component of polycarbonate | Yes | 21 CFR 172.515
FDA | resins - indirect food additive | Yes | 21 CFR 177.1580
c. Other:
EPA OERR | Reportable quantity | 1,000 lbs | EPA 1989c (40 CFR 302.4)
EPA OSW | Hazardous Waste Constituent (Appendix VIII) | Yes | EPA 1980 (40 CFR 261)
EPA OSW | Groundwater monitoring list (Appendix IX) | Yes | EPA 1987 (40 CFR 264)
EPA OSW | Land disposal restrictions (proposed) | Yes | EPA 1989b (40 CFR 268)
EPA OTS | Toxic chemical release reporting rule | Yes | EPA 1988a (40 CFR 372)
EPA OTS | Health and safety data reporting rule | Yes | EPA 1988b (40 CFR 716.120)
EPA OTS | Preliminary assessment information reporting rule | Yes | EPA 1982a (40 CFR 712.30)
Guidelines:
a. Air:
ACGIH | TLV TWA STEL | 5 ppm (15 mg/m^3^); 10 ppm (30 mg/m^3^) | ACGIH 1986
NIOSH | IDLH | 3,600 ppm | NIOSH 1985
b. Other:
EPA | Oral RfD | 1×10^−3^ mg/kg/day | IRIS 1989
[underlined: STATE]
Regulations and guidelines:
a. Air: | Acceptable ambient air concentrations | | NATICH 1989
Connecticut | | 300 μg/m^3^ (8 hr)
Florida (Tampa) | | 0.3 μg/m^3^ (8 hr)
Indiana | | 150 μg/m^3^ (8 hr)
Xansas | | 35.7 μg/m^3^ (annual;
Nevada | | 0.357 μg/m^3^ (8 hr)
New York | | 2.0 μg/m^3^ (1 yr)
North Dakota | | 0.30 μg/m^3^ (18 hr)
Vermont | | 0.15 μg/m^3^ (8 hr)
Virginia | | 357 μg/m^3^ (annual); 250 μg/m^3^ (24 hr)

ACGIH = American Conference of Governmental Industrial Hygienists; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; IDLH = Immediately Dangerous to Life or Health Level; NIOSH = National Institute for Occupational Safety and Healthi ODW = Office of Drinking Water; OERR = Office of Emergency and Remedial Response; OSHA = Occupational Safety and Health Administration; OSW = Office of Solid Wastes; OTS = Office of Toxic Substances; PEL = Permissible Exposure Limit; RfD = reference dose; STEL = Short Term Exposure Limit; TLV = Threshold Limit Value; TWA = Time-Weighted Average