# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Table 3-1 lists common synonyms, trade names, and other pertinent identification information for pyridine.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Table 3-2 lists important physical and chemical properties of pyridine.

TABLE 3-1 Chemical Identity of Pyridine

Characteristic | Information | Reference
Chemical name | Pyridine | Weast 1985
Synonyms | Azabenzene; azine | Sax and Lewis 1987
Trade names | No data
Chemical formula | C_5_H_5_N | Weast 1985
Chemical structure | [image]
Identification numbers:
CAS registry | 110-86-1 | Sax and Lewis 1987
NIOSH RTECS | UR 8400000 | Sax 1984
EPA hazardous waste | F005 | HSDB 1989
EPA hazardous waste | U196 | HSDB 1989
OHM/TADS | 7216879 | HSDB 1989
DOT/UN/NA/IMCO shipping | UN1282 | HSDB 1989
DOT/UN/NA/IMCO shipping | IMCO 3.0 | HSDB 1989
DOT/UN/NA/IMCO shipping | IMCO 6.1 | HSDB 1989
HSDB | 0118 | HSDB 1989
NCI | C55301 | NLM 1989

CAS = Chemical Abstracts Service; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and HazardousMaterials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

TABLE 3-2 Physical and Chemical Properties of Pyridine

Property | Information | Reference
Molecular weight | 79.10 | Weast 1985
Color | Slightly yellow to colorless | Sax and Lewis 1987
Physical state | Liquid | Sax and Lewis 1987
Melting point | −42°C | Weast 1985
Boiling point | 115.5°C | Weast 1985
Density at 20°C | 0.9819 | Weast 1985
Odor | Nauseating | Sax and Lewis 1987
Odor threshold:
Water | 0.95 mg/L | Amoore and Hautala 1983
Air | 0.17 ppm | Amoore and Hautala 1983
Solubility:
Water at 20°C | Very soluble | Sax and Lewis 1987
Organic solvents | Soluble in alcohol, ether, benzene | Sax and Lewis 1987
Partition coefficients:
Log K_ow_ | 0.64/1.04 | Verschueren 1983
Log K_oc_ | 0.84 | Roy and Griffin 1985
Vapor pressure at 13.2°C | 10 mmHg | Sax 1984
at 20°C | 14 mmHg | Verschueren 1983
at 25.5 °C | 20.6 mmHg | Chao et al. 1983
at 30°C | 26 mmHg | Verschueren 1983
Henry’s law constant: | 1.1×10^−5^ atm-m^3^-mole^−1^ (25°C) | Hawthorne et al. 1985
Autoignition temperature | 900°F (482°C) | Sax and Lewis 1987
Flashpoint | 68°F (20°C) (closed cup) | Sax and Lewis 1987
Flammability limits | Lower 1.8, upper 12.4 | HSDB 1989
Conversion factors | 1 mg/m^3^ = 0.30 ppm | Verschueren 1983
Conversion factors | 1 ppm = 3.29 mg/m^3^ | Verschueren 1983
Explosive limits | 1.8–12.4% | Sax and Lewis 1987
pKa | 5.19 | Reinhardt and Brittelli 1981