# 9 REFERENCES

* Cited in text

*Abd El-Aziz MI, Sahlab AM, Abd El-Khalik M. 1994. Influence of diazinon and deltamethrine on reproductive organs and fertility of male rats. Dtsch Tieräerztl Wochenshr 101:213–248.
*Abd El-Khalek MM, Rahmy NA, Haleem HH. 1999. Effect of the pyrethroid insecticide cypermethrin on fertility in male rats. Vet Med J Giza 47(3):295–305.
Abd El-Raheem K, El-Elaimy I, El-Mossallamy N, . 1987. Biochemical responses to induced intoxication with insecticides: 1. Effect of acute and repeated administration of pyrethroid (ripcord). Proc Zool Soc AR Egypt 13:141–156.
*Abdel-Khalik MM, Hanafy MSM, Abdel-Aziz MI. 1993. Studies on the teratogenic effects of deltamethrin in rats. Dtsch Tieräerztl Wochenshr 100:129–168.
Abdel-Rahman A, Shetty AK, Abdou-Donia MB. 2001. Subchronic dermal application of N,N-diethyl m-toluamide (DEET) and permethrin to adult rats, alone or in combination, causes diffuse neuronal cell death and cytoskeletal abnormalities in the cerebral cortex and the hippocampus, and purkinje neuron loss in the cerebellum. Exp Neurol 172:153–171.11681848
Abernathy CO, Ueda K, Engel JL, . 1973. Substrate-specificity and toxicological significance of pyrethroid-hydrolyzing esterases of mouse liver microsomes. Pestic Biochem Physiol 3:300–311.
Abou-Donia MB, Goldstein LB, Dechovsaia A, . 2001. Effects of daily dermal application of DEET and permethrin, alone and in combination, on sensorimotor performance, blood-brain barrier, and blood-tests barrier in rats. J Toxicol Environ Health 62:523–541.
Abou-Donia MB, Wilmarth KR, Jensen KF, . 1996. Neurotoxicity resulting from coexposure to pyridostigmine bromide, DEET, and permethrin: Implications of Gulf War chemical exposures. J Toxicol Environ Health 48:35–56.8637057
*Abu-Qare AW, Abou-Donia MB. 2001a. Combined exposure to DEET (N,N-diethyl-m-toluamide) and permethrin-induced release of rat brain mitochondrial cytochrome c. J Toxicol Environ Health 63:243–252.
Abu-Qare AW, Abou-Donia MB. 2001b. DEET (N,N-diethyl-m-toluamide) alone and in combination with permethrin increased urinary excretion of 6β-hydroxycortisol in rats, a marker of hepatic CYP3A induction. J Toxicol Environ Health A 64:373–384.11700004
Abu-Qare AW, Abou-Donia MB. 2003. Combined exposure to DEET (N,N-diethyl-m-toluamide) and permethrin: Pharmacokinetics and toxicological effects. J Toxicol Environ Health B 6:41–53.
*ACGIH. 2000. TLVs and BEIs: Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
*Adamis Z, Antal A, Füzesi I, . 1985. Occupational exposure to organophosphorus insecticides and synthetic pyrethroid. Int Arch Occup Environ Health 56:299–305.4066053
*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
*Agarwal DK, Chauhan LKS, Gupta S, . 1994. Cytogenetic effects of deltamethrin on rat bone marrow. Mutat Res 311:133–138.7526166
*Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Federal Register 54 (174):37618–37634.
*Agnihotri NP, Jain HK. 1987. Persistence of flucythrinate and fluvalinate in soil, water and sediment. Pesticides 21(6):36–38.
Agnihotri NP, Jain HK, Gajbhiye VT, . 1989. Persistence of some synthetic pyrethroids and organophosphorus insecticides in soil, water and sediment part II. J Entomol Res 13(2):131–136.
*Ahlbom J, Fredriksson A, Eriksson P. 1994. Neonatal exposure to a Type-I pyrethroid (bioallethrin) induces dose-response changes in brain muscarinic receptors and behaviour in neonatal and adult mice. Brain Res 645:318–324.8062093
Akhtar MH, Danis C, Trenholm D, . 1992. Deltamethrin residues in milk and tissues of lactating dairy cows. J Environ Sci Health B 27(3):235–253.1619215
*Akhtar N, Kayani SA, Ahmad MM, . 1996. Insecticide-induced changes in secretory activity of the thyroid gland in rats. J Appl Toxicol 16(5):397–400.8889791
*Alawi MA, Gharaibeh S, Al-Shureiki Y. 1990. Rueckstandsuntersuchungen auf fenitrothion und pyrethroide in wasser, boden und pflanzen nach der heuschreckenbekaempfung in Jordanien 1989. Chemosphere 20(3–4):443–447.
Aldana L, González de Mejía E, Craigmill A, . 1998. Cypermethrin increases apo A-1 and apo B mRNA but not hyperlipidemia in rats. Toxicol Lett 95:31–39.9650644
Aldana L, Tsutsumi V, Craigmill A, . 2001. α-Tocopherol modulates liver toxicity of the pyrethroid cypermethrin. Toxicol Lett 125:107–16.11701229
Aldridge WN. 1980. Mode of action of pyrethroids in mammals: Summary of toxicity and histological, neurophysiological and biochemical studies at Carshalton. In: Mattieu J, ed. Pyrethroid insecticides: Chemistry and action. Romainville, France: Roussel Uclaf, 45–47.
*Aldridge WN. 1990. An assessment of the toxicological properties of pyrethroids and their neurotoxicity. Crit Rev Toxicol 21(2):89–104.2083034
Aldridge WN, Clothier B, Forshaw P, . 1978. The effect of DDT and pyrethroids cismethrin and decamethrin on the acetyl choline and cyclic nucleotide content of rat brain. Biochem Pharmacol 27:1703–1706.212078
Allen GJ, Sanders D. 1995. Calcineurin, a type 2B protein phosphatase, modulates the Ca^2+^-permeable slow vacuolar ion channel of stomatal guard cells. Plant Cell 7:1473–1483.12242407
Altenkirch H, Hopmann D, Brockmeier B, . 1996. Neurological investigations in 23 cases of pyrethroid intoxication reported to the German Federal Health Office. Neurotoxicology 17:645–652.9086485
*Altman PL, Dittmer DS. 1974. In: Biological handbooks: Biology data book. Vol. III. 2^nd^ ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
*Amer SM, Abd-El Samie Ibrahim A, El-Sherbeny KM. 1993. Induction of chromosomal aberrations and sister chromatid exchange in vivo and in vitro by the insecticide cypermethrin. J Appl Toxicol 13(5):341–345.8258631
*Anadón A, Martinez-Larrañaga MR, Díaz MJ, . 1991a. Effect of deltamethrin on antipyrine pharmacokinetics and metabolism in rat. Arch Toxicol 65:156–159.2059156
*Anadón A, Martinez-Larrañaga MR, Díaz MJ, . 1991b. Toxicokinetics of permethrin in the rat. Toxicol Appl Pharmacol 110:1–8.1871768
Anadón A, Martinez-Larrañaga MR, Díaz MJ, . 1995. Effects of flumethrin on hepatic drug-metabolizing enzymes and antipyrine disposition in rats. Toxicol Appl Pharmacol 132:14–18.7747277
*Anadón A, Martinez-Larrañaga MR, Fernandez-Cruz ML, . 1996. Toxicokinetics of deltamethrin and its 4’-HO-metabolite in the rat. Toxicol Appl Pharmacol 141:8–16.8917670
*Andersen ME, Kirshnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, and replacement. New York: Marcel Dekker, Inc., 9–25.
*Andersen ME, Clewell HJ III, Gargas ML. 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
*Angerer J, Ritter A. 1997. Determination of metabolites of pyrethroids in human urine using solid-phase extraction and gas chromatography-mass spectrometry. J Chromatogr B Biomed Appl 695:217–226.
Angerer J, Butte W, Hoppe H, . 1999. Pyrethroid metabolites (cis-3-(2,2-dichlorovinyl)-2,2-dimethylcyclopropane-1-carboxylic acid; trans-3-(2,2-dichlorovinyl)-2,2-dimethylcyclopropane-1-carboxylic acid; cis-3-(2,2-dibromovinyl)-2,2-dimethylcyclopropane-1-carboxylic acid; 3-phenoxybenzoic acid; 4-fluoro-3-phenoxybenzoic acid). Anal Hazard Subst Biol Mater 6:231–254.
*Antonious GF, Byers ME, Kerst WC. 1997. Residue levels of pyrethrins and piperonyl butoxide in soil and runoff water. J Environ Sci Health B 32(5):621–644.9269080
Appel KE, Michalak H, Gericke S. 1994. [Health risks from pyrethroids? Data on their neurotoxicity, toxicokinetics and human health disorders.] Wiss Umwelt 2:95–108. (German).
*Aprea C, Stridori A, Sciarra G. 1997. Analytical method for the determination of urinary 3-phenoxybenzoic acid in subjects occupationally exposed to pyrethroid insecticides. J Chromatogr B Biomed Appl 695:227–236.
Asakawa F, Jitsunari F, Miki K, . 1996. Agricultural worker exposure to and absorption of permethrin applied to cabbage. Bull Environ Contam Toxicol 56:42–49.9026156
Aziz MH, Agrawal AK, Adhami VM, . 2001. Neurodevelopmental consequences of gestational exposure (GD14-GD20) to low dose deltamethrin in rats. Neurosci Lett 300:161–165.11226636
*Badawy MI. 1998. Organic insecticides in airborne suspended particulates. Bull Environ Contam Toxicol 60:693–701.9595183
Balbaa M, Abdelhamid EME, Bassiouny K. 1998. Enhancement of lysosomal enzymes by the pyrethroids, fenvalerate and trans-cypermethrin. Jpn J Toxicol Environ Health (Eisei Kagaku) 44(2):83–91.
Bansal N, Sharma SK, Srivastava AK, . 1997. Histomorphological and biochemical studies in experimental fluvanilate toxicity in rabbits. Indian J Anim Sci 67(4):278–280.
*Barnes DG, Dourson M. 1988. Reference dose (RfD) description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
*Barrueco C, Herrera A, Caballo C, . 1992. Cytogenetic effects of permethrin in cultured human lymphocytes. Mutagenesis 7(6):433–437.1474919
*Barrueco C, Herrera A, Caballo C, . 1994. Induction of structural chromosome aberrations in human lymphocyte cultures and CHO cells by permethrin. Teratog Carcinog Mutagen 14:31–38.7910417
*Bartsch H, Malaveille C, Camus AM, . 1980. Validation and comparative studies on 180 chemicals with S. typhimurium strains and V79 Chinese hamster cells in the presence of various metabolizing systems. Mutat Res 76:1–50.6993936
Bast GE, Taeschner D, Kampffmeyer HG. 1997. Permethrin absorption not detected in single-pass perfused rabbit ear, and absorption with oxidation of 3-phenoxybenzyl alcohol. Arch Toxicol 71:179–186.9049055
Bateman DN. 2000. Management of pyrethroid exposure. Clin Toxicol 38(2):107–109.
*Batiste-Alentorn M, Xamena N, Velázquez A, . 1986. Mutagenicity testing of the pyrethroid insecticide cypermethrin in drosophila. Mutagenesis 1(5):343–346.3137414
*Baynes RE, Halling KB, Riviere JE. 1997. The influence of diethyl-m-toluamide (DEET) on the percutaneous absorption of permethrin and carbaryl. Toxicol Appl Pharmacol 144:332–339.9194417
*Bennett RS, Klass EE, Coats JR, . 1983. Fenvalerate residues in nontarget organisms from treated cotton fields. Bull Environ Contam Toxicol 31:61–65.6882941
*Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag.
Bhatnagar R, Kataria M. 1997. Influence of permethrin on certain biochemical parameters in the rat brain. Med Sci Res 25:327–328.
*Bhaumik A, Gupta PK. 1990. Teratogenicity of decamethrin in rats. Indian Vet J 2:213–219.
*Bhunya SP, Pati PC. 1988. Genotoxic effects of a synthetic pyrethroid insecticide, cypermethrin, in mice in vivo. Toxicol Lett 41:223–230.3376150
*Bhunya SP, Pati PC. 1990. Effect of deltamethrin, a synthetic pyrethroid, on the induction of chromosome aberrations, micronuclei and sperm abnormalities in mice. Mutagenesis 5(3):229–232.2385176
Binka FN, Kubaje A, Adjuik M, . 1996. Impact of permethrin impregnated bednets on child mortality in Kassena-Nankana district, Ghana: a randomized controlled trial. Tropical Medicine and International Health 1(2):147–154.8665378
*Bissacot DZ, Vassilieff I. 1997a. HPLC determination of flumethrin, deltamethrin, cypermethrin and cyhalothrin residues in the milk and blood of lactating dairy cows. J Anal Toxicol 21:397–402.9288595
*Bissacot DZ, Vassilieff I. 1997b. Pyrethroid residues in milk and blood of dairy cows following single topical applications. Vet Hum Toxicol 39(1):6–8.9004471
*Blaylock BL, Abdel-Nasser M, McCarty SM, . 1995. Suppression of cellular immune responses in Balb/c mice following oral exposure to permethrin. Bull Environ Contam Toxicol 54:768–774.7780222
Bloom AS, Staatz CG, Dieringer T. 1983. Pyrethroid effects on operant responding and feeding. Neurobehav Toxicol Teratol 5:321–324.6877472
*Bloomquist JR. 1993. Neuroreceptor mechanisms in pyrethroid mode of action and resistance. In: Roe RM, Kuhr RJ, eds. Reviews in pesticide toxicology. Raleigh, NC: Toxicology Communications Inc., 184–230.
*Bloomquist JR, Adams PM, Soderlund DM. 1986. Inhibition of γ-aminobutyric acid-stimulated chloride flux in mouse brain vesicles by polychlorocycloalkane and pyrethroid insecticides. Neurotoxicology 7(3):11–20.2434890
Blume H-P, Ahlsdorf B. 1993. Prediction of pesticide behavior in soil by means of simple field tests. Ecotoxicol Environ Saf 26:313–332.7507822
BNA. 2001. Environment and Safety Library on the Web States and Territories. Bureau of National Affairs, Inc. Washington, D.C. http//www.esweb.bna.com/ (http://www.esweb.bna.com/). May 25, 2001.
*Boehncke A, Siebers J, Nolting H-G. 1990. Investigations of the evaporation of selected pesticides from natural and model surfaces in field and laboratory. Chemosphere 21(9):1109–1124.
*Box SA, Lee MR. 1996. A systemic reaction following exposure to a pyrethroid insecticide. Hum Exp Toxicol 15:389–390.8735461
*Bradbury JE, Forshaw PJ, Gray AJ, . 1983. The action of mephenesin and other agents on the effects produced by two neurotoxic pyrethroids in the intact and spinal rat. Neuropharmacology 22(7):907–914.6621820
Bradbury JE, Gray AJ, Forshaw P. 1981. Protection against pyrethroid toxicity in rats with mephenesin. Toxicol Appl Pharmacol 60:382–384.7281194
Bradbury SP, Coats JR. 1982. Toxicity of fenvalerate to bobwhite quail (Colinus virginianus) including brain and liver residues associated with mortality. J Toxicol Environ Health 10:307–319.7143484
Bradbury SP, Coats JR. 1989. Comparative toxicology of the pyrethroid insecticides. Rev of Environ Contam and Toxicol 108:133–177.2646661
*Braun HE, Frank R, Miller LA. 1985. Residues of cypermethrin in milk from cows wearing impregnated ear tags. Bull Environ Contam Toxicol 35:61–64.4027409
Briggs G. 1981. Adsorption of pesticides by some Australian soils. Aust J Soil Res 19:61–68.
Brodie ME, Aldridge WN. 1982. Elevated cerebellar cyclic GMP levels during the deltamethrin-induced motor syndrome. Neurobehav Toxicol Teratol 4:109–113.6280084
Brown GB, Gaupp JE, Olsen RW. 1988. Pyrethroid insecticides: Stereospecific allosteric interaction with the batrachotoxinin—A benzoate binding site of mammalian voltage-sensitive sodium channels. Mol Pharmacol 34:54–59.2455860
*Budavari S, O’Neil MJ, Smith A, . 1996. The Merck index: An encyclopedia of chemicals, drugs, and biologicals. 12^th^ ed. Whitehouse Station, NJ: Merck and Co., Inc.
Butler WH, Cohen SH, Squire RA. 1997. Mesenchymal tumors of the mouse urinary bladder with vascular and smooth muscle differentiation. Toxicol Pathol 25(3):268–274.9210258
*Caballo C, Herrera A, Barrueco C, . 1992. Analysis of cytogenetic damage induces in CHO cells by the pyrethroid insecticide fenvalerate. Teratog Carcinog Mutagen 12:243–249.1363962
*Cabral JRP, Galendo D. 1990. Carcinogenicity study of the pesticide fenvalerate in mice. Cancer Lett 49:13–18.2302693
Cabral JRP, Galendo D, Laval M, . 1990. Carcinogenicity studies with deltamethrin in mice and rats. Cancer Lett 49:147–152.2306708
*Cagen SZ, Malley LA, Parker CM, . 1984. Pyrethroid-mediated skin sensory stimulation characterized by a new behavioral paradigm. Toxicol Appl Pharmacol 76:270–279.6495334
*Calore EE, Cavaliere MJ, Puga FR, . 2000. Histologic peripheral nerve changes in rats induced by deltamethrin. Ecotoxicol Environ Saf 47:82–86.10993707
Campana MA, Panzeri AM, Moreno VJ, . 1999. Genotoxic evaluation of the pyrethroid λ-cyhalothrin using the micronucleus test in erythrocytes of the fish Cheirodon interruptus interruptus. Mutat Res 438:155–161.10036336
*Cantalamessa F. 1993. Acute toxicity of two pyrethroids, permethrin, and cypermethrin in neonatal and adult rats. Arch Toxicol 67:510–513.8240001
*Caplan JA, Isensee AR, Nelson JO. 1984. Fate and effects of [^14^C]fenvalerate in a tidal marsh sediment ecosystem model. J Agric Food Chem 32:166–171.
*Carbonell E, Puig M, Xamena N, . 1989. Mitotic arrest induced by fenvalerate in human lymphocyte cultures. Toxicol Lett 48:45–48.2749778
Carlson GP, Schoenig GP. 1980. Induction of liver microsomal NADPH cytochrome c reductase and cytochrome P-450 by some new synthetic pyrethroids. Toxicol Appl Pharmacol 52:507–512.6768169
*Carlson JE, Villaveces JW. 1977. Hypersensitivity pneumonitis due to pyrethrum: Report of a case. JAMA 237(16):1718–1719.576676
Carlton M. 1977. Some effects of cismethrin on the rabbit nervous system. Pestic Sci 8:700–712.
Casida JE. 1980. Pyrethrum flowers and pyrethroid insecticides. Environ Health Perspect 34:189–202.6993201
Casida JE, Quistad GB. 1995. Metabolism and synergism of pyrethrins. In: Casida JE, Quistad GB, eds. Pyrethrum flowers: Production, chemistry, toxicology, and uses. New York: Oxford University Press, 258–276.
Casida JE, Ruzo LO. 1980. Metabolic chemistry of pyrethroid insecticides. Pestic Sci 11:257–269.
*Casida JE, Gammon DW, Glickman AH, . 1983. Mechanisms of selective action of pyrethroid insecticides. Annu Rev Pharmacol Toxicol 23:413–438.6347050
*Casida JE, Kimmel EC, Elliott M, . 1971. Oxidative metabolism of pyrethrins in mammals. Nature 230:326–327.5549407
Casida JE, Ueda K, Gaughan LC, . 1976. Structure-biodegradability relationships in pyrethroid insecticides. Arch Environ Contam Toxicol 3:491–500.
Catinot R, Hoellinger H, Pfister A, . 1989a. Effects on rats of subacute intoxication with deltamethrin via an osmotic pump. Drug Chem Toxicol 12:173–196.2632242
Catinot R, Hoellinger H, Sonnier M, . 1989b. In vitro covalent binding of the pyrethroids cismethrin, cypermethrin and deltamethrin to rat liver homogenate and microsomes. Arch Toxicol 63:214–220.2764708
Catterall WA. 1992. Cellular and molecular biology of voltage-gated sodium channels. Physiol Rev 72(4):S15–S48.1332090
*Caux P-Y, Bastien C, Crowe A. 1996. Fate impact of pesticides applied to potato cultures: The Nicolet River Basin. Ecotoxicol Environ Saf 33:175–185.8723756
*Cecchine G, Golomb BA, Hilborne LH, . 2000. A review of the scientific literature as it pertains to Gulf War illnesses. Rand Publication Database. http://www.rand.org/publications/MR/MR1018.8/MR1018.8.pdf/. April 5, 2001.
Chalmers AE, Miller TA, Olsen RW. 1987. Deltamethrin: A neurophysiological study of the sites of action. Pestic Biochem Physiol 27:36–41.
Chambers J. 1980. An introduction to the metabolism of pyrethroids. Residue Rev 73:101–124.6990447
Chang J-Y, Lin J-M. 1998. Aliphatic aldehydes and allethrin in mosquito-coil smoke. Chemosphere 36(3):617–624.9451813
Chanh PH, Navarro-Delmasure C, Chanh A, . 1980. Toxicity and cardiovascular effects of decamethrin on anaesthetized dogs. IRCS J Med Sci 8:388–389.
Chanh P, Navarro-Delmasure C, Chanh APH, . 1981. Analgesic effects of decamethrin. IRCS J Med Sci 9:503–504.
Chanh PH, Navarro-Delmasure C, Pham Huu Chanh A, . 1984. Toxicological studies of deltamethrin. Int J Tissue React 6(2):127–133.6735621
*Chapman RA, Cole CM. 1982. Observations on the influence of water and soil pH on the persistence of insecticides. J Environ Sci Health B17(5):487–504.
*Chapman RA, Tu CM, Harris CR, . 1981. Persistence of five pyrethroid insecticides in sterile and natural, mineral and organic soil. Bull Environ Contam Toxicol 26:513–519.7236909
*Chatterjee KK, Talukder G, Sharma A. 1982. Effects of synthetic pyrethroids on mammalian chromosomes: I. Sumicidin. Mutat Res 105:101–106.7121478
*Chauhan LKS, Agarwal DK, Sundararaman V. 1997. In vivo induction of sister chromatid exchange in mouse bone marrow following oral exposure to commercial formulations of alpha-cyano pyrethroids. Toxicol Lett 93:153–157.9486951
Chawla R. 1996. Acute oral toxicity studies with K-othrine (a synthetic pyrethroid insecticide) in Swiss albino mice. Uttar Pradesh J Zool 16(1):67–68.
Chawla R. 1997. Laboratory evaluation of k-othrine, a synthetic pyrethroid against Swiss albino mice. J Adv Zool 18(1):51–53.
Chen AW, Fink JM, Letinski DJ, . 1997. Residue of cypermethrin and its major acid metabolites in milk and tissues from dairy bovines treated with cypermethrin. J Agric Food Chem 45:4850–4855.
*Chen H, Xiao J, Hu G, . 2002. Estrogenicity of organophosporus and pyrethroid pesticides. J Toxicol Environ Health A 65:1419–1435.12396874
*Chen S, Zhang Z, He F, . 1991. An epidemiological study on occupational acute pyrethroid poisoning in cotton farmers. Br J Ind Med 48:77–81.1998611
*Chen Y-L, Casida JE. 1969. Photodecomposition of pyrethrin I, phthalthrin, and dimethrin: Modification in the acid moiety. J Agric Food Chem 17(2):208–215.
*Chen Z-M, Wang Y-H. 1996. Chromatographic methods for the determination of pyrethrin and pyrethroid pesticide residues in crops, foods and environmental samples. J Chromatogr 754:367–395.
*Chen ZM, Zabik MJ, Leavitt RA. 1984. Comparative study of thin film photodegradative rates for 36 pesticides. Ind Eng Chem Prod Res Dev 23:5–11.
*Chester G, Hatfield LD, Hart TB, . 1987. Worker exposure to, and absorption of, cypermethrin during aerial application of an “ultra low volume” formulation to cotton. Arch Environ Contam Toxicol 16:69–78.3813658
*Chester G, Sabapathy NN, Woollen BH. 1992. Exposure and health assessment during application of lambda-cyhalothrin for malaria vector control in Pakistan. Bull WHO 70(5):615–619.1464147
*Chruścielska K, Kalhorn D. 1999. Genotoxicity of pyrethroids: Part 2. Studies on mutagenic activity of commercial formulations in mouse micronucleus test. Pestycydy 4:47–50.
*Chruścielska K, Kalhorn D, Sitowska B. 1999. Genotoxicity of pyrethroids: Part 1. Studies on mutagenic activity of pyrethroids formulations and their active ingredients in Saccharomyces cerevisiae assay. Pestycydy 4:39–45.
Chugh Y, Sankaranarayanan A, Sharma PL. 1991. Effect of fenvalerate and endosulfan on behavioral despair and forced locomotor activity in albino mice. Asia Pac J Pharmacol 6:31–35.
*Clark JM, Marion JR, Tessier DM, . 1991. Airborne drift residues collected near apple orchard environments due to application of insecticide mixtures. Bull Environ Contam Toxicol 46:829–836.1863790
*Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1:111–113.3843496
*Coats JR. 1990. Mechanisms of toxic action and structure-activity relationships for organochlorine and synthetic pyrethroid insecticides. Environ Health Perspect 87:255–262.2176589
Condés-Lara M, Graff G A, Vega-Riveroll L. 1999. Effects of cypermethrin on the electroencephalographic activity of the rat: A model of chemically induced seizures. Neurobehav Toxicol Teratol 21(3):293–298.
Cordon C. 1986. Gas chromatographic determination of flucythrinate synthetic pyrethroid residues in a range of crops. J Agric Food Chem 34:953–955.
*Cotham WE, Bidleman TF. 1989. Degradation of malathion, endosulfan, and fenvalerate in seawater and seawater/sediment microcosms. J Agric Food Chem 37:824–828.
Cremer JE, Seville MP. 1985. Changes in regional cerebral blood flow and glucose metabolism associated with symptoms of pyrethroid toxicity. Neurotoxicology 6(3):1–12.
*CRIS/USDA. 2001. CRIS Database. Current Research Information System. U.S. Department of Agriculture. April, 2001.
*CRISP. 2001. CRISP Database. Computer Retrieval of Information on Scientific Projects.
*CRISP. 2003. CRISP Database. Computer Retrieval of Information on Scientific Projects.
Crofton KM, Reiter LW. 1984. Effects of two pyrethroid insecticides on motor activity and the acoustic startle response in the rat. Toxicol Appl Pharmacol 75:318–328.6474463
*Crofton KM, Reiter LW. 1988. The effects of Type I and II pyrethroids on motor activity and the acoustic startle response in the rat. Fundam Appl Toxicol 10:624–634.3396790
*Crofton KM, Kehn LS, Gilbert ME. 1995. Vehicle and route dependent effects of a pyrethroid insecticide, deltamethrin, on motor function in the rat. Neurotoxicol Teratol 17(4):489–495.7565495
*Crofton KM, Reiter LW, Mailman RB. 1987. Pyrethroid insecticides and radio ligand displacement for the gaba receptor chloride ionophore complex. Toxicol Lett 35:183–190.3029901
*Crosby DG. 1995. Environmental fate of pyrethrins. In: Casida JE, Quistad GB, eds. Pyrethrum flowers. New York, NY: Oxford University Press, 194–213.
*Crossland NO, Shires SW, Bennett D. 1982. Aquatic toxicology of cypermethrin. III. Fate and biological effects of spray drift deposits in fresh water adjacent to agricultural land. Aquatic Toxicol 2:253–270.
Culliford SJ, Kozlowski RZ. 1999. Effects of pyrethroids on volume-sensitive chloride channels. Br J Pharmacol 126:28.
Culver CA, Malina JJ, Talvert RL. 1988. Probable anaphylactoid reaction to a pyrethrin pediculocide shampoo. Clin Pharm 7:846–849.3197386
*Curry AM, Bennett IP. 1985. PP321: 4 Hour acute inhalation toxicity study in the rat of a 13% EC formulation. Imperial Chemical Industries PLC. OTS0538576.
Dandliker WB, Hicks AN, Levison SA, . 1980. Effects of pesticides on the immune response. Environ Sci Technol 14(2):204–210.
Danielson TJ, Golsteyn LR, Elder JL. 1996. Pharmacokinetics of fenvalerate after intravenous administration to sheep. Pestic Sci 46:145–150.
Das AC, Mukherjee D. 1999. Influence of BHC and fenvalerate on mineralization and availability of some plant nutrients in soil. Bull Environ Contam Toxicol 62:371–376.10085183
*Davies JH. 1985. The pyrethroids: An historical introduction. In: Leahey JP, ed. The pyrethroid insecticides. Philadelphia, PA: Taylor & Francis, 1–41.
Davies MG, Kersey PJ. 1986. Contact allergy to yarrow and dandelion. Contact Dermatitis 14:256–257.2941233
Day KE. 1991. Effects of dissolved organic carbon on accumulation and acute toxicity of fenvalerate, deltamethrin and cyhalothrin to Daphnia magna (Straus). Environ Toxicol Chem 10:91–101.
Dayal M, Parmar D, Dhawan A, . 1999. Induction of rat brain and liver cytochrome P450 1A1/1A2 and 2B1/2B2 isoenzymes by deltamethrin. Environ Toxicol Pharmacol 7:169–178.21781923
de Boer F, van der Gugten j, Slangen JL, . 1988. Changes in plasma corticosterone and catecholamine contents induced by low doses of deltamethrin in rats. Toxicology 49:263–270.3376130
De Cheke ME. 1989. Chemical analysis of water and wastewater inorganics. J Water Pollut Control Fed 61(6):727–755.
Dejonckheere W, Steurbaut W, Drieghe S, . 1996a. Monitoring of pesticide residues in fresh vegetables, fruits, and other selected food items in Belgium. J Assoc Off Anal Chem Int 79(1):97–110.
Dejonckheere W, Steurbaut W, Drieghe S, . 1996b. Pesticide residue concentrations in the Belgian total diet, 1991-1993. J Assoc Off Anal Chem Int 79(2):520–528.
*Demian SR. 1998. Immunological alteration in mice exposed to deltamethrin insecticide: II. Defective humoral immune reactivity. J Med Res Inst 19(2):154–164.
*Demian SR, El-Sayed MH. 1993. Immunological alterations in mice exposed to deltamethrin insecticide I. Impairment of IL-1 & IL-2 production. J Med Res Inst 19(2):154–164.
Demoute JP. 1989. A brief review of the environmental fate and metabolism of pyrethroids. Pestic Sci 27:375–385.
Deshmukh PB. 1992. Three-generation reproductive studies of a synthetic pyrethroid - cyhalothrin. Toxicol Lett 64/65:779–781.
Deshmukh PB, Patel SV, Banerjee RS. 1993. Effect of cyhalothrin on reproductive parameters in mice. Proc Acad Environ Biol 2(1):99–104.
*Dési I, Dobronyi I, Varga L. 1986. Immuno-, neuro-, and general toxicologic animal studies on a synthetic pyrethroid: Cypermethrin. Ecotoxicol Environ Saf 12:220–232.3816641
Devaud LL, Szot P, Murray TF. 1986. PK 1195 antagonism of pyrethroid-induced proconvulsant activity. Eur J Pharmacol 120:269–273.
*Dianovský J, Šiviková K. 1997. Cytogenetic effect of supermethrin in pig and cattle peripheral lymphocytes. Acta Vet Brno 66:33–38.
Diel F, Detscher M, Borck H, . 1998a. Effects of permethrin on human basophils and lymphocytes in vitro. Inflamm Res 47:S11–S12.9561393
Diel F, Detscher M, Schock B, . 1998b. In vitro effects of the pyrethroid S-bioallethrin on lymphocytes and basophils from atopic and nonatopic subjects. Allergy 53:1052–1059.9860237
Diel F, Horr B, Borck H, . 1999. Pyrethroids and piperonyl-butoxide affect human T-lymphocytes in vitro. Toxicol Lett 107:65–74.10414782
*DOD. 1977. Toxicological evaluation of 3-(phenoxyphenyl) methyl (+ or −)-cis, trans-3-(2,2-dichloroethenyl)-2,2-dimethyl cyclopropanecarboxylate (permethrin), December 1975–April 1977. Department of the Army, Department of Defense. ADA047284.
*DOD. 2001. Environmental exposure report. U.S. Department of Defense. http://www.gulflink.osd.mil/pesto/pest_s04.htm. April 9, 2001.
Dogheim SM, Alla SAG, El-Marsafy AM. 1999. Monitoring pesticide residues in Egyptian fruits and vegetables in 1995. J Assoc Off Anal Chem Int 82(4):948–954.
*Dolara P, Salvadori M, Capobianco T, . 1992. Sister-chromatid exchanges in human lymphocytes induced by dimethoate, omethoate, deltamethrin, benomyl and their mixture. Mutat Res 283:113–118.1381487
*Dorman DC, Beasley VR. 1991. Neurotoxicology of pyrethrin and the pyrethroid insecticides. Vet Hum Toxicol 33(3):238–243.1713367
Dorman DC, Buck WB, Trammel HL, . 1990. Fenvalerate/N,N-diethyl-m-toluamide (DEET) toxicosis in two cats. J Am Vet Med Assoc 196(1):100–102.2295539
*DOT. 2001. Hazardous materials table, special provisions, hazardous materials communications, emergency response information, and training requirements. Department of Transportation. Code of Federal Regulations. 49 CFR 172. Appendix A. http://www.dot.gov/. April 19, 2001.
Dowling RH, Mack E, Small DM, . 1970. Effects of controlled interruption of the enterohepatic circulation of bile salts by biliary diversion and by ileal resection on bile salt secretion, synthesis, and pool size in the Rhesus monkey. J Clin Invest 49:232–342.4983661
*Dureja P. 1990. Photodecomposition of pyrethroid insecticide fenpropathrin. Pesticides 1989:31–33.
*Dureja P, Casida JE, Ruzo LO. 1984. Dinitroanilines as photostabilizers for pyrethroids. J Agric Food Chem 32:246–250.
Dyck PJ, Shimono M, Schoening GP, . 1984. The evaluation of a new synthetic pyrethroid pesticide (permethrin) for neurotoxicity. J Environ Pathol Toxicol Oncol 5:109–117.6097663
*Eadsforth CV, Baldwin MK. 1983. Human dose-excretion studies with the pyrethroid insecticide, cypermethrin. Xenobiotica 13(2):67–72.6880240
*Eadsforth CV, Bragt PC, van Sittert NJ. 1988. Human dose-excretion studies with pyrethroid insecticides cypermethrin and alphacypermethrin: Relevance for biological monitoring. Xenobiotica 18(5):603–614.3400277
Eells JT, Bandettini PA, Holman PA, . 1992. Pyrethroid insecticide-induced alterations in mammalian synaptic membrane potential. J Pharmacol Exp Ther 262(3):1173–1181.1527722
Eells JT, Rasmussen JL, Bandettini PA, . 1993. Differences in the neuroexcitatory actions of pyrethroid insecticides and sodium channel-specific neurotoxins in rat and trout brain synaptosomes. Toxicol Appl Pharmacol 123:107–119.8236249
*Eil C, Nisula BC. 1990. The binding properties of pyrethroids to human skin fibroblast androgen receptors and to sex hormone binding globulin. J Steroid Biochem 3(3–4):409–414.
*Eitzer BD. 1991. Cycling of indoor air concentrations of d-trans-allethrin following repeated pesticide applications. Bull Environ Contam Toxicol 47:406–412.1768956
Eke KR. 1996. Pesticides in the aquatic environment in England and Wales. Pestic Outlook April:15–21.
El-Ashmawy IM, Zakaria AD, Hemed SA, . 1993. Cytotoxic effects of the pyrethroid insecticide (Matox) with reference to its influence on the reproductive hormone. Vet Med J Giza 41(3):125–130.
Elbetieha A, Da’as SI, Khamas W, . 2001. Evaluation of the toxic potentials of cypermethrin pesticide on some reproductive and fertility parameters in the male rats. Arch Environ Contam Toxicol 41:522–528.11598791
*El-Elaimy I. 1986. Biochemical disturbance in liver function and whole blood AChE due to repeated dermal application of baythroid to rat. Proc Zool Soc AR Egypt 10:51–60.
*El-Gohary M, Awara WM, Nassar S, . 1999. Deltamethrin-induced testicular apoptosis in rats: The protective effect of nitric oxide synthase inhibitor. Toxicology 132:1–8.10199576
El-Khatib EN. 2001. Assessment of the mutagenic activity of alpha-cypermethrin: Detection of p53 mutation using SSCP analysis of polymerase chain reaction. Mutat Res 483:S73.
El-Khatib EN, Rokaya HA. 2001. Genotoxic effects of two pesticides and their mixtures: In vivo chromosomal aberrations and micronucleus assay in rat bone-marrow cells. [Abstract]. Toxciol Lett 123:123.
*Ellenhorn MJ, Schonwald S, Ordog G, . 1997. Medical toxicology: Diagnosis and treatment of human poisoning. 2nd ed. Baltimore: Williams & Wilkins.
Elliott M, Janes NF, Kimmel EC, . 1972. Metabolic fate of pyrethrin I, pyrethrin II, and allethrin administered orally to rats. J Agric Food Chem 20(2):300–313.5016611
*Elliott M, Janes NF, Pulman DA, . 1976. Radiosynthesis and metabolism in rats of the R isomers of the insecticide permethrin. J Agric Food Chem 24(2):270–276.1254806
El-Meligy S, El-Ashwah N, Gaffar N, . 1993. Effect of fenvalerate on liver, brain, and kidney sodium-potassium adenosine triphosphatase activity and serum electrolytes in rats. Egypt J Biochem 11(1):47–55.
El-Salkh BA. 1996. Ultrastructural changes of the liver of rat after polytrin treatment. al-Azhar Bull Sci 7(1):939–946.
El-Sebae AH, Salem MH, El-Assar MRS, . 1988. In vitro effect of profenofos, fenvalerate and dimilin on protein and RNA biosynthesis by rabbit liver and muscle tissues. J Environ Sci Health B23(5):439–451.
El-Sewedy SM, Mostafa MH, El-Bassiouni EA, . 1982a. Effect of fenvalerate on kynurenine metabolizing enzymes and acid ribonuclease of mouse liver. J Environ Sci Health B 17:571–579.7175102
El-Sewedy SM, Zahran MA, Seidan MA, . 1982b. Effect and mechanism of action of methomyl and cypermethrin insecticides on kynurenine metabolizing enzymes of mouse liver. J Environ Sci Health B17(5):527–539.
*El-Shahawi FI. 1996. In vivo toxicological studies of the effect of pyrethroid insectide permethrin on female Wistar rats. Alex J Pharm Sci 10(1):71–76.
El-Tawil OS, Abdel-Rahman MS. 1997. Effect of cypermethrin on isolated male and female rat hepatocytes. J Toxicol Environ Health 52:461–474.9388536
El-Tawil OS, Abdel-Rahman MS. 2001. The role of enzyme induction and inhibition on cypermethrin hepatotoxicity. Pharmacol Res 44(1):33–40.11428908
El-Toukhy MA, Girgis RS. 1993. In vivo and in vitro studies on the effect of larvin and cypermethrin on adenosine triphosphatase activity of male rats. J Environ Sci Health B 28(5):599–619.8409234
El-Toukhy MA, Ebiad SA, Hassan AA, . 1989. In vivo studies on the effect of some insecticides on the hepatic activities of L-tryptophan 2,3-dioxygenase and pyridoxal phosphokinase of male mice. J Environ Sci Health B 24(3):265–276.2547861
*EMMI. 1997. EMMI Database. Environmental Monitoring Methods Index. U.S. Environmental Protection Agency.
Enan E, Matsumura F. 1993. Activation of phosphoinositide/protein kinase C pathway in rat brain tissue by pyrethroids. Biochem Pharmacol 45(3):703–710.8095139
Enan E, Pinkerton KE, Peake J, . 1996. Deltamethrin-induced thymus atrophy in male Balb/c mice. Biochem Pharmacol 51(4):447–454.8619889
*EPA. 1981. Data evaluation record: Cyhalothrin oral toxicity study in beagle dogs (repeated daily dosing for 26 weeks). U.S. Environmental Protection Agency. Office of Pesticide Programs. Tox review 005100 (excerpt).
*EPA. 1983. Memorandum: Review of a 1 year dosing study with the synthetic pyrethroid permethrin. U.S. Environmental Protection Agency. Office of Pesticides and Toxic Substances. Tox Review 003403.
*EPA. 1985a. Data evaluation record: Cyhalothrin: 28-day feeding study in the rat. U.S. Environmental Protection Agency. Office of Pesticide Programs. Tox review 005100 (excerpt).
*EPA. 1985b. Data evaluation record: Cyhalothrin: 90-day feeding study in rats. U.S. Environmental Protection Agency. Office of Pesticide Programs. Tox review 005100 (excerpt).
*EPA. 1985c. Data evaluation record: Cyhalothrin: Chronic toxicity study in rats. U.S. Environmental Protection Agency. Office of Pesticide Programs. Tox review 005100 (excerpt).
*EPA. 1985d. Data evaluation record: Cyhalothrin: Chronic toxicity and oncogenicity feeding study in mice. U.S. Environmental Protection Agency. Office of Pesticide Programs. Tox review 005100 (excerpt).
*EPA. 1986a. Data evaluation record: Cyhalothrin: Teratogenicity study in rats. U.S. Environmental Protection Agency. Office of Pesticide Programs. Tox review 005100 (excerpt).
*EPA. 1986b. Data evaluation record: Cyhalothrin: Three-generation reproduction study in rats. U.S. Environmental Protection Agency. Office of Pesticide Programs. Tox review 005100 (excerpt).
*EPA. 1987. Memorandum: Esfenvalerate: ASANA (pydrin)- Submission of the range-finding study used to determine dosages for the 1-year dog study. U.S. Environmental Protection Agency. Office of Pesticides and Toxic Substances. Tox review 006524.
*EPA. 1988a. Recommendations for and documentation of biological values for use in risk assessment. Cincinnati, OH: U.S. Environmental Protection Agency. PB88-179874.
*EPA. 1988b. Reference physiological parameters in pharmacokinetic modeling. Washington, DC: U.S. Environmental Protection Agency. PB88-196019.
*EPA. 1988c. Memorandum: Pyrethrins: Submission of rat and rabbit teratology range finding studies in response to a prior request from Toxicology Branch. U.S. Environmental Protection Agency. Office of Pesticides and Toxic Substances. Tox review 006824.
*EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency. Office of Health and Environmental Assessment, Office of Research and Development. Environmental Criteria and Assessment Office. EPA 600/8-90/066A.
*EPA. 1991a. Data evaluation record: Esfenvalerate: Subchronic oral toxicity (90-day) mouse. U.S. Environmental Protection Agency. Office of Pesticide Programs. Tox review 008967 (excerpt).
*EPA. 1991b. Memorandum: Permethrin: Review of rat and rabbit development toxicity studies (83-3) submitted in response to FIFRA 88 toxicity data requirements. U.S. Environmental Protection Agency. Office of Pesticides and Toxic Substances. Tox review 008344.
*EPA. 1992a. Another look: National survey of pesticides in drinking water wells: Phase II report. Office of Water. U.S. Environmental Protection Agency. Office of Pesticides and Toxic Substances, EPA 579/09-91-020.
*EPA. 1992b. Data evaluation record: Esfenvalerate: Comparative mammalian neurotoxicity- Rat 81-8ss 1 dose- 2 weeks. U.S. Environmental Protection Agency. Office of Pesticide Programs. Tox review 00981 (excerpt).
*EPA. 1992c. Data evaluation report: Cypermethrin: Multi generation reproduction study-rats. U.S. Environmental Protection Agency. Office of Pesticide Programs. Tox review (excerpt) 009347.
*EPA. 1994a. Memorandum: Resmethrin: Evaluation of 2-generation reproduction study in rat and reevaluation of the following previously submitted studies: 3-generation reproduction study in rat, six month dog, rat. U.S. Environmental Protection Agency. Office of Pesticides and Toxic Substances. Tox review 011329.
*EPA. 1994b. Memorandum: Permethrin: Review of series 81-8ss and 82-7ss acute and subchronic neurotoxicity screen studies and a literature publication on the neurotoxicity and commentary on a special positive control study with acrylamide. U.S. Environmental Protection Agency. Office of Pesticides and Toxic Substances.
*EPA. 1994c. Memorandum. Pyrethrum extract: Review of rat chronic feeding/carcinogenicity study (IRDC 1990) and mouse carcinogenicity study (IRDC 1990). U.S. Environmental Protection Agency. Office of Pesticides and Toxic Substances. Tox Review 01079.
*EPA. 1994d. Memorandum: Resmethrin: Evaluation of new mouse dietary carcinogenicity study and reevaluation of previously submitted mouse carcinogenicity study on resmethrin (SBP 1:52). U.S. Environmental Protection Agency. Office of Pesticides and Toxic Substances. Tox review 011067.
*EPA. 1995. Emergency planning and community Right-to-know Act. U.S. Environmental Protection Agency. http://www.epa.gov/region5/debs/html/epcra.htm. April 19, 1995.
*EPA. 1996. Memorandum: Cypermethrin: Review of a series 82-4 subchronic inhalation toxicity study in rats and a series 83-3 developmental toxicity study in rabbits. U.S. Environmental Protection Agency. Office of Pesticides and Toxic Substances. Tox review 012056.
*EPA. 1999. Memorandum: Pyrethrins: Report of the cancer assessment review committee. U.S. Environmental Protection Agency. Office of Pesticides and Toxic Substances. Tox Review 013354.
*EPA. 2000a. Restricted use products (RUP) report: October 2000. U.S. Environmental Protection Agency. Office of Pesticide Programs. http://www.epa.gov/RestProd/rupoct00.htm. April 2, 2001.
*EPA. 2000b. Synthetic pyrethroids for mosquito control. U.S. Environmental Protection Agency. 735-F-00-004. May 2000.
*EPA. 2000c. NCOD query results: New CCL ambient occurrence data. U.S. Environmental Protection Agency. National Drinking Water Contaminant Occurrence Database. http://oaspub.epa.gov/ncod/rpt_new_ccl_ambient_pkg.run_report. April 26, 2001.
*EPA. 2001a. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.h. April 26, 2001.
*EPA. 2001b. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. April 26, 2001.
*EPA. 2001c. Determination of reportable quantities for hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3. http://www.epa.gov/docs/epacfr40/chapt-I.info/subc. April 26, 2001.
*EPA. 2001d. NPDES Permit application testing requirements. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 122, Appendix D. http://www.epa.gov/epahome/cfr40.htm. April 19, 2001.
*EPA. 2001e. Toxic chemical release reporting: Community right-to-know. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. http://www.epa.gov/epacfr40/chapt-I.infor/chi-toc. April 26, 2001.
*EPA. 2001f. Pesticide programs. Tolerances and exemptions from tolerances for pesticide chemicals in food. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR Part 180. http://access.gpo.gov/nara/cfr/cfrhtml_00/Title_40/40cfr180_main_00.html. April 19, 2001.
*EPA. 2003. Lists of other (inert) pesticide ingredients. U.S. Environmental Protection Agency. Office of Pesticide Programs. http://www.epa.gov/opprd001/inerts/lists.html. March 27, 2003.
Eriksson P. 1991. DDT and pyrethroids-ecotoxicological considerations. Comp Biochem Physiol 100C(1–2):269–270.
Eriksson P. 1992. Neuroreceptor and behavioral effects of DDT and pyrethroids in immature and adult mammals. In: Isaacson RL, Jensen KF, eds. The vulnerable brain and environmental risks. New York, NY: Plenum Press, 235–251.
*Eriksson P, Fredriksson A. 1991. Neurotoxic effects of two different pyrethroids, bioallethrin and deltamethrin, on immature and adult mice: Changes in behavioral and muscarinic receptor variables. Toxicol Appl Pharmacol 108:78–85.2006507
*Eriksson P, Nordberg A. 1990. Effects of two pyrethroids, bioallethrin and deltamethrin, on subpopulations of muscarinic and nicotinic receptors in the neonatal mouse brain. Toxicol Appl Pharmacol 102:452–463.
Eriksson P, Talts U. 2000. Neonatal exposure to neurotoxic pesticides increases adult susceptibility: A review of current findings. Neurotoxicology 21:37–48.10794383
Eriksson P, Ankarberg E, Viberg H, . 2001. Neonatal exposure to toxicants: Defined critical period: Altered adult susceptibility. Neurotoxicology 22(4):510.
*Eriksson P, Fredriksson A, Nordbery A. 1991. Neonatal exposure to pyrethroids and nicotine - influence on the development of cholinergic receptor subtypes and behavior in young and adult mice. Neurotoxicology 12(1):133–134.
*Erstfeld KM. 1999. Environmental fate of synthetic pyrethroids during spray drift and field runoff treatments in aquatic microcosms. Chemosphere 39(10):1737–1769.10520490
Essawy GS, El-Banna HA, Sobiihy HM, . 1994. Influence of lambda (synthetic pyrethroids) on fertility and blood parameters in male rats. Vet Med J Giza 42(1):71–75.
FDA. 1989. Residues in foods—1988. J Assoc Off Anal Chem 72(5):133A–152A.
FDA. 1990. Residues in foods: Monitoring programs. J Assoc Off Anal Chem 73(5):127A–146A.
FDA. 1991. Residues in foods. J Assoc Off Anal Chem 74(5):121A–141A.
*FDA. 2000a. Piperonyl butoxide and pyrethrins as components of bags. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 178.3730. http://www.access.gpo.gov/. September 6, 2000.
*FDA. 2000b. Squalane, pyrethrins and piperonyl butoxide. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 524.2140. http://www.access.gpo.gov/. September 6, 2000.
*FDA. 2000c. Food and Drug Administration: Total diet study. Summary of residues found ordered by food market baskets 91-3–99-1. U.S. Food and Drug Administration. September 6, 2000.
*FDA. 2001. Food and Drug Administration pesticide program: Residue monitoring. U.S. Food and Drug Administration. http://vm.cfsan.fda.gov/~acrobat/pes99rep.pdf. April 16, 2001.
*FEDRIP. 2001. Federal Research in Progress. April 2001.
*FEDRIP. 2003. Federal Research in Progress. April 2003.
Fernandez MC, Martinez-Larrañaga MR, Fernandez-Cruz ML, . 1997. Neurotoxicological effects and brain disposition of deltamethrin in rats. Methods Find Exp Clin Pharmacol 19(Suppl. A):113.9151287
Ferone MR, Amorena M, De Liguoro M, . 1994. Toxicokinetics of fenvalerate in rat. Acta Toxicol Ther 15(4):221–227.
*Flannigan SA, Tucker SB. 1985. Variation in cutaneous sensation between synthetic pyrethroid insecticides. Contact Dermatitis 13:140–147.4053596
Flannigan SA, Tucker SB, Key MM, . 1985a. Primary irritant contact dermatitis from synthetic pyrethroid insecticide exposure. Arch Toxicol 56:288–294.3994514
*Flannigan SA, Tucker SB, Key MM, . 1985b. Synthetic pyrethroid insecticides: A dermatological evaluation. Br J Ind Med 42:363–372.4005189
Flodström S, Wärngård L, Ljungquist S, . 1988. Inhibition of metabolic cooperation in vitro and enhancement of enzyme altered foci incidence in rat liver by the pyrethroid insecticide fenvalerate. Arch Toxicol 61:218–223.2895627
*Flucke W, Schilde B. 1980. FCR 1272. Subacute oral toxicity study on rats. Institut fur Toxikologie. Report No. 9039.
*Flucke W, Thyssen J. 1980. Acute toxicity studies. Institut fur Toxikologie. OTS0543768.
*Fomon SJ. 1966. Body composition of the infant: Part I: The male “reference infant”. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
*Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Forshaw PJ, Bradbury JE. 1983. Pharmacological effects of pyrethroids on the cardiovascular system of the rat. Eur J Pharmacol 91:207–213.6311578
Forshaw PJ, Ray DE. 1986. The effects of two pyrethroids, cismethrin and deltamethrin, on skeletal muscle and the trigeminal reflex system in the rat. Pestic Biochem Physiol 25:143–151.
Forshaw PJ, Ray DE. 1990. A novel action of deltamethrin on membrane resistance in mammalian skeletal muscle and non-myelinated nerve fibers. Neuropharmacology 29(1):75–82.
Forshaw PJ, Ray DE. 1993. Deltamethrin, but not cismethrin, inhibits a neuronal voltage-dependent chloride channel. Neurotoxicology 14(4):555.
*Forshaw PJ, Ray DE. 1997. Development of therapy for Type II pyrethroid insecticide poisoning. Hum Exp Toxicol 16:382.
*Forshaw PJ, Lister T, Ray DE. 2000. The role of voltage-gated chloride channels in Type II pyrethroid insecticide poisoning. Toxicol Appl Pharmacol 163:1–8.10662599
Foulhoux P, Cotonat J, Leclerc M, . 1984. Treatment of deltamethrin acute intoxications. Neurotoxicology 5(4):77.6326007
Frank R, Braun HE, Clegg BS, . 1990. Survey of farm wells for pesticides, Ontario, Canada, 1986–1987. Bull Environ Contam Toxicol 44:410–419.2328348
Frank R, Braun HE, Miller LA, . 1984. Fenvalerate residues in milk following topical treatment to dairy cows. Pestic Sci 15:600–604.
Frank R, Braun HE, Ripley BD. 1987a. Residues of insecticides, fungicides, and herbicides on Ontario-grown vegetables, 1980-1985. J Assoc Off Anal Chem 70(6):1081–1086.3436903
*Frank R, Johnson K, Braun HE, . 1991. Monitoring air, soil, stream and fish for aerial drift of permethrin. Environ Monit Assess 16:127–150.24241888
Frank R, Ripley BD, Braun HE, . 1987b. Survey of farm wells for pesticides residues, Southern Ontario, Canada, 1981-1982, 1984. Arch Environ Contam Toxicol 16:1–8.
*Franz TJ, Lehman PA, Franz SF, . 1996. Comparative percutaneous absorption of lindane and permethrin. Arch Dermatol 132:901–905.8712839
*Freitag D, Ballhorn L, Geyer H, . 1985. Environmental hazard profile of organic chemicals. Chemosphere 14(10):1589–1616.
Frenkel REP, Hong YJ, Shin DH. 1988. Misuse of eye drops due to interchanged caps. Arch Ophthalmol 106:16–17.3337694
Fuortes L. 1999. Urticaria due to airborne permethrin exposure. Vet Hum Toxicol 41:92–93.10192138
Gabbianelli R, Falcioni G, Nasuit C, . 2002. Cypermethrin-induced plasma membrane perturbation on erythrocytes from rats: reduction of fluidity in the hydrophobic core and in gltathione peroxidase activity. Toxicology 175(1–3):91–101.12049839
Galceran MT, Santos FJ, Caixach J, . 1993. PCBs and chlorinated pesticides in shellfish of a deltaic environment. Chemosphere 27(7):1183–1200.
*Gandhi G, Chowdhury JB, Sareen PK, . 1995. Genotoxic effects of deltamethrin in the mouse bone marrow micronucleus assay. Mutat Res 346:203–206.7753112
*Garey J, Wolff MS. 1998. Estrogenic and antiprogestagenic activities of pyrethroid insecticides. Biochem Biophys Res Commun 251:855–859.9790999
Garg SK, Shah MA, Garg KM, . 1997. Biochemical and physiological alterations following short term exposure to fluvalinate—a synthetic pyrethroid. Indian J Pharmacol 29:250–254.
*Gaughan LC, Ackerman ME, Unai T, . 1978. Distribution and metabolism of trans- and cis-permethrin in lactating Jersey cows. J Agric Food Chem 26(3):813–818.
*Gaughan LC, Unai T, Casida JE. 1977. Permethrin metabolism in rats. J Agric Food Chem 25(1):9–17.
*Geetha KY, Devi KR. 1992. Evaluation of cypermethrin for mutagenicity in somatic and germ cells of mice. Trends Life Sci 7(2):99–104.
George DA. 1985. Chemical contaminants monitoring. J Assoc Off Anal Chem 68(6):1160–1163.4086440
*Ghiasuddin SM, Soderlund DM. 1984. Hydrolysis of pyrethroid insecticides by soluble mouse brain esterases. Toxicol Appl Pharmacol 74:390–396.6740686
*Ghosh AK, Sharma A, Talukder G. 1992. Cytotoxic effects of Sumicidin, a Type II synthetic pyrethroid, on mice in vivo at 6, 12 and 24 h after exposure. Cytobios 71:85–91.1473356
Ghosh TK. 1990. Biochemical changes induced by the insecticide fenvalerate in the male gonads of albino rat. Environ Ecol 8(1):63–67.
*Gianessi LP, Silvers CS. 2000. Trends in crop pesticide use: Comparing 1992 and 1997. Washington, DC: National Center for Food and Agricultural Policy.
Gilbert ME, Mack CM, Crofton KM. 1989. Pyrethroids and enhanced inhibition in the hippocampus of the rat. Brain Res 477:314–321.2702491
Giri S, Sharma GD, Giri A, . 2002. Fenvalerate-induced chromosome aberrations and sister chromatid exchanges in the bone marrow cells of mice in vivo. Mutat Res 520:125–132.12297152
*Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Glickman AH, Casida JE. 1982. Species and structural variations affecting pyrethroid neurotoxicity. Neurobehav Toxicol Teratol 4:793–799.6763155
Glowa JR. 1986. Acute and sub-acute effects of deltamethrin and chlordimeform on schedule-controlled responding in the mouse. Neurobehav Toxicol Teratol 8:97–102.3703100
*Go V, Garey J, Wolff MS, . 1999. Estrogenic potential of certain pyrethroid compounds in the MCF-7 human breast carcinoma cell line. Environ Health Perspect 107(3):173–177.10064545
*Goldfrank LR, Flomenbaum NE, Lewin NA, . 1998. Goldfrank’s toxicologic emergencies. 6th ed. Stamford, CT: Appleton & Lange.
Gombe S, Ogada TA. 1988. Health of men on long term exposure to pyrethrins. E Afr Med J 65(11):734–742.
*Gomes M, Bernardi MM, Spinosa H. 1991a. Effects of prenatal pyrethroid insecticide exposure on the sexual development of rats. Vet Hum Toxicol 33(5):427–428.1746129
Gomes M, Bernardi MM, Spinosa H. 1991b. Pyrethroid insecticides and pregnancy: Effect on physical and behavioral development of rats. Vet Hum Toxicol 33(4):315–317.1897124
Goswami N, Chatterjee SK. 1993. Effect of cypermethrin on hematological variables of albino mice. Environ Ecol 11(3):653–655.
*Gotoh Y, Kawakami M, Matsumoto N, . 1998. Permethrin emulsion ingestion: Clinical manifestations and clearance of isomers. Clin Toxicol 36(1&2):57–61.
*Graillot C, Hoellinger H. 1982. Binding of two pyrethroid isomers, cismethrin and bioresmethrin, to liver proteins. Toxicol Appl Pharmacol 66(313–318):313–318.6762698
*Grant SMB. 1993. An unusual cause of burning mouth sensation. Br Dent J 175:378–380.8257649
*Gray AJ, Connors TA. 1980. Delayed toxicity after intravenous administration of bioresmethrin to rats. Pestic Sci 11:361–366.
*Gray AJ, Rickard J. 1982. The toxicokinetics of deltamethrin in rats after intravenous administration of a toxic dose. Pestic Biochem Physiol 18:205–215.
*Gray AJ, Soderlund DM. 1985. Mammalian toxicology of pyrethroids. In: Hutson DH, Roberts TR, eds. Insecticides. Vol 5: Progress in pesticide biochemistry and toxicology. New York, NY: John Wiley and Sons Ltd., 193–248.
*Gray AJ, Connors TA, Hoellinger H, . 1980a. The relationship between the pharmacokinetics of intravenous cismethrin and bioresmethrin and their mammalian toxicity. Pestic Biochem Physiol 13:281–293.
Gray A, Connors TA, Rickard J. 1980b. Mechanism of mammalian toxicity of the pyrethroids. In: Littauer UZ, Silman DI, Teichberg VI, ., eds. Neurotransmitters and their receptors. New York, NY: John Wiley and Sons Ltd, 565–568.
Grindem CB, Corbett WT, Tomkins MT. 1990. Risk factors for Haemobartonella felis infection in cats. J Am Vet Med Assoc 196(1):96–102.2295559
Grosse G, Thiele T, Heuckendorf E, . 2002. Deltamethrin differentially affects neuronal subtypes in hippcampal primary culture. Neuroscience 112(1):233–241.12044486
*Gunderson EL. 1988. FDA total diet study, April 1982-1984, dietary intakes of pesticides, selected elements, and other chemicals. J Assoc Off Anal Chem 71:1200–1209.3240978
*Gunderson EL. 1995a. Dietary intakes of pesticides, selected elements, and other chemicals: FDA total diet study, June 1984–April 1986. J Assoc Off Anal Chem Int 78(4):910–921.
*Gunderson EL. 1995b. FDA Total diet study, July 1986-April 1991, Dietary intakes of pesticides, selected elements, and other chemicals. J Assoc Off Anal Chem Int 78(6):1353–1363.
Gupta A, Agarwal R, Shukla GS. 1999a. Functional impairment of blood-brain barrier following pesticide exposure during early development in rats. Hum Exp Toxicol 18:174–179.10215108
Gupta MK, Jha GJ, Singh KK. 1999b. Effects of chronic cypermethrin toxicity on thyroid function in goats. Indian Vet J 76:340–341.
*Gupta PK. 1990. Teratogenic effects of cypermethrin in rats. J Environ Biol 11(2):121–126.
Gupta PK, Kumar S. 1991. Cumulative toxicity of deltamethrin in mice. J Environ Biol 12(1):45–50.
*Gupta RK, Mehr ZA, Korte DW, . 1990. Mutagenic potential of permethrin in the Drosophila melanogaster (diptera: drosophilidae) sex-linked recessive lethal test. J Econ Entomol 83(3):721–724.2115898
*Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Habazin-Novak V, Pleština R. 1984. The effect of deltamethrin on induction of hepatic microsomal cytochrome P-450 in rats. Period Biol 86(4):315–316.
Habazin-Novak V, Fajdetic T, Kramaric M. 1985. Effects of technical malathion and deltamethrin on hepatic microsomal cytochrome P-450 and antipyrine half-life in rats. Iugosl Physiol Pharmacol Acta 21(2):149–153.
*Haddad LM, Shannon MW, Winchester JR. 1998. Clinical management of poisoning and drug overdose. 3rd ed. Philadelphia, PA: W.B. Saunders Company.
Hadnagy W, Seemayer NH, Kuhn K-H, . 1999. Induction of mitotic cell division disturbances and mitotic arrest by pyrethroids in V79 cell cultures. Toxicol Lett 107:81–87.10414784
Haggas RL, Rees L, Thompson HM, . 1991. Sexual dimorphism in trans-cypermethrin hydrolysis in the domestic chicken. Biochem Soc Trans 19:303S.1783142
Hagiwara A, Yamada M, Hasegawa R, . 1990. Lack of enhancing effects of fenvalerate and esfenvalerate on induction of preneoplastic glutathione S-transferase placental form positive liver cell foci in rats. Cancer Lett 54:67–73.2208092
*Haitzer M, Höss S, Traunspurger W, . 1998. Effects of dissolved organic matter (DOM) on the bioconcentration of organic chemicals in aquatic organisms—A review. Chemosphere 37(7):1335–1362.9734324
*Haley RW, Kurt TL. 1997. Self-reported exposure to neurotoxic chemical combinations in the Gulf War: A cross-sectional epidemiologic study. JAMA 277:231–237.9005273
*Haley RW, Hom J, Roland PS, . 1997a. Evaluation of neurologic function in Gulf War veterans: A blinded case-control study. JAMA 277(3):223–230.9005272
*Haley RW, Kurt TL, Hom J. 1997b. Is there a Gulf War syndrome? Searching for syndromes by factor analysis of symptoms. JAMA 277(3):215–222.9005271
Hall LW, Alden RW. 1997. A review of concurrent ambient water column and sediment toxicity testing in the Chesapeake Bay watershed: 1990-1994. Environ Toxicol Chem 16(8):1606–1617.
Hasan NRA, El-Mahdy MM, Hamouda MA, . 1994. Pathological studies on the effect of pyrethroids aerosol on albino rats. Vet Med J Giza 42(1):23–29.
*Hassan AB, Soliman GA, Farag AA, . 1993. Effect of the synthetic pyrethroids Sumicidin and S-3206 on male rat fertility. Vet Med J Giza 41(2):33–38.
Hassouna I, Wickert H, El-Elaimy I, . 1996. Systemic application of pyrethroid insecticides evokes differential expression of c-fos and c-jun proteins in rat brain. Neurotoxicology 17(2):415–432.8856738
*HazDat. 2003. Agency of Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. April 2003.
*He F, Deng H, Ji X, . 1991. Changes of nerve excitability and urinary deltamethrin in sprayers. Int Arch Occup Environ Health 62:587–590.1856014
*He F, Sun J, Han K, . 1988. Effects of pyrethroid insecticides on subjects engaged in packaging pyrethroids. Br J Ind Med 45:548–551.3415921
*He F, Wang S, Liu L, . 1989. Clinical manifestations and diagnosis of acute pyrethroid poisoning. Arch Toxicol 63:54–58.2742502
Heath J, Leahey JP. 1989. The metabolism of tefluthrin in the goat. Pestic Sci 25:375–389.
Heder AF, Hirsch-Ernst KI, Bauer D, . 2001. Induction of cytochrome P450 2B1 by pyrethroids in primary rat hepatocyte cultures. Biochem Pharmacol 62:71–79.11377398
Helson BV, Payne NJ, Sundaram KMS. 1993. Impact assessment of spray drift from silvicultural aerial applications of permethrin on aquatic invertebrates using mosquito bioassays. Environ Toxicol Chem 12:1635–1642.
Hemming H, Flodström S, Wärngård L. 1993. Enhancement of altered hepatic foci in rat liver and inhibition of intercellular communication in vitro by the pyrethroid insecticides fenvalerate, flucythrinate and cypermethrin. Carcinogenesis 14(12):2531–3535.7903603
*Hend RW, Gellatly JBM, Fleming DJ. 1979. Toxicity studies on the insecticide WL 41706: A three generation reproduction study (minus histopathology) in rats. Shell Oil Co. OTS0534728.
Henshel DS, Allen CA, Lam Y, . 1996. A comparison of the early embryo effects of ethanol, 1,1,1-trichloroethane, atrazine, 2,4-D, methyl mercury, lead and 2,3,7,8-TCDD. Toxicologist March(1 pt2):197.
*Herrera A, Laborda E. 1988. Mutagenic activity in synthetic pyrethroids in Salmonella typhimurium. Mutagenesis 3(6):509–514.3070291
Heudorf U, Angerer Juergen. 2001. Metabolites of pyrethroid insecticides in urine specimens: Current exposure in an urban population in Germany. Environ Health Perspect 109(3):213–7.11333180
*Hext PM. 1987. PP321: 4-Hour acute inhalation toxicity study in the rat. Imperial Chemical Industries PLC. OTS0545653.
*Hext PM, Brammer A, Chalmers DT, . 1986. PP321: 1 Year oral dosing study in dogs. ICI Amers Inc. OTS0545310.
*Hiatzer M, Hoss S, Traunspurger W, . 1998. Effects of dissolved organic matter (DOM) on the bioconcentration of organic chemicals in aquatic organisms—a review. Chemosphere 37(7):1335–1362.9734324
Hijzen TH, Slangen JL. 1988. Effect of Type I and Type II pyrethroids on the startle response in rats. Toxicol Lett 40:141–152.3341055
*Hijzen TH, De Beun R, Slangen JL. 1988. Effects of pyrethroids on the acoustic startle reflex in the rat. Toxicology 49:271–276.3376131
*Hill BD. 1983. Persistence of deltamethrin in a Lethbridge sandy clay loam. J Environ Sci Health B18(6):691–703.
*Hill BD, Johnson DL. 1987. Persistence of deltamethrin and its isomers on pasture forage and litter. J Agric Food Chem 35:373–378.
*Hiromori T, Nakanishi T, Kawaguchi S, . 1986. Therapeutic effects of methocarbamol on acute intoxication by pyrethroids in rats. J Pestic Sci 11:9–14.
*Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
*Hoellinger H, Lecorsier A, Sonnier M, . 1987. Cytotoxicity, cytogenotoxicity and allergenicity tests on certain pyrethroids. Drug Chem Toxicol 10:291–310.3428187
Hoellinger H, Sonnier M, Pichon J, . 1983. In vivo covalent binding of cismethrin and bioresmethrin to hepatic proteins. Toxicol Lett 19:179–187.6658824
Holloway SF, Salgado VL, Wu CH, . 1989. Kinetic properties of single sodium channels modified by fenvalerate in mouse neuroblastoma cells. Pflugers Arch 414:613–621.2554247
Holmstead RL, Soderlund DM. 1977. Separation and analysis of the pyrethrins by combined gas-liquid chromatography-chemical ionization mass spectrometry. J Assoc Off Anal Chem 60(1):685–689.870491
Hornychova M, Frantik E, Kubat J, . 1995. Neurotoxicity profile of supermethrin, a new pyrethroid insecticide. Cent Eur J Public Health 3(4):210–218.8903524
Hotchkiss SA, Hewitt P, Caldwell J. 1990. Absorption of cypermethrin through rat skin in vitro. Eur J Pharmacol 183:367.
*Hour T-C, Chen L, Lin J-K. 1998. Comparative investigation on the mutagenicities of organophosphate, phthalimide, pyrethroid and carbamate insecticides by the Ames and lactam tests. Mutagenesis 13(2):157–166.9568589
*Howard PH, Meylan WM. 1997. Handbook of physical properties of organic chemicals. Boca Raton, FL: Lewis Publishers.
Hoy JB, Cornell JA, Karlix JL, . 2000a. Interactions of pyridostigmine bromide, DEET and permethrin alter locomotor behavior of rats. Vet Hum Toxicol 42(2):65–71.10750168
Hoy JB, Cornell JA, Karlix JL, . 2000b. Repeated coadministration of pyridostigmine bromide, DEET, and permethrin alter locomotor behavior of rats. Vet Hum Toxicol 42(2):72–76.10750169
*HSDB. 2001. Pyrethrum: Environmental standards and regulations. Hazardous Substances Data Bank. http://toxnet.nlm.nih.gov/. April 19, 2001.
*Hudson PM, Tilson HA, Chen PH, . 1986. Neurobehavioral effects of permethrin are associated with alterations in regional levels of biogenic amine metabolites and amino acid neurotransmitters. Neurotoxicology 7(1):143–154.2872638
Hundley HK, Cairns T, Luke MA, . 1988. Pesticide residue findings by the Luke Method in domestic and imported foods and animal feeds for fiscal years 1982-1986. J Assoc Off Anal Chem 71(5):875–892.3235407
*Hunt LM, Gilbert BC. 1977. Distribution and excretion rates of ^14^C-labeled permethrin isomers administered orally to four lactating goats for 10 days. J Agric Food Chem 25(3):673–676.558240
Hunt LM, Gilbert BN, Lemeilleur CA. 1979. Distribution and depletion of radioactivity in hens treated dermally with ^14^C-labeled permethrin. Poult Sci 58:1197–1201.523385
*Husain R, Seth PK. 1991. Neurotoxic effects of deltamethrin, a synthetic pyrethroid during early development in rats. [Abstract]. Int J Toxicol Occup Environ Health 1(1):138.
*Husain R, Gupta A, Khanna VK, . 1991. Neurotoxicological effects of a pyrethroid formulation, fenvalerate in rats. Res Commun Chem Pathol Pharmacol 73:111–114.1882120
Husain R, Husain R, Adhami VM, . 1996. Behavioral, neurochemical, and neuromorphological effects of deltamethrin in adult rats. J Toxicol Environ Health 48:515–526.8751838
*Hussain M, Perschke H. 1991. A study of factors affecting the persistence of deltamethrin applied to cotton fabric for tsetse fly control. Chemosphere 22(7):677–684.
*Hutson DH. 1979. The metabolic fate of synthetic pyrethroid insecticides in mammals. Prog Drug Metab 5:215–252.
Hutson DH, Casida JE. 1978. Taurine conjugation in metabolism of 3-phenoxybenzoic acid and the pyrethroid insecticide cypermethrin in mouse. Xenobiotica 8(9):565–571.695699
Hutson DH, Logan CJ. 1986. The metabolic fate in rats of the pyrethroid insecticide WL85871, a mixture of two isomers of cypermethrin. Pestic Sci 17:548–558.
*IARC. 2001. IARC agents and summary evaluations. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/. April 19, 2001.
Imamura L, Hasegawa H, Kurashina K, . 2002. Neonatal exposure of newborn mice to pyrethoid (permethrin) represses activity-dependent c-fos mRNA expression in cerebellum. Arch Toxicol 76:392–397.12111003
Institóris L, Siroki O, Undeger U, . 1999a. Immunotoxicological effects of repeated combined exposure by cypermethrin and the heavy metals lead and cadmium in rats. Int J Immunopharmacol 21:735–743.10576619
Institoris L, Siroki O, Undeger U, . 2001. Immunotoxicological investigation of subacute combined exposure by permethrin and the heavy metals arsenic(III) and mercury(II) in rats. Int Immunopharmacol 1:925–933.11379047
Institoris L, Siroki O, Undeger U, . 2002. Immunotoxicological investigation i rats dosed repeatedly with combinations of cypermethrin, As (III), and Hg(II). Toxicology 172:59–67.11844615
*Institóris L, Undeger U, Siroki O, . 1999b. Comparison of detection sensitivity of immuno- and genotoxicological effects of subacute cypermethrin and permethrin exposure in rats. Toxicology 137:47–55.10513999
*IRIS. 2003a. Chronic health hazard assessments for noncarcinogenic effects: Cyhalothrin. U.S. Environmental Protection Agency. Integrated Risk Information System. http://www.epa.gov/iris/subst/0279.htm. May 14, 2003.
*IRIS. 2003b. Chronic health hazard assessments for noncarcinogenic effects: Cypermethrin. U.S. Environmental Protection Agency. Integrated Risk Information System. http://www.epa.gov/iris/subst/0380.htm. May 14, 2003.
*IRIS. 2003c. Chronic health hazard assessments for noncarcinogenic effects: Danitol. U.S. Environmental Protection Agency. Integrated Risk Information System. http://www.epa.gov/iris/subst/0034.htm. May 14, 2003.
*IRIS. 2003d. Chronic health hazard assessments for noncarcinogenic effects: Permethrin. U.S. Environmental Protection Agency. Integrated Risk Information System. http://www.epa.gov/iris/subst/0185.htm. May 14, 2003.
*IRIS. 2003e. Chronic health hazard assessments for noncarcinogenic effects: Resmethrin. U.S. Environmental Protection Agency. Integrated Risk Information System. http://www.epa.gov/iris/subst/0343.htm. May 14, 2003.
*IRIS. 2003f. U.S. Environmental Protection Agency. Integrated Risk Information System. http://www.epa.gov/iris/subst/index.html. April 3, 2003.
Ishikawa Y, Charalambous P, Matsumura F. 1989. Modification by pyrethroids and DDT of phosphorylation activities of rat brain sodium channel. Biochem Pharmacol 38(15):2449–2457.2547381
*Ishmael J, Litchfield MH. 1988. Chronic toxicity and carcinogenic evaluation of permethrin in rats and mice. Fundam Appl Toxicol 11:308–322.3220209
Isobe N, Kaneko H, Shiba K, . 1990. Metabolism of esfenvalerate in rats and mice and effects of its isomers on metabolic fates of esfenvalerate. J Pestic Sci 15:159–168.
Ivie GW, Casida JE. 1971a. Photosensitizers for the accelerated degradation of chlorinated cyclodienes and other insecticide chemicals exposed to sunlight on bean leaves. J Agric Food Chem 19(3):410–416.
Ivie GW, Casida JE. 1971b. Sensitized photodecomposition and photosensitizer activity of pesticide chemicals exposed to sunlight on silica gel chromatoplates. J Agric Food Chem 19(3):405–409.
Izumi T, Kaneko H, Matsuo M, . 1984. Comparative metabolism of the six stereoisomers of phenothrin in rats and mice. J Pestic Sci 9:259–267.
Jain RK. 1996. Fenvalerate (α-cyano-m-phenoxy-benzyl α-isopropyl-p-chlorophenyl acetate) residues in and on okra fruits. Sci Total Environ 187:253–255.8711468
Jao LT, Casida JE. 1974. Esterase inhibitors as synergists for (+)-trans-chrysanthemate insecticide chemicals. Pestic Biochem Physiol 4:456–464.
*Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs. cerebral cortex. Brain Res 190:3–16.6769537
Johnstone DR, Cooper JF, Dobson HM. 1987. The availability and fall-out of an insecticidal aerosol dispersed from aircraft during operations for control of tsetse fly in Zimbabwe. Atmos Environ 21(11):2311–2321.
Jokanović M, Maksimović M. 1995. A comparison of trinedoxime, obidoxime, pralidoxime and HI-6 in the treatment of oral organophophorus insecticide poisoning in the rat. Arch Toxicol 70:119–123.8773184
Jordan EG, Kaufman DD. 1986. Degradation of cis- and trans-permethrin in flooded soil. J Agric Food Chem 34:880–884.
Joy RM, Albertson TE. 1991. Interactions of GABA_A_ antagonists with deltamethrin, diazepam, pentobarbital, and SKF100330A in the rat dentate gyrus. Toxicol Appl Pharmacol 109:251–262.2068725
Joy RM, Lister T, Ray DE, . 1990. Characteristics of the prolonged inhibition produced by a range of pyrethroids in the rat hippocampus. Toxicol Appl Pharmacol 103:528–538.2339424
Juhler RK, Lauridsen MG, Christensen MR, . 1999. Pesticide residues in selected food commodities: Results from the Danish National Pesticide Monitoring Program 1995-1996. J Assoc Off Anal Chem Int 82(2):337–358.
*Junting L, Chuichang F. 1991. Solid phase extraction method for rapid isolation and clean-up of some synthetic pyrethroid insecticides from human urine and plasma. Forensic Sci Int 51:89–93.1752596
Kadota T, Okuno Y, Kohda H, . 1976. Mammalian toxicological study of permethrin, 3-phenoxybenzyl ±-cis, trans-2,2-dimethyl-3-(2,2-dichlorovinyl)-cyclopropane-1-carboxylate. Botyu-Kagaku 41:143–151.
Kadous A, Matsumura F, Enan E. 1994. High affinity binding of ^3^H-verapamil to rat brain synaptic membrane is antagonized by pyrethroid insecticides. J Environ Sci Health B 29(5):855–871.8089431
Kale M, Rathore N, John S, . 1999. Lipid peroxidative damage on pyrethroid exposure and alterations in antioxidant status in rat erythrocytes: A possible involvement of reactive oxygen species. Toxicol Lett 105:197–205.10355540
*Kale PG, Petty BT, Walker S, . 1995. Mutagenicity testing of nine herbicides and pesticides currently used in agriculture. Environ Mol Mutagen 25:148–153.7698107
Kallman M, Sylianco-Wu L, Wilson M, . 1990. Ability of diazepam (DZ) to block the perinatal neurotoxicity of Type I and Type II pyrethroid formulations. Toxicologist 10(1):172.
Kamei J, Iguchi E, Sasaki M, . 2002. Modification of the fenvalerate-induced noiceptive response in mice by diabetes. Brain Res 948:17–23.12383951
Kaneko H, Izumi T, Matsuo M, . 1984a. Metabolism of fenvalerate in dogs. J Pestic Sci 9:269–274.
*Kaneko H, Izumi T, Ueda Y, . 1984b. Metabolism and placental transfer of stereoisomers of tetramethrin isomers in pregnant rats. J Pestic Sci 9:249–258.
Kaneko H, Matsuo M, Miyamoto J. 1984c. Comparative metabolism of stereoisomers of cyphenothrin and phenothrin isomers in rats. J Pestic Sci 9:237–247.
Kaneko H, Ohkawa H, Miyamoto J. 1981a. Absorption and metabolism of dermally applied phenothrin in rats. J Pestic Sci 6:169–182.
Kaneko H, Ohkawa H, Miyamoto J. 1981b. Comparative metabolism of fenvalerate and the [2S, αS]-isomer in rats and mice. J Pestic Sci 6:317–326.
Kaneko H, Ohkawa H, Miyamoto J. 1981c. Metabolism of tetramethrin isomers in rats. J Pestic Sci 6:425–435.
Kaneko H, Shiba K, Yoshitake A, . 1987. Metabolism of fenpropathrin (S-3206) in rats. J Pestic Sci 12:385–395.
Karen DJ, Li W, Harp PR, . 2001. Striatal dopaminergic pathways as a target for the insecticides permethrin and chlorpyrifos. Neurotoxicology 22(6):811–7.11829414
Karmos-Várszegi M, Dési I. 1984. Acute effect of pyrethroid insecticides on the behaviour of mice. Acta Physiol Hung 63:343–344.
*Katagi T. 1991. Photodegradation of the pyrethroid insecticide esfenvalerate on soil, clay minerals, and humic acid surfaces. J Agric Food Chem 39:1351–1356.
Kathren RL. 1994. Toward improved biokinetic models for actinides: the United States Transuranium and Uranium Registries, a twenty-five year report. Radiat Prot Dosim 53(1–4):219–227.
Kathren RL. 1995. The United States Transuranium and Uranium Registries: 1968–1993. Radiat Prot Dosim 60(4):349–354.
*Kaufman DD, Russell BA, Helling CS, . 1981. Movement of cypermethrin, decamethrin, permethrin, and their degradation products in soil. J Agric Food Chem 29:239–245.
Kaul PP, Rastogi A, Hans RK, . 1996. Fenvalerate-induced alterations in circulatory thyroid hormones and calcium stores in rat brain. Toxicol Lett 89:29–33.8952708
Kaur J, Sandhu HS. 2000. Biochemical alterations induced by repeated dermal toxicity of cypermethrin and deltamethrin in buffalo calves. Indian J Anim Sci 70(7):708–709.
*Kavlock R, Chernoff N, Baron R, . 1979. Toxicity studies with decamethrin, a synthetic pyrethroid insecticide. J Environ Pathol Toxicol 2:751–765.370325
*Khan SU, Behki RM, Tapping RI, . 1988. Deltamethrin residues in an organic soil under laboratory conditions and its degradation by a bacterial strain. J Agric Food Chem 36:636–638.
*Khan SU, Kacew S, Akhtar MH. 1986. Bioavailability of bound ^14^C residues in rats from bean plants treated with ^14^C-deltamethrin. Chemosphere 15(7):923–927.
*Khan SU, Kacew S, Akhtar MH. 1990. Bound ^14^C residues in stored wheat treated with [^14^C] deltamethrin and their bioavailabilities in rats. J Agric Food Chem 38:1077–1082.
Khan SU, Schnitzer M, Schulten HR. 1993. Fate of deltamethrin after nine years of incubation in an organic soil under laboratory conditions. J Agric Food Chem 41(7):1143–1151.
Khanna RN, Gupta GSD, Anand M. 2002. Kinetics of distribution of cypermethrin in blood, brain, and spinal cord after a single administration to rabbits. Bull Environ Contam Toxicol 69:749–755.12375126
Khurana R, Mahipal SK, Chauhan RS. 1999. Effect of pesticides on delayed type hypersensitivity reaction in sheep. Indian J Anim Sci 69(11):880–881.
Kim SS, Rhee GS, Kim SH, . 2002. Permethrin affects reproductive development in rats. Teratology 65(6):333.
Knox JM, Tucker SB. 1983. A new cutaneous sensation caused by synthetic pyrethroids. Clin Res 31(2):586A.
*Knox JM, Tucker SR, Flannigan SA. 1984. Paresthesia from cutaneous exposure to a synthetic pyrethroid insecticide. Arch Dermatol 120:744–746.6721539
*Kolmodin-Hedman B, Swensson Å, Åkerblom M. 1982. Occupational exposure to some synthetic pyrethroids (permethrin and fenvalerate). Arch Toxicol 50:27–33.6214240
*Kolpin DW, Barbash JE, Gilliom RJ. 1998. Occurrence of pesticides in shallow groundwater of the United States: Initial results from the National Water-Quality Assessment Program. Environ Sci Technol 32(5):558–566.
*Kolpin DW, Goolsby DA, Thurman EM. 1995. Pesticides in near-surface aquifers: an assessment using highly sensitive analytical methods and tritium. J Environ Qual 24:1125–1132.
*Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
Kostka G, Palut D, Kopeć-Szlęzak J, . 2000. Early hepatic changes in rats induced by permethrin in comparison with DDT. Toxicology 142:135–143.10685513
Kowalczyk-Bronisz SH, Gieldanowski J, Bubak B. 1990. Immunological profile of animals exposed to pesticide - deltamethrin. Arch Immunol Ther Exp 38:229–238.
*Krapac IG, Roy WR, Smyth CA, . 1995. Occurrence and distribution of pesticides in soil at agrichemical facilities in Illinois. J Soil Contam 4(3):209–226.
*Kreuger J, Peterson M, Lundgren E. 1999. Agricultural inputs of pesticide residues to stream and pond sediments in a small catchment in southern Sweden. Bull Environ Contam Toxicol 62:55–62.9870990
*Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. New York, NY: Raven Press, Ltd., 149–188.
*Krishnan K, Anderson ME, Clewell HJ III, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. New York, NY: Academic Press, 399–437.
Krishnappa K, Honnegowda, Jayakumar K, . 1999a. Effect of lambda cyhalothrin, on non-specific immune response in rats. Indian Vet J 76:1058–1061.
Krishnappa H, Honnegowda, Suresh TP, . 1999b. Effect of λ-cyhalothrin, a synthetic pyrethroid insecticide on certain defense mechanisms and immune response in male rats. Indian Vet J 76:506–510.
Krishnappa H, Honnegowda, Suresh TP, . 2000. Acute toxicity study of lambda cyhalothrin, a pyrethroid insecticide in rats. Indian Vet J 77:768–769.
Kühn K-H, Leng G, Bucholski KA, . 1996. Determination of pyrethroid metabolites in human urine by capillary gas chromatography-mass spectrometry. Chromatographia 13:285–292.
*Kühn KH, Wieseler B, Leng G, . 1999. Toxicokinetics of pyrethroids in humans: consequences for biological monitoring. Bull Environ Contam Toxicol 62:101–108.9933305
Kumar S, Dhanaraj PS, Bhatnagar P. 1989. Bioconcentration and effects of dieldrin, dimethoate, and permethrin on Saccharomyces cerevisiae. Bull Environ Contam Toxicol 43:246–253.2673440
*Kunimatsu T, Yamada T, Keiko O, . 2002. Lack of (anti-) androgenic or estrogenic effects of three pyrethroids (esfenvalerate, fenvalerate, and permethrin) in the Hershberger and uterotrophic assays. Regul Toxicol Pharmacol 35:227–237.12052007
*Laughlin J, Newburn K, Gold RE. 1991. Pyrethroid insecticides and formulations as factors in residues remaining in apparel fabrics after laundering. Bull Environ Contam Toxicol 47:355–361.1768948
*Lawrence LL, Casida JE. 1983. Stereospecific action of pyrethroid insecticides on the γ-aminobutyric acid receptor-ionophore complex. Science 221:1399–1401.6310756
Lazarini CA, Florio JC, Lemonica IP, . 2001. Effects of prenatal exposure to deltamethrin on forced swimming behavior, motor activity, and striatal dopamine levels in male and female rats. Neurotoxicol Teratol 23:665–673.11792535
*Lee PW. 1985. Fate of fenvalerate (Pydrin insecticide) in the soil environment. J Agric Food Chem 33:993–998.
Leahey JP, ed. 1985. The pyrethroid insecticides. Philadelphia PA: Taylor and Francis, 263–342.
Lee PW, Stearns SM, Powell WR. 1985. Rat metabolism of fenvalerate (Pydrin insecticide). J Agric Food Chem 33:988–993.
*Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
*Leng G, Lewalter J. 1999. Role of individual susceptibility in risk assessment of pesticides. Occup Environ Med 56:449–453.10472315
*Leng G, Kuhn K-H, Idel H. 1996. Biological monitoring of pyrethroid metabolites in urine of pest control operators. Toxicol Lett 88:215–220.8920739
*Leng G, Kühn K-H, Idel H. 1997a. Biological monitoring of pyrethroids in blood and pyrethroid metabolites in urine: Applications and limitations. Sci Total Environ 199:173–181.9200861
*Leng G, Kühn K-H, Wieseler B, . 1999a. Metabolism of (S)-bioallethrin and related compounds in humans. Toxicol Lett 107:109–121.10414788
*Leng G, Leng A, Kühn K, . 1997b. Human dose-excretion studies with the pyrethroid insecticide cyfluthrin: Urinary metabolite profile following inhalation. Xenobiotica 27(12):1273–1283.9460232
*Leng G, Lewalter J, Röhrig B, . 1999b. The influence of individual susceptibility in pyrethroid exposure. Toxicol Lett 107:123–130.10414789
Lenza-Rizos C, Avramides EJ. 1995. Pesticide residues in olive oil. Rev Environ Contam Toxicol 141:111–131.7886254
*LeQuesne PM, Maxwell IC. 1980. Transient facial sensory symptoms following exposure to synthetic pyrethroids: A clinical and electrophysiological assessment. Neurotoxicology 2:1–11.
*Lessenger JE. 1992. Five office workers inadvertently exposed to cypermethrin. J Toxicol Environ Health 35:261–267.1578509
Lessenger JE. 1995. A rash and chemical burns in a cowboy exposed to permethrin. J Agromed 2(3):25–28.
*Leung H-W. 1993. Physiologically-based pharmacokinetic modeling. In: Ballentine B, Marro T, Turner P, eds. General and applied toxicology. New York: Stockton Press, 153–164.
*Lewis RG, Bond AE, Johnson DE, . 1988. Measurement of atmospheric concentration of common household pesticides: A pilot study. Environ Monit Assess 10:59–73.24248528
*Litchfield MH. 1985. Toxicity to mammals. In: Leahey JP, ed. The pyrethroid insecticides. London: Taylor & Francis, 99–150.
*Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
Llewellyn DM, Brazier A, Brown R, . 1996. Occupational exposure to permethrin during its use as a public hygiene insecticide. Ann Occup Hyg 40(5):499–509.8888633
Lock EA, Berry PN. 1980. Biochemical changes in the rat cerebellum following cypermethrin administration. Dev Toxicol Environ Sci 8:623–626.6273108
Lock EA, Berry PN. 1981. Biochemical changes in the rat cerebellum following cypermethrin administration. Toxicol Appl Pharmacol 59:508–514.6267733
*Loeser E, Eiben R. 1983. Multigeneration study on rats. Mobay Chemical Corporation. OTS0555303.
*Lombet A, Mourre C, Lazdunski M. 1988. Interaction of insecticides of the pyrethroid family with specific binding sites on the voltage-dependent sodium channel from mammalian brain. Brain Res 459:44–53.2844361
Lord KA, McKinley M, Walker N. 1982. Degradation of permethrin in soils. Environ Pollut 29(Series A):81–90.
Luke MA, Masumoto HT, Cairns T, . 1988. Levels and incidences of pesticide residues in various foods and animal feeds analyzed by the Luke multiresidue methodology for fiscal years 1982-1986. J Assoc Off Anal Chem 71(2):415–420.3384794
*Lukowicz-Ratajczak J, Krechniak J. 1992. Effects of deltamethrin on the immune system in mice. Environ Res 59:467–475.1464294
*Lutnicka H, Bogacka T, Wolska L, . 1999. Degradation of pyrethroids in an aquatic ecosystem model. Wat Res 33(16):3441–3446.
Luty S, Latuszyńská J, Halliop J, . 1998. Toxicity of dermally applied alpha-cypermethrin in rats. Ann Agric Environ Med 5:109–115.9860811
Luty S, Latuszyńská J, Pbuchowska-Przebirowska D, . 2000. Subacute toxicity of orally applied alpha-cypermethrin in Swiss mice. Ann Agric Environ Med 7:33–41.10865243
Lykken L. 1972. Role of photosensitizers in alteration of pesticide residues in sunlight. In: Matsumura F, Boush GM, Misato T, eds. Environmental toxicology of pesticides. New York, NY: Academic Press, 449–469.
MacRae IC. 1989. Microbial metabolism of pesticides and structurally related compounds. Rev Environ Contam Toxicol 109:1–87.2675207
*Madsen C, Claesson MH, Röpke C. 1996. Immunotoxicity of the pyrethroid insecticides deltamethrin and α-cypermethrin. Toxicology 107:219–227.8604482
Magnusson B, Blohm SG, Fregert S, . 1968. Routine patch testing IV: Supplementary series of test substances for Scandinavian countries. Acta Derm Venereol (Stockh) 48:110–114.4172191
*Maguire RJ. 1990. Chemical and photochemical isomerization of deltamethrin. J Agric Food Chem 38:1613–1617.
Maguire RJ. 1992a. Aquatic environmental fate of deltamethrin. Water Sci Technol 25(11):99–102.
Maguire RJ. 1992b. The importance of pesticide volatilization form the surface microlayer of natural waters after aerial spraying. Water Sci Technol 25(11):111–116.
*Maguire RJ, Carey JH, Hart JH, . 1989. Persistence and fate of deltamethrin sprayed on a pond. J Agric Food Chem 37:1153–1159.
*Maiti PK, Kar A. 1998. Is triiodothyronine capable of ameliorating pyrethroid-induced thyroid dysfunction and lipid peroxidation? J Appl Toxicol 18:125–128.9570695
Maity NK, Punia JS. 1991. Effect of fluvalinate, a synthetic pyrethroid on learning and memory traces in rats. Indian J Exp Biol 29:178–179.1869303
Majumder S, Chakraborty AK, Mandal TK, . 1994. Subacute toxicity of fenvalerate in broiler chicks: Concentration, cytotoxicity and biochemical profiles. Indian J Exp Biol 32:752–756.7821986
*Malaviya M, Husain R, Seth PK, . 1993. Perinatal effect of two pyrethroid insecticides on brain neurotransmitter function in the neonatal rat. Vet Hum Toxicol 35(2):119–122.8385837
*Malley LA, Cagen SZ, Parker CM, . 1985. Effect of vitamin E and other amelioratory agents on the fenvalerate-mediated skin sensation. Toxicol Lett 29:51–58.2867622
Malone JC, Brown NC. 1968. Toxicity of various grades of pyrethrum to laboratory animals. Pyrethrum Post 4(3):3–8.
Malpe ND, Phadnaik BS, Sadeker RD, . 1996. Acute toxicity studies of deltamethrin in rats. Indian Vet J 73:217–219.
Mandal TK, Bhattacharya A, Chakraborty AK, . 1992. Disposition kinetics, cytotoxicity and residues of fenvalerate in tissues following oral administration to goats. Pestic Sci 35:201–207.
*Mandal TK, Chakraborty AK, Bhattacharya A, . 1996. The disposition of kinetics and residues of fenvalerate in tissues following a single dermal application to black Bengal goats. Vet Res Commun 20:265–272.8739525
*Mandhane SN, Chopde CT. 1997. Neurobehavioral effects of low level fenvalerate exposure in mice. Indian J Exp Biol 35:623–627.9357167
Marei A, Ruzo LO, Casida JE. 1982. Analysis and persistence of permethrin, cypermethrin, deltamethrin, and fenvalerate in the fat and brain of treated rats. J Agric Food Chem 30:558–562.7096807
Martin CN, Kennelly JC. 1985. Metabolism, mutagenicity, and DNA binding of biphenyl-based azodyes. Drug Metab Rev 16:89–117.3905319
Masri MS, Hendrickson AP, Cox AJ, . 1964. Subacute toxicity of two chrysanthemumic acid esters: Barthrin and dimethrin. Toxicol Appl Pharmacol 6:716–725.14235839
*Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
*Mbaria JM, Maitho TE, Muchiri DJ. 1993. Median lethal doses, clinical signs and post-mortem changes in acute pyrethrins toxicity in sheep and rabbits. Pyrethrum Post 19(1):26–29.
*McCain WC, Lee R, Johnson MS, . 1997. Acute toxicity study of pyridostigmine bromide, permethrin, and DEET in the laboratory rat. J Toxicol Environ Health 50:113–124.9048956
*McCord CP, Kilker CH, Minster DK. 1921. Pyrethrum dermatitis: A record of the occurrence of occupational dermatosis among workers in the pyrethrum industry. JAMA 77(6):448–449.
*McDaniel KL, Moser VC. 1993. Utility of a neurobehavioral screening battery for differentiating the effects of two pyrethroids, permethrin and cypermethrin. Neurotoxicol Teratol 15:71–83.8510610
McKillop CM, Brock JAC, Oliver GJA. 1984. Pyrethroid and aconitine binding sites. Neurotoxicology 5(4):75.
McKillop CM, Brock JAC, Oliver GJA, . 1987. A quantitative assessment of pyrethroid-induced paraesthesia in the guinea-pig flank model. Toxicol Lett 36:1–7.2436357
McPhail RC, Gordon WA, Johnston MA. 1981. Behavioral effects of a synthetic pyrethroid insecticide (decamethrin). Fed Proc Fed Am Soc Exp Biol 40(3):678.
*Metcalf RL. 1989. Insect control. In: Elvers B, Hawkins S, Ravenscroft M, ., eds. Ullmann’s encyclopedia of industrial chemistry. Germany: VCH, 263–277.
*Metcalf RL. 1995. Insect control technology. In: Kirk-Othmer encyclopedia of chemical technology. New York: John Wiley and Sons, 533–602.
*Meyer EK. 1999. Toxicosis in cats erroneously treated with 45 to 65% permethrin products. J Am Vet Med Assoc 215(2):198–203.10416472
*Meylan WM, Howard PH. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26(12):2293–2299.
Miadoková E, Garajová L. 1994. Genotoxicity testing of the technical supercypermethrin in the SOS chromotest. Acta Fac Rerum Nat Univ Comenianae, Form Prot Nat 16:37–43.
Miadoková E, Garajová L, Podstavková S, . 1993. Non-mutagenic effect of supercypermethrin forte proved in salmonella typhimurium. Acta Fac Rerum Nat Univ Comenianae, Genet Biol Mol 24–25:9–14.
*Miadoková E, Miklovičová M, Dúhová V, . 1991. Effects of the insecticide pyrethroid II in the Ames test, and on Hordeum vulgare and Vicia faba. Biol Plant 33(2):156–162.
*Miadoková E, Vlčková V, Dúhová V, . 1992. Effects of supercypermethrin, a synthetic developmental pyrethroid, on four biological test systems. Mutat Res 280:161–168.1381478
Mikula I, Pistl J, Kačmár P. 1992. Immune response of sheep at subchronic intoxication by pyrethroid insecticide supercypermethrine. Acta Vet Brno 61:57–60.
*Millet M, Wortham H, Sanusi A, . 1997. Atmospheric contamination by pesticides: Determination in the liquid, gaseous and particulate phases. Environ Sci Pollut Res 4(3) 172–180.
*Milne GWA. 1995. CRC handbook of pesticides. Boca Raton: CRC Press.
Misra S, Sharma CB. 1997. Metabolism and bioaccumulation of fenvalerate and its metabolites in rat organs. Biomed Chromatogr 11:50–53.9051218
*Mitchell JA, Wilson MC, Kallman MJ. 1988. Behavioral effects of pydrin and ambush in male mice. Neurotoxicol Teratol 10:113–119.3398818
Mitchell JC, Dupuid G, Towers GH. 1972. Allergic contact dermatitis from pyrethrum (Chrysanthemum spp.). The roles of pyrethrosin, a sesquiterpene lactone, and of pyrethrin II. Br J Dermatol 86:568–573.5045949
*Mitsche T, Borck H, Horr B, . 2000. Pyrethroid syndrome in an animal keeper. Allergy 55:93–94.10696865
*Miyamoto J. 1976. Degradation, metabolism and toxicity of synthetic pyrethroids. Environ Health Perspect 14:15–28.789062
*Miyamoto J, Kaneko H, Tsuji R, . 1995. Pyrethroids, nerve poisons: How their risks to human health should be assessed. Toxicol Lett 82:933–940.8597164
Miyamoto J, Nishida T, Ueda K. 1971. Metabolic fate of resmethrin, 5-benzyl-3-furymethyl dl-trans-chrysanthemate in the rat. Pestic Biochem Physiol 1:293–306.
Miyamoto J, Sato Y, Yamamoto K, . 1968. Biochemical studies on the mode of action of pyrethroidal insecticides. Part I. Metabolic fate of phthalthrin in mammals. Agric Biol Chem 32(5):628–640.
Miyamoto J, Suzuki T, Nakae C. 1974. Metabolism of phenothrin or 3-phenoxybenzyl d- trans-chrysanthemumate in mammals. Pestic Biochem Physiol 4:438–450.
MMWR. 2000. Illnesses associated with use of automatic insecticide dispenser units-Selected states and United States, 1986-1999. Morbidity and Mortality Weekly Report 49:492–495.10881765
Mohamed OSA, Adam SEI. 1990. Toxicity of Sumicidin (fenvalerate) to Nubian goats. J Comp Pathol 102(1):1–6.2312795
Mohamed OSA, Adam SEI. 1992. Effect of phenobarbitone pretreatment on the toxicity of temik and Sumicidin in Nubian goats. Vet Hum Toxicol 34:138–140.1509674
*Mohan EM, Banupriya CAY, Anitha K, . 1998. Effect of sublethal dose of chlorpyrifos 48% EC and cypermethrin 25% EC in Wistar rats. Pollut Res 17(1):13–16.
*Moniz AC, Bernardi NM, Souza-Spinosa HS, . 1990. Effects of exposure to a pyrethroid insecticide during lactation on the behavior of infant and adult rats. Braz J Med Biol Res 23:45–48.2386848
*Moniz AC, Bernardi MM, Spinosa HS. 1994. Effects of a pyrethroid Type II pesticide on conditioned behaviors of rats. Vet Hum Toxicol 36(2):120–124.8197710
Moniz AC, Cruz-Casallas PE, Oliveira CA, . 1999. Perinatal fenvalerate exposure: Behavioral and endocrinology changes in male rats. Neurotoxicol Teratol 21(5):611–618.10492396
Moore JB. 1972. Pyrethrum extract: Part 2. Toxicology and pharmacology of pyrethrum extract. In: Nelson RH, ed. Pyrethrum flowers. Minneapolis, MN: McLaughlin Gormley King Co., 68–82.
*Moore JB. 1975. Pyrethrum extract. In: Nelson RH, ed. Pyrethrum flowers. Minneapolis, MI: McLaughlin Gormley King Co., 68–82.
Moretti M, Villarini M, Scassellati-Sforzolini G, . 1997. Applicability of aspecific noninvasive methods for biomonitoring of occupational exposure to deltamethrin: Preliminary study using an animal model. Arch Environ Contam Toxicol 33:323–328.9353211
*Moretto A. 1991. Indoor spraying with the pyrethroid insecticide λ-cyhalothrin: Effects on spraymen and inhabitants of sprayed houses. Bull WHO 59(5):591–594.
*Moriya M, Ohta T, Watanabe K, . 1983. Further mutagenicity studies on pesticides in bacterial reversion assay systems. Mutat Res 116:185–216.6339892
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
Motomura H, Narahashi T. 2001. Interaction of tetramethrin and deltamethrin at the single sodium channel in rat hippocampal neurons. Neurotoxicology 22(3):329–39.11456334
Mount ME, Moller G, Cook J, . 1991. Clinical illness associated with a commercial tick and flea product in dogs and cats. Vet Hum Toxicol 33(1):19–27.
Moussa M, Iskander KG, Gorgy AA. 1989. Scanning electron microscopic investigation of the effect of chronic toxicity on the permethrin on the tongue papillae of albino rats. Egypt Dent J 35(2):107–115.2630255
*Mueller-Beilschmidt D. 1990. Toxicology and environmental fate of synthetic pyrethroids. J Pestic Ref 10(3). http://www.igc.org/panna/resources/_pestis/PESTIS.1996.14.html. February 22, 2001.
*Muir DCG, Rawn GP, Grift NP. 1985. Fate of the pyrethroid insecticide deltamethrin in small ponds: A mass balance study. J Agric Food Chem 33:603–609.
Müller-Mohnssen H. 1999. Chronic sequelae and irreversible injuries following acute pyrethroid intoxication. Toxicol Lett 107:161–175.10414793
Nakamura Y, Tonogai Y, Sekiguchi Y, . 1994. Multiresidue analysis of 48 pesticides in agricultural products by capillary gas chromatography. J Agric Food Chem 42:2508–2518.
Nakanishi M, Hamada Y, Izaki K. 1970. Toxicological studies on a new pyrethroid: Kikuthrin (part II). Botyu-Kagaku 35:113–116.
Nakanishi M, Kato Y, Furuta T, . 1971. [Metabolic fate of proparthrin. Studies on insecticide. VIII.] Botyu-Kagaku 36:116–121. (Japanese).
*Nakano E, Rabello-Gay MN, Pereira CA. 1996. Evaluation of the genotoxic potential of flumethrin in mouse bone marrow by chromosomal analysis and micronucleus test. Teratog Carcinog Mutagen 16:37–48.8792532
*Narahashi T. 1971. Mode of action of pyrethroids. Bull Organ Mond Sante 44:337–345.
*Narahashi T. 1976. Nerve membrane as a target of pyrethroids. Pestic Sci 7:267–272.
Narahashi T. 1982. Cellular and molecular mechanisms of action of insecticides: Neurophysiological approach. Neurobehav Toxicol Teratol 4:753–758.6302535
*Narahashi T. 1985. Nerve membrane ionic channels as the primary target of pyrethroids. Neurotoxicology 6(2):3–22.
*Narahashi T. 1986. Mechanisms of action of pyrethroids on sodium and calcium channel gating. In: Ford MG, Lunt GG, Reay RC, ., eds. Neuropharmacology and pesticide action. Deerfield Beach, FL: VCH, 267–285.
*Narahashi T. 1996. Neuronal ion channels as the target sites of insecticides. Pharmacol Toxicol 78:1–14.8821391
Narahashi T, Carter DB, Frey J, . 1995. Sodium channels and GABA_A_ receptor-channel complex as targets of environmental toxicants. Toxicol Lett 82/83:239–245.8597060
Narahashi T, Frey JM, Ginsburg KS, . 1992. Sodium and GABA-activated channels as the targets of pyrethroids and cyclodienes. Toxicol Lett 64/65:429–436.
Narahashi T, Ginsburg KS, Nagata K, . 1998. Ion channels as targets for insecticides. Neurotoxicology 19(4–5):581–590.9745915
Nassif M, Brooke JP, Hutchinson DBA, . 1980. Studies with permethrin against body lice in Egypt. Pestic Sci 11:679–684.
*NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press.
*Nehéz M, Lorencz R, Dési I. 2000. Simultaneous action of cypermethrin and two environmental pollutant metals, cadmium and lead, on bone marrow cell chromosomes of rats in subchronic administration. Ecotoxicol Environ Saf 45:55–60.10677268
Neidert E, Saschenbrecker PW. 1996. Occurrence of pesticide residues in selected agricultural food commodities available in Canada. J Assoc Off Anal Chem Int 79(2):549–566.
*NIOSH. 1987. Registry of toxic effects of chemical substances. Vol. 4. 1985-86 ed. Washington, DC U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, 3687.
*NIOSH. 1989. National occupational health survey of mining. Pyrites report. National Institute for Occupational Safety and Health. PB90-180787.
*NIOSH. 2001. Documentation for immediately dangerous to life or health concentrations (IDLHs). National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/idlh/8003347.html. April 13, 2001.
Nozaki S, Takahashi M, Hashimoto K. 1995. Effect of pyrethroid (allethrin and fenvalerate) on excitability changes following nerve impulse. J Occup Health 37:5–8.
*NRC. 1993. National Research Council. Pesticides in the diets of infants and children. Washington, DC: National Academy Press.
*Ohkawa H, Kaneko H, Tsuji H, . 1979. Metabolism of fenvalerate (Sumicidin) in rats. J Pestic Sci 4:143–155.
*Ohsawa K, Casida JE. 1980. Metabolism in rats of the potent knockdown pyrethroid kadethrin. J Agric Food Chem 28:250–255.7391361
Okumura D, Melnicoe R, Jackson T, . 1991. Pesticide residues in food crops analyzed by the California Department of Food and Agriculture in 1989. Rev Environ Contam Toxicol 118:87–151.1992493
*Okuno Y, Ito S, Seki T, . 1986a. Fenvalerate-induced granulomatous changes in rats and mice. J Toxicol Sci 11:53–66.3712506
Okuno Y, Seki T, Ito S, . 1986b. Differential metabolism of fenvalerate and granuloma formation. Toxicol Appl Pharmacol 83:157–169.3952745
*Oraby HA. 1997. Micronuclei formation in bone marrow cells of rats treated with meothrin (synthetic pyrethroid). J Appl Toxicol 17(6):353–356.9418941
Ortiz D, Yáñez L, Gómez H, . 1995. Acute toxicological effects in rats treated with a mixture of commercially formulated products containing methyl parathion and permethrin. Ecotoxicol Environ Saf 32:154–158.8575360
*OSHA. 2001a. Limits for air contaminants. U.S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000, Table Z-1. http://www.osha-slc.gov/OshStddata/19101000TABLEZ-1.html. March 26, 2001.
*OSHA. 2001b. OSHA regulations: Air contaminants. U.S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. http://www.osha-slc.gov/OshStddata/19151000.html. March 26, 2001.
*OSHA. 2001c. OSHA Regulations: Gases, vapors, fumes, dusts, and mists. U.S. Department of Labor.
Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. http://www.osha-slc.gov/OshStddata/19260055.html. March 26, 2001.
*Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Pall HS, Williams AC, Waring R, . 1987. Motorneuron disease as manifestation of pesticide toxicity. [Abstract]. Lancet II(8560):685.
Pang G-F, Fan C-L, Chao Y-Z, . 1994. Packed-column gas chromatographic method for the simultaneous determination of 10 pyrethroid insecticide residues in fruits, vegetables, and grains. J Assoc Off Anal Chem 77(3):738–747.
*Pang G-F, Cao Y-Z, Fan C-L, . 1997. Modification of AOAC multiresidue method for determining synthetic pyrethroid residues in fruits, vegetables, and grains. Part III: Studies of analyte stability and method ruggedness. J Assoc Off Anal Chem Int 80(1):63–73.
*Parihar NS, Gupta A. 1998. Fenvalerate residues in green pods, pod cover, and grain of pigeonpea (Cajanus cajan L.). Bull Environ Contam Toxicol 60:159–163.9484570
*Parker CM, Albert JR, Van Gelder GA, . 1985. Neuropharmacologic and neuropathologic effect of fenvalerate in mice and rats. Fundam Appl Toxicol 5:278–286.2985461
*Parker CM, McCullough CB, Gellatly JBM, . 1983. Toxicologic and carcinogenic evaluation of fenvalerate in the B6C3F1 mouse. Fundam Appl Toxicol 3:114–120.6873529
*Parker CM, Patterson DR, Van Gelder GA, . 1984a. Chronic toxicity and carcinogenicity evaluation of fenvalerate in rats. J Toxicol Environ Health 13:83–97.6716513
*Parker CM, Piccirillo VJ, Kurtz SL, . 1984b. Six-month feeding study of fenvalerate in dogs. Fundam Appl Toxicol 4:577–586.6479503
Parker CM, Wimberly HC, Lam AS, . 1986. Subchronic feeding study of decarboxyfenvalerate in rats. J Toxicol Environ Health 18:77–90.3701883
*Paterson S, Mackay D, Tam D, . 1990. Uptake of organic chemicals by plants: A review of processes, correlations and models. Chemosphere 21(3):297–331.
*Pati PC, Bhunya SP. 1989. Cytogenetic effects of fenvalerate in mammalian in vivo test system. Mutat Res 222:149–154.2922004
Patro N, Mishra SK, Chattopadhyay M, . 1997. Neurotoxicological effects of deltamethrin on the postnatal development of cerebellum of rat. J Biosci 22(2):117–130.
Pauluhn J. 1996. Risk assessment of pyrethroids following indoor use. Toxicol Lett 88:339–348.8920758
Pauluhn J, Machemer LH. 1998. Assessment of pyrethroid-induced paraesthesias: Comparison of animal model and human data. Toxicol Lett 96/97:361–368.9820689
*Pauluhn J, Thyssen J. 1982. Study for acute inhalation toxicology (effect of formulating agent on inhalation). Miles Inc. OTS0543768.
Peele DB, Crofton KM. 1987. Pyrethroid effects on schedule-controlled behavior: Time and dosage relationships. Neurotoxicol Teratol 9:387–394.3696110
*Peter JV, John G, Cherian AM. 1996. Pyrethroid poisoning. J Assoc Physicians India 44(5):343–344.9282587
*Pluijmen M, Drevon C, Montesano R, . 1984. Lack of mutagenicity of synthetic pyrethroids in Salmonella typhimurium strains and in V79 Chinese hamster cells. Mutat Res 137:7–15.6379439
*Poláková H, Vargová M. 1983. Evaluation of the mutagenic effects of decamethrin: Cytogenetic analysis of bone marrow. Mutat Res 120:167–171.6843579
*Pomorska K. 1999. Determination of alphacypermethrin in the air by capillary gas chromatography. Int J Occup Saf Ergon 5(4):529–536.10657925
Popovic J, Mikov M, Stanulovic M, . 2001. Clinical study of permethrin efficacy and toxicity. Toxicol Lett 123:89.11641038
*Poulos L, Athanaselis S, Coutselinis A. 1982. Acute intoxication with cypermethrin (NRDC 149). J Toxicol Clin Toxicol 19(5):519–520.7175998
Pozzi C, Marai P, Ponti R, . 1985. Toxicity in man due to stain removers containing 1,2-dichloropropane. Br J Ind Med 42:770–772.4063220
Prinsen GH, Van Sittert NJ. 1980. Exposure and medical monitoring study of a new synthetic pyrethroid after one season of spraying on cotton in Ivory Coast. In: Tordoir WF, Van Heemstra-Lequin EAH, eds. Field worker exposure during pesticide application. New York, NY: Elsevier Scientific Publishing Co., 105–120.
*Puig M, Carbonell E, Xamena N, . 1989. Analysis of cytogenetic damage induced in cultured human lymphocytes by the pyrethroid insecticides cypermethrin and fenvalerate. Mutagenesis 4(1):72–74.2654555
Punareewattana K, Smith BJ, Blaylock BL, . 2001. Topical permethrin exposure inhibits antibody production and macrophage function in C57Bl/6N mice. Food Chem Toxicol 39:133–139.11267706
Queiroz MLS. 1993a. Effects of deltamethrin on the growth and differentiation of bone marrow hematopoietic stem cells. Braz J Med Biol Res 26:525–535.8257942
Queiroz MLS. 1993b. Hematopoietic effects in mice exposed to deltamethrin and hydrocortisone. Int J Immunopharmacol 15(3):301–307.8505142
*Quistad GB, Selim S. 1983. Fluvalinate metabolism by Rhesus monkeys. J Agric Food Chem 31:596–599.6886216
*Quistad GB, Staiger LE, Jamieson GC, . 1982. Metabolism of fluvalinate by a lactating dairy cow. J Agric Food Chem 30:895–901.7142592
*Quistad GB, Staiger LE, Jamieson GC, . 1983. Fluvalinate metabolism by rats. J Agric Food Chem 31:589–596.6886215
Ramon MF, Ballesteros S, Martinez-Arrieta R, . 1999. A prospective study of pyrethroids exposures. J Toxicol Clin Toxicol 37:664.
Rangaswamy V, Venkateswarlu K. 1992. Degradation of selected insecticides by bacteria isolated from soil. Bull Environ Contam Toxicol 49:797–804.1450557
Rangoonwala S, Suryawanshi SA, Pandey AK. 1996. Effects of fenvalerate on serum calcium and inorganic phosphate levels, and tissue phophatases of Rattus norvegicus. J Adv Zool 17(1):15–19.
Rani S, Dua KK. 1999. Cypermethrin toxicity induced histological and biochemical changes in the liver of albino rats (Rattus norvegicus). J Ecotoxicol Environ Monit 9(1):41–46.
Rao KSP, Chetty CS, Desaiah D. 1984. In vitro effects of pyrethroids on rat brain and liver ATPase activities. J Toxicol Environ Health 14:257–265.6239040
*Rawn GP, Webster GRB, Muir DCG. 1982. Fate of permethrin in model outdoor ponds. J Environ Sci Health B17(5):463–486.
Ray DE. 1980. An EEG investigation of decamethrin-induced choreoathetosis in the rat. Exp Brain Res 38:221–227.7358105
Ray DE. 1982a. Changes in brain blood flow associated with deltamethrin-induced choreoathetosis in the rat. Exp Brain Res 45:269–276.6799314
Ray DE. 1982b. The contrasting actions of two pyrethroids (deltamethrin and cismethrin) in the rat. Neurobehav Toxicol Teratol 4:801–804.7170043
*Ray DE. 1991. Pesticides derived from plants and other organisms. In: Handbook of Pesticide Toxicology. Vol. 2. Hayes WJ, Laws ER, eds. Academic Press, Inc., 585–636.
*Ray DE, Cremer JE. 1979. The action of decamethrin (a synthetic pyrethroid) on the rat. Pestic Biochem Physiol 10:333–340.
Ray DE, Sutharsan S, Forshaw PJ. 1997. Actions of pyrethroid insecticides on voltage-gated chloride channels in neuroblastoma cells. Neurotoxicology 18(3):755–760.9339822
*Ray DE, Verschoyle, Muhammad BY. 2002. Reproducibility of developmental neurotoxicity produced by pyrethroids and DDT in neonatal mice. Toxicologist 66(1-S):131.
Reddy BN, Reddy KS, Janardhan A. 1991. Effect of dimethoate and fenvalerate on conditioned avoidance and passive avoidance responses. Indian J Exp Biol 29:176–177.1869302
Rekling JC, Theophilidis G. 1995. Effects of the pyrethroid insecticide, deltamethrin, on respiratory modulated hypoglossal motoneurons in a brain stem slice from newborn mice. Neurosci Lett 198:189–192.8552318
Rhodes C, Jones BK, Croucher A, . 1984. The bioaccumulation and biotransformation of cis, trans-cypermethrin in the rat. Pestic Sci 25:471–480.
Rickard J, Brodie ME. 1985. Correlation of blood and brain levels of the neurotoxic pyrethroid deltamethrin with the onset of symptoms in rats. Pestic Biochem Physiol 23:143–156.
Rickett FE, Tyszkiewicz K. 1973. Pyrethrum dermatitis II. The allergenicity of pyrethrum cleoresin and its cross-reactions with the saline extract of pyrethrum flowers. Pestic Sci 4:801–810.
*Ridlen RL, Christopher RJ, Ivie GW, . 1984. Distribution and metabolism of cis- and trans-resmethrin in lactating Jersey cows. J Agric Food Chem 32:1211–1217.
*Rigakis KB, Martin-Scott S, Crown EM, . 1987. Limiting pesticide exposure through textile cleaning procedures and selection of clothing. Agric Forestry Bull 10(2):24–27.
*Rivera J, Caixach J, Ventura F, . 1985. Herbicide and surfactant spill analysis of an industrial waste dumping at Llobregat River (Spain). Chemosphere 14(5):395–402.
Riviere JE, Baynes RE, Brooks JD, . 2003. Percutaneous absorption of topical N,N-diethyl-m-toluamide (DEET): Effects of exposure variables and coadministered toxicants. J Environ Toxicol Environ Health A 66:133–151.
Robertson KE. 1997. Potentially toxic self-treatment of uremic pruritus with topical pyrethroid insecticides. Ann Pharmacother 31:120–121.
*Roinestad KS, Louis JB, Rosen JD. 1993. Determination of pesticides in indoor air and dust. J Assoc Off Anal Chem Int 76(5):1121–1126.
Ronis MJJ, Barger TM, Gandy J, . 1995. Anti-androgenic effects of perinatal cypermethrin exposure in the developing rat. Neurotoxicology 16(4):763.
*Rose GP, Dewar AJ. 1983. Intoxication with four synthetic pyrethroids fails to show any correlation between neuromuscular dysfunction and neurobiochemical abnormalities in rats. Arch Toxicol 53:297–316.6314930
Rosenberg AM, Semchuk KM, McDuffie HH, . 1999. Prevalence of antinuclear antibodies in a rural population. J Toxicol Environ Health 56:225–236.
Ross J, Fong HR, Thonsinthusak T, . 1991. Measuring potential dermal transfer of surface pesticide residue generated from indoor fogger use: Using the CDFA roller method interim report II. Chemosphere 22(9–10):975–984.
*Ross J, Thongsinthusak T, Fong HR, . 1990. Measuring potential dermal transfer of surface pesticide residue generated from indoor fogger use: An interim report. Chemosphere 20(3/4):349–360.
Roy RR, Albert RH, Wilson P, . 1995. U.S. Food and Drug Administration pesticide program: Incidence/level monitoring of domestic and imported pears and tomatoes. J Assoc Off Anal Chem Int 78(4):930–940.
Ruzo LO, Casida JE. 1977. Metabolism and toxicology of pyrethroids with dihalovinyl substituents. Environ Health Perspect 21:285–292.612453
Ruzo LO, Casida JE, Holden I. 1985. Pyrethroid chemistry: Reactive α,β-unsaturated keto aldehydes from peracid oxidation, oxidative photodecomposition, and metabolism of 5-benzyl-3-furylmethyl derivatives. J Agric Food Chem 33:622–625.
*Ruzo LO, Unai T, Casida JE. 1978. Decamethrin metabolism in rats. J Agric Food Chem 26(4):918–925.670573
*Ryu J-C, Kim K-R, Kim H-J, . 1996. Evaluation of the genetic toxicity of synthetic chemicals (II), a pyrethroid insecticide, fenpropathrin. Arch Pharmacal Res 19(4):251–257.
Salawu OA, Iyaniwura TT. 2000. Effects of anticonvulsants on acute cypermethrin poisoning in mice and rats. Vet Hum Toxicol 42(5):303–305.11003126
Saleh MAA, Mohamed ZA, Ahmed FA, . 1986. Comparative toxicity of flucythrinate and fenvalerate to albino rats. Egypt J Food Sci 14(1):31–37.
Salem HAH, Al-Busadah KA, Hussein YA, . 1999. Effect of supracide and sharkesuper administrations on thyroid, gonadotrophic and female sex hormones in rabbits. Pak Vet J 19(4):188–191.
Salem MH, Abo-Elezz Z, Abd-Allah GA, . 1988. Effect of organophosphorous (dimethoate) and pyrethroid (deltamethrin) pesticides on semen characteristics in rabbits. J Environ Sci Health B 23(3):279–290.3403918
*Samsonov YN, Makarov VI. 1996. Kinetics and photophysical mechanism of sunlight photolysis of unstable resmethrin and phenothrin in aerosols and thin films. Bull Environ Contam Toxicol 56:903–910.8661879
*Santoni G, Cantalamessa F, Cavagna R, . 1998. Cypermethrin-induced alteration of thymocyte distribution and functions in prenatally-exposed rats. Toxicology 125:67–78.9585102
*Santoni G, Cantalamessa F, Mazzucca L, . 1997. Prenatal exposure to cypermethrin modulates rat NK cell cytotoxic functions. Toxicology 120:231–242.9217310
*Santoni G, Cantalamessa F, Spreghini E, . 1999. Alterations of T cell distribution and functions in prenatally cypermethrin-exposed rats: Possible involvement of catecholamines. Toxicology 138:175–187.10593508
Satpathy SK, Tyagi PK, Das BS, . 1997. Evaluation of possible toxic effects of cyfluthrin during short-term, relevant community exposure. Bull Environ Contam Toxicol 59:681–687.9323214
*Sattelle DB, Yamamoto D. 1988. Molecular targets of pyrethroid insecticides. Adv Insect Physiol 20:147–213.
Schattenberg HF, Hsu JP. 1992. Pesticide residue survey of produce from 1989 to 1991. J Assoc Off Anal Chem Int 75(5):925–933.
*Schimmel SC, Garnas RL, Patrick JM, . 1983. Acute toxicity, bioconcentration, and persistence of AC 222,705, benthiocarb, chlorpyrifos, fenvalerate, methyl parathion, and permethrin in the estuarine environment. J Agric Food Chem 31:104–114.6681821
Schmidt S. 1998. Biodegradation of diaryl ether pesticides. In: Wittich RM, ed. Biodegradation of dioxins and furans. R.G. Landes Company, 229–281.
*Schoenig GP. 1995. Mammalian toxicology of pyrethrum extract. In: Casida JE, Quistad GB, eds. Pyrethrum flowers: Production, chemistry, toxicology, and uses. New York: Oxford University Press, 249–257.
Schulz R, Dabrowski JM. 2001. Combined effects of predatory fish and sublethal pesticide contamination on the behavior and mortality of mayfly nymphs. Environ Toxicol Chem 20(11):2537–2543.11699780
Scott RC, Ramsey JD. 1987. Comparison of the in vivo and in vitro percutaneous absorption of a lipophilic molecule (cypermethrin), a pyrethroid insecticide. J Invest Dermatol 89:142–146.3598206
Sędrowicz L, Wikowska D, Olędzka R. 1996. Effect of chlorfenvinphos, cypermethrin and their mixture on the intestinal transport of leucine and methionine. J Appl Toxicol 16(6):483–489.8956093
*Setchell BP, Waites GMH. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society.
*Shah PV, Fisher HL, Sumler MR, . 1987. Percutaneous absorption and pharmacokinetics of permethrin in young and adult rats. Toxicology 47:230–231.
Shaker N, Hassan GA, El-Nouty FD, . 1988. In vivo chronic effect of dimethoate and deltamethrin on rabbits. J Environ Sci Health B23(4):387–399.
Shakoori A, Ali SS, Saleem MA. 1988. Effects of cypermethrin on the blood and liver of albino rats. J Biochem Toxicol 3:59–71.2466999
*Shakoori AR, Aslam F, Sabir M, . 1992a. Effect of prolonged administration of insecticide (cyhalothrin/karate) on the blood and liver of rabbits. Folia Biol 40:91–99.
Shakoori AR, Butt U, Riffat R, . 1992b. Toxic effects of short-term oral administration of danitol on the blood and liver of rabbits. Punjab Univ J Zool 7:13–26.
Shan G, Stoutamire DW, Wengatz I, . 1999a. Development of an immunoassay for the pyrethroid insecticide esfenvalerate. J Agric Food Chem 47:2145–2155.10552511
Shan G, Wengatz I, Stoutamire DW, . 1999b. An enzyme-linked immunosorbent assay for the detection of esfenvalerate metabolites in human urine. Chem Res Toxicol 12(11):1033–1041.10563828
*Sharom MS, Solomon KR. 1981. Adsorption-desorption, degradation, and distribution of permethrin in aqueous systems. J Agric Food Chem 29:1122–1125.
Shawky AS, Gomaa EA, Bakry H, . 1984. Mutagenicity and teratogenicity of the synthetic pyrethroid insecticide cypermethrin in albino rats. Genetics 107(3):S98.
Sheets LP. 2000. A consideration of age-dependent differences in susceptibility to organophosphorus and pyrethroid insecticides. Neurotoxicology 2(1–2):57–64.
*Sheets LP, Doherty JD, Law MW, . 1994. Age-dependent differences in the susceptibility of rats to deltamethrin. Toxicol Appl Pharmacol 126:186–190.8184428
*Shiba K, Kaneko H, Kakuta N, . 1990. Placental transfer of esfenvalerate in pregnant rats. J Pestic Sci 15:169–174.
*Shono T, Ohsawa K, Casida JE. 1979. Metabolism of trans- and cis-permethrin, trans- and cis-cypermethrin and decamethrin by microsomal enzymes. J Agric Food Chem 27(2):316–325.429687
*Shujie W, Qinglang Z, Lan Y, . 1988. Health survey among farmers exposed to deltamethrin in the cotton fields. Ecotoxicol Environ Saf 15:1–6.3359951
*Shukla Y, Taneja P. 2000. Mutagenic evaluation of deltamethrin using rodent dominant lethal assay. Mutat Res 467:119–127.10838199
Shukla Y, Arora A, Singh A. 2001. Tumourigenic studies on deltamethrin in Swiss albino mice. Toxicology 163(1):1–9.11376860
Shukla Y, Yadav A, Arora A. 2002. Carcinogenic and cocarcinogenic potential of cypermethrin on mouse skin. Cancer Lett 182:33–41.12175521
Sidon EW, Moody RP, Franklin CA. 1988. Percutaneous absorption of cis- and trans-permethrin in Rhesus monkeys and rats: Anatomic site and interspecies variation. J Toxicol Environ Health 23:207–216.3343697
*Siebers J, Mattusch P. 1996. Determination of airborne residues in greenhouses after application of pesticides. Chemosphere 33(8):1597–1607.
*Silver IS, Dauterman WC. 1989a. The pharmacokinetics and metabolism of (1R, cis)- and (1R, trans)-tetramethrin in rats. Xenobiotica 19(3):301–314.2665326
*Silver IS, Dauterman WC. 1989b. The toxicokinetics of (1R, cis)- and (1R, trans)-tetramethrin in the isolated perfused rat liver. Xenobiotica 19(5):509–519.2750207
*Simonaitis RA, Cail RS. 1975. Gas-liquid chromatographic determination of resmethrin in corn, cornmeal, flour, and wheat. J Assoc Off Anal Chem Int 58(5):1032–1036.
Singh G, Sharma LD, Ahmad AH, . 1999. Fenvalerate induced dermal toxicity in buffalo calves. J Appl Anim Res 16:205–210.
Siroki O, Institóris L, Tatar E, . 1994. Immunotoxicological investigation of SCMF, a new pyrethroid pesticide in mice. Hum Exp Toxicol 13:337–343.8043315
*Slameňová D, Dušinská M, Gábelová A, . 1992. An evaluation of three pesticides: Piritione, supercypermethrin and metachlor in transformation bioassays of BHK21 and hamster embryo cells. Cell Biol Toxicol 8(4):217–231.1493583
Smith PA, Thompson MJ, Edwards JW. 2002. Estimating occupational exposure to the pyrethroid termiticide bifenthrin by measuring metabolites in urine. J Chromatogr B Analyt Technol Biomed Life Sci 778:113–120.
Smith S, Willis GH. 1987. Interaction of methyl parathion with permethrin and flucythrinate as related to their mutual persistence in soil. Soil Sci 144(1):67–71.
*Smith S, Willis GH, Cooper CM. 1995. Cyfluthrin persistence in soil as affected by moisture, organic matter, and redox potential. Bull Environ Contam Toxicol 55:142–148.7663084
Smith TJ, Soderlund DM. 1998. Action of pyrethroid insecticide cypermethrin on rat brain IIa sodium channels expressed in Xenopus oocytes. Neurotoxicology 19(6):823–832.9863771
Smith TJ, Soderlund DM. 2001. Potent actions of the pyrethroid insecticides cismethrin and cypermthrin on rat tetrodotoxin-resistant peripheral nerve (SNS/PN3) sodium channels expressed in Xenopus oocytes. Pestic Biochem Physiol 70(1):52–61.
*Soderlund DM. 1995. Mode of action of pyrethrins and pyrethroids. In: Casida JE, Quistad GB, eds. Pyrethrum flowers: Production, chemistry, toxicology, and uses. New York, NY: Oxford University Press, 217–233.
Soderlund DM, Bloomquist JR. 1989. Neurotoxic actions of pyrethroid insecticides. Annu Rev Entomol 34:77–96.2539040
*Soderlund DM, Clark JM, Sheets LP, . 2002. Mechanisms of pyrethroid neurotoxicity: implications for cumulative risk assessment. Toxicology 171:3–59.11812616
Soderlund DM, Ghiasuddin SM, Helmuth DW. 1983. Receptor-like stereospecific binding of a pyrethroid insecticide to mouse brain membranes. Life Sci 33:261–267.6865660
Sogorb MA, Vilanova E. 2002. Enzymes involved in the detoxification of organophosphorus, carbamate and pyrethroid insecticides through hydrolysis. Toxicol Lett 128:215–228.11869832
*Song JH, Narahashi T. 1996. Modulation of sodium channels of rat cerebellar purkinje neurons by the pyrethroid tetramethrin. J Pharmacol Exp Ther 277(1):445–453.8613953
*Southwood J. 1984. Acute oral toxicity to the mouse. Imperial Chemical Industries PLC. OTS0545463.
Spencer F, Berhane Z. 1982. Uterine and fetal characteristics in rats following a post-implantational exposure to permethrin. Bull Environ Contam Toxicol 29:84–88.7115999
*Spinosa HDS, Silva YMA, Nicolau AA, . 1999. Possible anxiogenic effects of fenvalerate, a Type II pyrethroid pesticide, in rats. Physiol Behav 67(4):611–615.10549901
Spittler TD, Argauer RJ, Lisk DJ, . 1984. Gas chromatographic determination of fenvalerate insecticide residues in processed tomato products and by-products. J Assoc Off Anal Chem 67(4):824–826.6469916
Springfield AC, Carlson GP, DeFeo JJ. 1973. Liver enlargement and modification of hepatic microsomal drug metabolism in rats by pyrethrum. Toxicol Appl Pharmacol 24:298–308.4144493
*SRI. 2000. Directory of chemical producers. SRI International.
Staatz CG, Bloom AS, Lech JJ. 1980. A pharmacological analysis of mechanisms of permethrin neurotoxicity in mice. Fed Proc Fed Am Soc Exp Biol 39(3):624.
Staatz CG, Bloom AS, Lech JJ. 1982. A pharmacological study of pyrethroid neurotoxicity in mice. Pestic Biochem Physiol 17:287–292.
*Staiger LE, Quistad GB. 1984. Metabolism of [benzyl-U-ring-^14^C] fluvalinate by rats. J Agric Food Chem 32:1130–1133.
Stein EA, Washburn M, Walczak C, . 1987. Effects of pyrethroid insecticides on operant responding maintained by food. Neurotoxicol Teratol 9:27–31.3627076
Stelzer KJ, Gordon MA. 1984. Effects of pyrethroids on lymphocyte mitogenic responsiveness. Res Commun Chem Pathol Pharmacol 46:137–150.6505384
*Stockis A, Bitar N, Rougeron C, . 1985. Fate of ^14^C-deltamethrin given orally in healthy volunteers. Naunyn-Schmiedebergs Arch Pharmacol 330:R13.
Sukul P. 1995. Dissipation of deltamethrin and fenvalerate residues in green gram (Vigna radiata (L.) Wilczek) under Indian climatic condition. Bull Environ Contam Toxicol 55:562–567.8555681
*Sundaram KMS. 1991. Fate and short-term persistence of permethrin insecticide injected in a Northern Ontario (Canada) headwater stream. Pestic Sci 31:281–294.
*Surrallés J, Cartbonell E, Puig M, . 1990. Induction of mitotic micronuclei by the pyrethroid insecticide fenvalerate in cultured human lymphocytes. Toxicol Lett 54:151–155.2124379
*Surrallés J, Xamena N, Creus A, . 1995. Induction of micronuclei by five pyrethroid insecticides in whole-blood and isolated human lymphocyte cultures. Mutat Res 341:169–184.7529358
Suzuki T, Miyamoto J. 1974. Metabolism of tetramethrin in houseflies and rats in vitro. Pestic Biochem Physiol 4:86–97.
Sylianco-Wu L, Kallman M, Wilson M, . 1990. Behavioral and neurochemical consequences of perinatal exposure to Type I and Type II pyrethroid formulations. Neurotoxicol Teratol 12(1):565–566.
Szépvölgyi J, Nagy K, Bedó M, . 1988. Examination of the interaction of decis and dithane in rats. Toxicology 53:107–111.2904711
Tabarean IV, Narahashi T. 2001. Kintetics of modulation of tetrodotoxin-sensitive and tetrodotoxin-resistant sodium channels by tetramethrin and deltamethrin. J Pharmacol Exp Ther 299(3):988–97.11714887
Takahashi M, Le Quesne PM. 1982. The effects of the pyrethroids deltamethrin and cismethrin on nerve excitability in rats. J Neurol Neurosurg Psychiatry 45:1005–1011.6294250
*Takahashi N, Mikami N, Matsuda T, . 1985a. Hydrolysis of the pyrethroid insecticide cypermethrin in aqueous media. J Pestic Sci 10:643–648.
*Takahashi N, Mikami N, Yamad H, . 1985b. Hydrolysis of the pyrethroid insecticide fenpropathrin in aqueous media. Pestic Sci 16:113–118.
*Takahashi N, Mikami N, Yamada H, . 1985c. Photodegradation of the pyrethroid insecticide fenpropathrin in water, on soil and on plant foliage. Pestic Sci 16:119–131.
*Talts U, Fredriksson A, Eriksson P. 1998a. Changes in behavior and muscarinic receptor density after neonatal and adult exposure to bioallethrin. Neurobiol Aging 19(6):545–552.10192213
Talts U, Talts JF, Eriksson P. 1998b. Differential expression of muscarinic subtype mRNAs after exposure to neurotoxic pesticides. Neurobiol Aging 19(6):553–559.10192214
Tamang RK, Gupta G, Chauhan H, . 1988. In vivo immunosuppression by synthetic pyrethroid (cypermethrin) pesticide in mice and goats. Vet Immunol Immunopathol 19:299–305.3075379
Tanaka T, Moriwaki SI, Horio T. 1987. Occupational dermatitis with simultaneous immediate and delayed allergy to chrysanthemum. Contact Dermatitis 16:152–154.2953551
Tandon SK, Gupta PK. 1990. Pharmacological basis of cypermethrin neurotoxicity. Indian Vet J 67:21–24.
*Tang JX, Siegfried BD. 1996. Bioconcentration and uptake of a pyrethroid and organophosphate insecticide by selected aquatic insects. Bull Environ Contam Toxicol 57:993–998.8875850
Tapase JS, Sharma SN, Singh SP. 1995a. Hematological alterations during experimental oral toxicity of fenvalerate in buffalo calves. Indian Vet Med J 19:239–243.
Tapase JS, Sharma SN, Singh SP. 1995b. Pathology of fenvalerate toxicity in buffalo calves. Indian J Agric Sci 65(5):540–541.
Tateno C, Ito S, Tanaka M, . 1993. Effects of pyrethroid insecticides on gap junctional intercellular communications in Balb/c3T3 cells by dye-transfer assay. Cell Biol Toxicol 9(3):215–221.8299001
Taylor P. 1979. Scabies in Zimbabwe Rhodesia: Distribution on the human body and the efficacy of lindane and permethrin as scabicides. Cent Afr J Med 25(8):165–168.91446
Taylor WG, Vedres DD, Hall TW. 1997. Capillary gas chromatographic determination of permethrin insecticide by transesterification. J Chromatogr B Biomed Sci Appl 690:123–129.9106036
*Thapinta A, Hudak PF. 2000. Pesticide use and residual occurrence in Thailand. Environ Monit Assess 60:103–114.
*Thyssen J. 1980. FCR 1272 subacute inhalational toxicity study on rats. Miles Inc. OTS0543768.
*Tomigahara Y, Mori M, Shiba K, . 1994a. Metabolism of tetramethrin isomers in rat. I. Identification of a sulphonic acid type of conjugate and reduced metabolites. Xenobiotica 24(5):473–484.8079506
*Tomigahara Y, Mori M, Shiba K, . 1994b. Metabolism of tetramethrin isomers in rat: II. Identification and quantitation of metabolites. Xenobiotica 24(12):1205–1214.7771107
Tomigahara Y, Onogi M, Miki M, . 1996. Metabolism of tetramethrin isomers in rat. III. Stereochemistry of reduced metabolites. Xenobiotica 26(2):201–210.8868003
Tomigahara Y, Onogi M, Saito K, . 1997. Metabolism of tetramethrin isomers in rat: IV. Tissues responsible for formation of reduced and hydrated metabolites. Xenobiotica 27(9):961–971.9381736
*Tomlin CDS. 1997. The pesticide manual - world compendium. 11^th^ ed. Surrey, England: British Crop Protection Council.
Trainer VL, McPhee JC, Boutelet-Bochan H, . 1997. High affinity binding of pyrethroids to the α subunit of brain subunit channels. Mol Pharmacol 51:651–657.9106631
Trainer VL, Moreau E, Guedin D, . 1993. Neurotoxin binding and allosteric modulation at receptor sites 2 and 5 on purified and reconstituted rat brain sodium channels. J Biol Chem 268(23):17114–17119.8394327
*TRI99. 2001. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Offices of Environmental Information. U.S. Environmental Protection Agency. Toxic Release Inventory. http://www.epa.gov/triexplorer/. April 26, 2001.
*Tsuji R, Kobayashi K, Ikeda M, . 2002. Lack of changes in brain muscarinic receptor and motor activity of mice after neonatal inhalation exposure to d-allethrin. J Appl Toxicol 22:423–429.12424746
Tsuji R, Isobe N, Kawasaki H. 1996. Effect of pyrethroids on pentobarbital-induced sleeping time in relation to the chemical structure. Toxicology 106:131–137.8571384
*Tucker SB, Flannigan SA. 1983. Cutaneous effects from occupational exposure to fenvalerate. Arch Toxicol 54:195–202.6661029
*Tucker SB, Flannigan SA, Ross CE. 1984. Inhibition of cutaneous paresthesia resulting from synthetic pyrethroid exposure. Int J Dermatol 23(10):686–689.6526564
Tulinská J, Kubová J, Janota S, . 1995. Investigation of immunotoxicity of supercypermethrin forte in the Wistar rat. Hum Exp Toxicol 14:399–403.7612300
Ueda A, Aoyama K, Manda F, . 1994. Delayed-type allergenicity of triforine (Saprol). Contact Dermatitis 31:140–145.7821004
*Ueda K, Gaughan C, Casida JE. 1974. Photodecomposition of resmethrin and related pyrethroids. J Agric Food Chem 22(2):212–220.4840567
*Ueda K, Gaughan C, Casida JE. 1975a. Metabolism of four resmethrin isomers by liver microsomes. Pestic Biochem Physiol 5:280–294.
*Ueda K, Gaughan LC, Casida JE. 1975b. Metabolism of (+)-trans- and (+)-cis-resmethrin in rats. J Agric Food Chem 23(1):106–115.1133269
*USDA. 2001a. ARS Pesticide properties database. U.S. Department of Agriculture. http://wizard.arsusda.gov/acsl/textfiles/PYRETHRINS. February 8, 2001.
*USDA. 2001b. Labeling treated seed. U.S. Department of Agriculture. Code of Federal Regulations. 7 CFR 201.31a. http://www4.law.cornell.edu/cfr/7p201.htm. April 19, 2001.
*USGS. 2001. USGS pesticide national synthesis project. U.S. Geological Survey. http://ca.water.usgs.gov/pnsp/use/92/cyfluthrn.html. March 21, 2001.
Vaccari A, Ruiu S, Mocci I, . 1998. Selected pyrethroid insecticides stimulate glutamate uptake in brain synaptic vesicles. NeuroReport 9:3519–3523.9855310
Vais H, Atkinson S, Eldursi N, . 2000. A single amino acid change makes a rat neuronal sodium channel highly sensitive to pyrethroid insecticides. FEBS Lett 470:135–138.10734222
*Valentine WM. 1990. Pyrethrin and pyrethroid insecticides. Vet Clin North Am Small Anim Pract 20(2):375–382.2180183
*Vandenplas O, Delwiche JP, Auverdin J, . 2000. Asthma to tetramethrin. Allergy 55:418–419.10782542
*van der Rhee HJ, Farquhar JA, Vermeulen NPE. 1989. Efficacy and transdermal absorption of permethrin in scabies patients. Acta Derm Venereol (Stockh) 69:170–182.2564238
Van Haaren F, Cody B, Hoy JB, . 2000. The effects of pyridostigmine bromide and permethrin, alone or in combination, on response acquisition in male and female rats. Pharmacol Biochem Behav 66(4):739–746.10973511
*Varshneya C, Singh T, Sharma LD, . 1992. Immunotoxic responses of cypermethrin, a synthetic pyrethroid insecticide in rats. Indian J Physiol Pharmacol 36(2):123–126.1506076
Venant A, Belli P, Borrel S, . 1990. Excretion of deltamethrin in lactating dairy cows. Food Addit Contam 7(4):535–543.2394274
*Verschoyle RD, Aldridge WN. 1980. Structure-activity relationships of some pyrethroids in rats. Arch Toxicol 45:325–329.7447703
Verschoyle RD, Barnes JM. 1972. Toxicity of natural and synthetic pyrethrins to rats. Pestic Biochem Physiol 2:308–311.
*Viera I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
Vijverberg HPM, de Weille JR. 1985. The interaction of pyrethroids with voltage-dependent Na channels. Neurotoxicology 6(2):23–34.2410827
*Vijverberg HPM, van den Bercken J. 1982. Action of pyrethroid insecticides on the vertebrate nervous system. Neuropathol Appl Neurobiol 8:421–440.7162556
*Vijverberg HPM, van den Bercken J. 1990. Neurotoxicological effects and the mode of action of pyrethroid insecticides. Crit Rev Toxicol 21(2):105–126.1964560
*Vijverberg HPM, van der Zalm JM, van Kleef RGD, . 1983. Temperature- and structure-dependent interaction of pyrethroids with the sodium channels in frog node of Ranvier. Biochim Biophys Acta 728:73.6299340
*Vijverberg HPM, de Weille JR, Ruigt GSF, . 1986. The effect of pyrethroid structure on the interaction with the sodium channel in the nerve membrane. In: Ford MG, Lunt GG, Reay RC, ., eds. Neuropharmacology and pesticide action. Deerfield Beach, FL: VCH, 267–285.
*Villarini M, Moretti M, Pasquini R, . 1998. In vitro genotoxic effects of the insecticide deltamethrin in human peripheral blood leukocytes: DNA damage (‘comet’ assay) in relation to the induction of sister-chromatid exchanges and micronuclei. Toxicology 130:129–139.9865480
Villarini M, Moretti M, Scassellati-Sforzolini G, . 1995. Studies on hepatic xenobiotic-metabolizing enzymes in rats treated with insecticide deltamethrin. J Environ Pathol Toxicol Oncol 14(1):45–52.7473074
*Vlčková V. 1991. Mutagenic activity of supercypermethrin applied to yeast Saccharomyces cerevisiae D7. Acta Fac Rerum Nat Univ Comenianae, Genet Biol Mol 25:25–31.
Wagner SL. 1994. Allergy from pyrethrin of pyrethroid insecticides. J Agromed 1:39–45.
*Wagner SL. 2000. Fatal asthma in a child after use of an animal shampoo containing pyrethrin. West J Med 173:86–87.10924422
Waite DT, Grover R, Westcott ND, . 1995. Atmospheric deposition of pesticide in a small southern Saskatchewan watershed. Environ Toxicol Chem 14(7):1171–1175.
Wallace KB. 2002. Mechanisms of pyrethroid neurotoxicity: implications for cumulative risk assessment. Toxicology 171:1.11812615
*Wan H. 1990. Pesticide exposure of applicators working in tea plantations. Bull Environ Contam Toxicol 45:459–462.2257342
Wärngård L, Flodsröm S. 1989. Effects of tetradecanoyl phorbol acetate, pyrethroids and DDT in the V79. Cell Biol Toxicol 5(1):67–75.2920299
*Wax PM, Hoffman RS. 1994. Fatality associated with inhalation of a pyrethrin shampoo. Clin Toxicol 32(4):457–460.
Wax PM, Hoffman RS, Goldfrank LR. 1991. Fatality associated with inhalation of a pyrethrin insecticide [Abstract]. Vet Hum Toxicol 33(4):363.
Wenclawiak B, Otterbach A. 2000. Carbon-based quantitation of pyrethrins by supercritical-fluid chromatography. J Biochem Biophys Meth 43:197–207.10869676
*West JR, Smith HW, Chasi H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
Wester RC, Bucks DAW, Maibach HI. 1994. Human in vivo percutaneous absorption of pyrethrin and piperonyl butoxide. Food Chem Toxicol 32(1):51–53.8132164
*White INH, Verschoyle RD, Moradian MH, . 1976. The relationship between brain levels of cismethrin and bioresmethrin in female rats and neurotoxic effects. Pestic Biochem Physiol 6:491–500.
*Whittem T. 1995. Pyrethrin and pyrethroid insecticide intoxication in cats. Compend Contin Edu Pract Vet 17(4):489–492.
*WHO. 1990a. Cyhalothrin. Environmental Health Criteria 99. Geneva: World Health Organization.
*WHO. 1990b. Fenvalerate. Environmental Health Criteria 95. Geneva: World Health Organization.
*WHO. 1990c. Permethrin. Environmental Health Criteria 94. Geneva: World Health Organization.
*WHO. 2001. Guidelines for drinking water quality. World Health Organization. http://www.who.int/. April 19, 2001.
*Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York: Academic Press.
Wieseler B, Kühn K-H, Leng G, . 1998. Effects of pyrethroid insecticides on pest control operators. Bull Environ Contam Toxicol 60:837–844.9606258
*Wilkes MF. 2000. Pyrethroid-induced pareasthesia- a central or local toxic effect? Clin Toxicol 38(2):103–105.
Wilkes MF, Woollen BH, Marsh JR, . 1993. Biological monitoring for pesticide exposure- the role of human volunteer studies. Int Arch Occup Environ Health 65:S189–S192.8406924
Williams CH. 1973. Tests for possible teratogenic carcinogenic, mutagenic, and allergenic effects of pyrethrum. In: Casida JE, ed. Pyrethrum: The natural insecticide. London, England: Academic Press, 167–176.
Williamson EG, Long SF, Kallman MJ, . 1989. A comparative analysis of the acute toxicity of technical-grade pyrethroid insecticides and their commercial formulations. Ecotoxicol Environ Saf 18:27–34.2776687
*Wintersteiger R, Ofner B, Juan H, . 1994. Determination of traces of pyrethrins and piperonyl butoxide in biological material by high-performance liquid chromatography. J Chromatogr 660:205–210.
Woodrow JE, Seiber JN. 1997. Correlation techniques for estimating pesticide volatilization flux and downwind concentrations. Environ Sci Technol 31:523–529.
*Woollen BH. 1993. Biological monitoring for pesticide absorption. Ann Occup Hyg 37:525–540.8250473
*Woollen BH, Marsh JR, Laird WJD, . 1992. The metabolism of cypermethrin in man: Differences in urinary metabolite profiles following oral and dermal administration. Xenobiotica 22(8):983–991.1413886
*Wright CDP, Forshaw PJ, Ray DE. 1988. Classification of the actions of the ten pyrethroid insecticides in the rat, using the trigeminal reflex and skeletal muscle as test systems. Pestic Biochem Physiol 30:79–86.
*Wright CG, Leidy RB, Dupree HE. 1993. Cypermethrin in the ambient air and on surfaces of rooms treated for cockroaches. Bull Environ Contam Toxicol 51:356–360.8219589
*Wright CG, Leidy RB, Dupree HE. 1996. Insecticide residues in the ambient air of commercial pest control buildings, 1993. Bull Environ Contam Toxicol 56:21–28.9026153
*Wszolek PC, Hogue DE, Lisk DJ. 1981a. Accumulation of fenvalerate insecticide in lamb tissues. Bull Environ Contam Toxicol 27:869–871.7337860
*Wszolek PC, LaFaunce NA, Wachs T, . 1981b. Studies of possible bovine urinary excretion and rumen decomposition of fenvalerate insecticide and a metabolite. Bull Environ Contam Toxicol 26:262–266.7248551
*Wszolek PC, Lein DH, Lisk DJ. 1980. Excretion of fenvalerate insecticide in the milk of dairy cows. Bull Environ Contam Toxicol 24:296–298.7362910
Wu A, Liu Y. 2000. Apoptotic cell death in rat brain following deltamethrin treatment. Neurosci Lett 279:85–88.10674627
Wu A, Ren T, Hu Q, . 2000. Deltamethrin induces altered expression of P53, Bax and Bcl-2 in rat brain. Neurosci Lett 284:29–32.10771154
*Yamamoto D, Yeh JZ, Narahashi T. 1986. Ion permeation and selectivity of squid axon sodium channels modified by tetramethrin. Brain Res 372:193–197.2423191
Yamamoto I, Elliott M, Casida JE. 1971. The metabolic fate of pyrethrin I, pyrethrin II, and allethrin. Bull WHO 44:347–348.5315352
*Yao PP, Li YW, Ding YZ, . 1992. Biological monitoring of deltamethrin in sprayers by HPLC method. J Hyg Epidemiol Microbiol Immunol 36(1):31–36.
Yarsan E, Bilgili A, Kanbur M, . 2002. Effects of deltamthrin on lipid peroxidation in mice. Vet Hum Toxicol 44(2):73–5.11931506
*Yasin M, Baugh PJ, Bonwick GA, . 1996. Analytical method development for the determination of synthetic pyrethroid insecticides in soil by gas chromatography-mass spectrometry operated in negative-ion chemical-ionization mode. J Chromatogr 754:235–243.
Yess NJ. 1993. U.S. Food and Drug Administration survey of methyl mercury in canned tuna. J Assoc Off Anal Chem Int 76(1):36–38.
*Yi-Qun W, Xiao-Yen G, Chun-Ling L. 1994. Determination of pyrethroids in human urine by gas chromatography. Biomed Environ Sci 7:216–221.7848550
Yomamoto D, Quandt FN, Narahashi T. 1983. Modification of single sodium channels by the insecticide tetramethrin. Brain Res 274:344–349.6313121
*Yoshida K, Antal A, Fuzesi I, . 1990. Characteristics of applicator exposure to synthetic pyrethroid in ULV-handheld and ULV–ULA spray applications. J Environ Sci Health B25(2) 151–167.
Younis HM, Hamid NA, El-Saad MMA, . 2000. Alterations by the respiratory protein complexes of rat heart mitochondria induced by the insecticide fenvalerate. Biochem Soc Trans 28(5):A191.
*Zhang L, Khan S, Akhtar M, . 1984. Persistence, degradation, and distribution of deltamethrin in an organic soil under laboratory conditions. J Agric Food Chem 32(6):1207–1211.
*Zhang Z, Sun J, Chen S, . 1991. Levels of exposure and biological monitoring of pyrethroids in spraymen. Br J Ind Med 48:82–86.1998612
*Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
Zucker A. 1965. Investigation of purified pyrethrum extracts. Ann Allergy 23:335–339.14331967