# 7 ANALYTICAL METHODS

The purpose of this chapter is to describe the analytical methods that are available for detecting, measuring, and/or monitoring pyrethrins and pyrethroids, its metabolites, and other biomarkers of exposure and effect to pyrethrins and pyrethroids. The intent is not to provide an exhaustive list of analytical methods. Rather, the intention is to identify well-established methods that are used as the standard methods of analysis. Many of the analytical methods used for environmental samples are the methods approved by federal agencies and organizations such as EPA and the National Institute for Occupational Safety and Health (NIOSH). Other methods presented in this chapter are those that are approved by groups such as the Association of Official Analytical Chemists (AOAC) and the American Public Health Association (APHA). Additionally, analytical methods are included that modify previously used methods to obtain lower detection limits and/or to improve accuracy and precision.

## 7.1 BIOLOGICAL MATERIALS

Exposure to pyrethrins and pyrethroids is most commonly evaluated by the analysis of urine and blood using gas chromatography (GC) combined with electron capture detection (ECD), flame ionization detection (FID), or mass spectrometry (MS) and high performance liquid chromatography (HPLC) coupled with ultraviolet (UV) detector. Recovery is generally high, and sensitivity is in the parts per billion (ppb) range.

A simple and rapid method for the isolation of synthetic pyrethroids using a solid phase extraction method is described by Junting and Chichang (1991). A similar method that employs HPLC for analysis was used to quantify pyrethrins in plasma by Wintersteiger et al. (1994). This method eliminates time-consuming repeated extractions with organic solvents and centrifugations without losing the efficiency of recovery.

Pyrethrins and pyrethroids are extensively metabolized by the cleavage of the ester linkage, oxidation, and conjugation. Metabolites formed are less lipophilic, and are rapidly and easily excreted in the urine. Exposure to pyrethrins and pyrethroids can be monitored by the detection of these excreted metabolites. Pyrethroids such as cyfluthrin, cyhalothrin, cypermethrin, deltamethrin, fenvalerate, phenothrin, and permethrin can be metabolized resulting in the formation of halosubstituted chrysanthemic and 3-phenoxybenzoic acids (Angrer and Ritter 1997; Yao et al. 1992). The rapid metabolism of the pyrethroids makes it useful to monitor for pyrethroid metabolites in the urine of exposed individuals rather than monitoring the actual concentration of the pyrethroid itself in blood (Leng et al. 1999a). Also, it has been demonstrated that storing frozen urine samples for up to a year results in no further degradation of the metabolites (Leng et al. 1999a). In contrast, pyrethroids stored in plasma are susceptible to continued degradation (Leng et al. 1999a).

Methods for analyzing pyrethrins and pyrethroids as well as the metabolites in biological samples are shown in Table 7-1.

## 7.2 ENVIRONMENTAL SAMPLES

Concerns about contamination of environmental media, plants, and animals with pyrethrins have led to the need for more rapid, sensitive, and selective methods of analysis. As with biological samples, the most common methods of analysis are GC combined with ECD, FID, or flame photometric detection (FPD) and HPLC coupled with UV detector. Thermal conductivity detectors, thermionic detectors, and nitrogen phosphorus detectors have also been used in conjunction with GC.

Pyrethrins and pyrethroids are nonpolar compounds and nonsystemic in plants; thus, the extraction procedures in environmental samples are simpler than those used for organophosphate and carbamate insecticides. Generally, the samples are homogenized with a nonpolar solvent, such as hexane or benzene, or a binary solvent mixture, such as hexane-acetone, hexane-isopropanol, or light petroleum-diethyl ether. The pyrethrins and pyrethroids, along with a wide variety of other lipophilic substances are co-extracted during this procedure. The resulting solution is dried with anhydrous sodium sulfate. If there are too many co-extracted compounds, separation by liquid-liquid partition or column chromatography is performed. Samples with a low water content, such as tea, tobacco, and straw, are usually extracted with a binary solvent mixture, as are moist vegetables and fruits. Soil samples are first ground and filtered to remove large particles and stones, and then are extracted with acetone-hexane, methanol, acetone, or acetonitrile. Pyrethrins and pyrethroids are extracted from water samples with hexane, methylene chloride, or acetonitrile with subsequent drying with anhydrous sodium sulfate.

Table 7-1 Analytical Methods for Determining Pyrethrins and Pyrethroids in Biological Materials

Sample matrix | Analyte | Preparation method | Analytical method | Sample detection limit | Percent recovery | Reference
Blood, milk | Deltamethrin, cyhalothrin cypermethrin, flumethrin | Acidify with 1 N HCl; extract twice with CH_3_CN and filter; extract filtrate with hexane and discard the hexane phase; remove CH_3_CN under a stream of N_2_ and heat to dryness; cleanup on a silica gel column; dissolve in CH_3_CN and filter through a 0.45 µm pore cellulose filter | LC/UV | 1.0 µg/kg | 78–91 | Bissacot and Vassilieff 1997a, 1997b
Plasma | Pyrethrins | Dilute centrifuged plasma with water; cleanup on a solid phase extraction column; elute with methanol | RPHPLC/UV | 0.167 mg/L | 70–72 | Wintersteiger et al. 1994
Plasma | Cyfluthrin, cypermethrin, permethrin | Precipitation of proteins followed by liquid-liquid extraction | GC/ECD | 5 µg/L | No data | Leng et al. 1999a
Plasma, urine | Fenopropathrin, permethrin, cypermethrin, fenvalerate, deltamethrin | Mix samples with 70% methanol; pour on to Sep-Pak C_18_ columns pretreated with chloroform, methanol, methanol/water, and water; wash with water; elute with chloroform; evaporate to dryness under stream of N_2_; redissolve in ethanol | GC/FID | 2 mg/L | 81–93; 90–102 | Junting and Chuichang 1991
Urine | Cis- and trans-3-(2,2-dichlorovinyl)-2,2-dimethylcycloprane-1-carboxylic acid; 3-phenoxybenzoic acid; fluorophenoxybenzoic acid | Liquid-liquid extraction followed by methylation of the free acid metabolites | GC/MS | 0.5 µg/L | No data | Leng et al. 1999b
Urine | Cis- and trans-3-(2,2-dichlorovinyl)-2,2-dimethylcycloprane-1-carboxylic acid; cis-3-(2,2-dibromovinyl)-2,2-dimethylcycloprane-1-carboxylic acid; 3-phenoxybenzoic acid; 4-fluoro-3-phenoxy-benzoic acid | Acidify with AcOH; add concentrated H_2_SO_4_; heat at 90 °C for 1 hour; cleanup on C_18_ column; elute with methanol into a vial containing concentrated H_2_SO_4_; complete derivatization on water bath for 1 hour; extract with hexane | GC/MS | 0.3–0.5 µg/L | 90–98 | Angerer and Ritter 1997
Urine | Dibromovinyl-dimethylcyclopropane carboxylic acid, 3-phenoxybenzyl-hydroxyethyl acetate, 3-phenoxybenzoic acid | Adjust pH of sample to 6.5; extract with hexane; evaporate to dryness; redissolve in methanol | RPHPLC/UV | No data | 95 | Yao et al. 1992
Urine | Deltamethrin, fenvalerate | Extract with hexane; concentrate and cleanup on Florisil column; elute with benzene; dry on anhydrous Na_2_SO_4_ | GC/ECD | 0.2 µg/L | 92–95.3 | Yi-Qun et al. 1994

AcOH = acetic acid; CH_3_CN = acetonitrile; ECD = electron capture detector; FID = flame ionization detector; GC = gas chromatography; HCl = hydrochloric acid; H_2_SO_4_ = sulfuric acid; LC = liquid chromatography; MS = mass spectrometry; N_2_ = nitrogen; Na_2_SO_4_ = sodium sulfate; RPHPLC = reverse phase high performance liquid chromatography; UV = ultra-violet detection

In the analysis of pyrethrins, the total residues of the six active compounds are often analyzed for, but in the analysis of pyrethroids, the individual compounds are usually quantified (Chen and Wang 1996). An extensive review of the chromatographic methods employed for the determination of pyrethrins and pyrethroids in foods, crops, and environmental media has been published (Chen and Wang 1996). Many pyrethroids such as bifenthrin, cyfluthrin, cyhalothrin, cypermethrin, deltamethrin, fenvalerate, and permethrin possess one or more halogenated atoms which are sensitive to ECD. Often, derivitization is used to create a sensitive group for pyrethroids that do not possess halogenated atoms (allethrin, resmethrin, phenothrin, and tetramethrin, for example), or to improve the sensitivity and peak tailing situations in some halogenated pyrethroids (Chen and Wang 1996). Consequently, GC/ECD is the most popular analytical approach for analyzing pyrethroids in environmental samples.

A detection limit of 0.1 µg/m^3^ and a mean recovery of 100.15% has been reported for the analysis of cypermethrin in air using GC/ECD (Pomorska 1999), while permethrin and resmethrin had detection limits in the ng/m^3^ and very good recoveries with a GC/MS method (Roinestad et al. 1993). This is comparable to methods used for the determination of other pyrethroids in air using GC (EMMI 1997). The analysis of pyrethrins and pyrethroids in water is also accomplished through the use of GC and HPLC. Detection limits in the ppb (µg/L) range have been achieved (EMMI 1997). A method for the analysis of selected pyrethroids in soils has been described by Alawi et al. (1990) that utilizes GC equipped with a nitrogen phosphorus detector (NPD).

Methods for analyzing pyrethrins in environmental samples are shown in Table 7-2.

## 7.3 ADEQUACY OF THE DATABASE

Section 104(i)(5) of CERCLA, as amended, directs the Administrator of ATSDR (in consultation with the Administrator of EPA and agencies and programs of the Public Health Service) to assess whether adequate information on the health effects of pyrethrins and pyrethroids are available. Where adequate information is not available, ATSDR, in conjunction with the National Toxicology Program (NTP), is required to assure the initiation of a program of research designed to determine the health effects (and techniques for developing methods to determine such health effects) of pyrethrins.

The following categories of possible data needs have been identified by a joint team of scientists from ATSDR, NTP, and EPA. They are defined as substance-specific informational needs that if met would reduce the uncertainties of human health assessment. This definition should not be interpreted to mean that all data needs discussed in this section must be filled. In the future, the identified data needs will be evaluated and prioritized, and a substance-specific research agenda will be proposed.

Table 7-2 Analytical Methods for Determining Pyrethrins and Pyrethroids in Environmental Samples

Sample matrix | Analyte | Preparation method | Analytical method | Sample detection limit | Percent recovery | Reference
Air | Allethrin, fenvalerate, pyrethrin I, resmethrin | Air samples collected on a sorbent cartridge; extract with 5% diethyl ether in hexane | GC/ECD; GC/NPD; GC/FPD; HPLC/UV | 0.1–50 µg/m^3^ | No data | ASTM D4861 EMMI 1997
Air | Cypermethrin | Air samples collected on a sorbent cartridge; extract with acetone | GC/ECD | 0.1 µg/m^3^ | 100.15 (mean recovery) | Pomorska 1999
Air | Resmethrin, permethrin | Air samples collected on filter paper or Tenax tubes; extract with acetone | GC/MS | 1 ng/m^3^ (permethrin); 10 ng/m^3^ (resmethrin) | 109.5–110.9 (permethrin); 84.6 (resmethrin) | Roinestad et al. 1993
Air (dust) | Resmethrin, permethrin | Dust samples are homogenized in a blender or food processor; extract with acetone | GC/MS | 50 ng/g (permethrin); 100 ng/g (resmethrin) | 94.8–124.4 (permethrin); 82.6 (resmethrin) | Roinestad et al. 1993
Air | Pyrethrums | Air samples collected with sampling pump equipped with filter; extract with CH_3_CN | HPLC/UV | 0.020 mg/m^3^ | No data | NIOSH 5008 EMMI 1997
Fats, oils, milk, cheese, fish | Allethrin, bifenthrin, deltamethrin, esfenvalerate, fenvalerate, permethrin, tetramethrin, tralomethrin | Dissolve fat in petroleum ether; extract with CH_3_CN; dilute with water; clean up on Florisil column; extract with petroleum ether/ethyl ether | GC/ECD | No data | No data | FDA 211.1; FDA 231.1 EMMI 1997
Fatty and non fatty foods | Allethrin, bifenthrin, cyfluthrin, deltamethrin, esfenvalerate, fenpropathrin, fenvalerate, fluvalinate, permethrin, tetramethrin, tralomethrin | Dissolve fat in petroleum ether; extract with CH_3_CN; dilute with water; cleanup on Florisil column; elute with a series of eluants–methylene chloride, hexane, and CH_3_CN | GLC/ECD | No data | No data | FDA 252 EMMI 1997
Non-fatty food | Allethrin, bifenthrin, cyfluthrin, deltamethrin, esfenvalerate, fenpropathrin, fenvalerate, fluvalinate, permethrin, tetramethrin, tralomethrin | Extract with CH_3_CN or CH_3_CN/water mixture; dilute with water; extract with petroleum ether; cleanup on Florisil column; elute with petroleum ether/ethyl ether | GC/FPD | No data | No data | FDA 232.1 EMMI 1997
Non-fatty food | Bifenthrin, cyfluthrin, deltamethrin, esfenvalerate, fenvalerate, flucythrinate, fluvalinate, permethrin | Blend with acetone and filter; extract with petroleum ether and methylene chloride; concentrate to remove methylene chloride | GC/ECD; GC/FPD | No data | No data | FDA 232.4 EMMI 1997
Non-fatty foods | Deltamethrin, fenpropathrin, tralomethrin | Blend with acetone and filter; extract with methylene chloride; cleanup on a column containing charcoal, MgO, and Celite 545; elute with CH_3_CN-benzene | GC/FPD; GC/TSD | No data | No data | FDA 232.3 EMMI 1997
Fruits, vegetables, grains | Bifenthrin, cyhalothrin, cypermethrin, deltamethrin, fenpropathrin, fenvalerate, fluvalinate, permethrin | Homogenize in CH_3_CN and filter; extract with hexane; wash with 4% NaCl; dry over anhydrous Na_2_SO_4_; evaporate to dryness; redissolve in hexane; extract with CH_3_CN; evaporate to dryness; redissolve in hexane; cleanup on Florisil column; elute with a mixture of petroleum ether and ethyl ether. | GC/ECD | No data | >70 | Pang et al. 1997
Groundwater, drinking water | Permethrin | Extract with methylene chloride; dry over anhydrous Na_2_SO_4_; concentrate; add methyl tert-butyl ether | GC/ECD | 0.5 µg/L | No data | EMSLC 508 EMMI 1997
Waste water, municipal and industrial | Allethrin, cyfluthrin, fenvalerate, phenothrin, pyrethrins I, pyrethrins II, resmethrin, tetramethrin | Saturate sample with NaCl; extract with CH_3_CN; concentrate extract | HPLC/UV | 2 µg/L | No data | EAD 1660 EMMI 1997
Waste water, industrial | Resmethrin | Extract with methylene chloride; dry over anhydrous Na_2_SO_4_; concentrate | GC/FID | 36 µg/L | No data | EMSLC 616 EMMI 1997
Soil | Cypermethrin, permethrin, cyfluthrin, fluvalinate, deltamethrin | Extract with acetone saturated with sodium chloride; dry with Na_2_SO_4_ | GC/NPD | 0.004–0.012 mg/kg | 114 | Alawi et al. 1990
Pet shampoo | Pyrethrins I, pyrethrins II, tetramethrin | Dilute with water and add Celite 545; add to a Celite column; elute with petroleum ether; filter through 0.5 µm filter | HPLC/UV GC/FID | No data | No data | EPA-B EMMI 1997
Pesticide formulation | Pyrethrins I, pyrethrins II | Extract with petroleum ether; filter; evaporate the filtrate to <1 mL; add 0.5 N alcoholic NaOH and reflux gently; concentrate; add Filter-Cel and 10% BaCl_2_ filter; neutralize with H_2_SO_4_ using phenolphthalein; extract with petroleum ether; extract with 0.1 N NaOH; add Deniges reagent and let stand in darkness; add alcohol and precipitate HgCl with NaCl solution; filter; add dilute HCl; add chloroform and ICl solution | Titration | No data | No data | AOAC 936.05 EMMI 1997
Pesticide formulation | Permethrin | Dissolve in methyl isobutyl ketone | GC/FID | No data | No data | AOAC 986.03 EMMI 1997
Pesticide formulation | Deltamethrin | Dissolve (and sonicate) in isooctane-1,4-dioxane; filter | HPLC/UV | No data | No data | AOAC 991.03 EMMI 1997
Pesticide formulation | Allethrin | Add ethylenediamine; swirl; let stand; wash with pyridine; add thymophthalein indicator; titrate with 0.1 N NaOMe | Titration | No data | No data | AOAC 953.05 EMMI 1997
Pesticide formulation | Pyrethrums | Dilute with acetone; add dicyclohexyl phthalate (internal standard) | GC/FID | No data | No data | AOAC 982.02 EMMI 1997
Pesticide formulation | Pyrethrins I, pyrethrins II | Add sample to a column packed, bottom to top, with anhydrous Na_2_SO_4_, Florisil, and anhydrous Na_2_SO_4_; wash with hexane; elute with acetone; evaporate to dryness; dissolve residue in carbon disulfide; dry over anhydrous Na_2_SO_4_ | GC/FID | No data | No data | EPA-B EMMI 1997
Aerosol formulation | Resmethrin | Cool can in freezer overnight; punch holes in can to relieve pressure; open can and warm to room temperature; remove remaining volatiles by placing in a water bath; dissolve residue in benzene | GC/TCD | No data | No data | PMD-Res EMMI 1997
Aerosol formulation | Resmethrin | Cool can in freezer overnight; punch holes in can to relieve pressure; open can and warm to room temperature; remove remaining volatiles by placing in a water bath; dissolve residue in methanol | RPHPLC/UV | No data | No data | PMD-Res EPA-B EMMI 1997

BaCl = barium chloride; CH_3_CN = acetonitrile; ECD = electron capture detector; FID = flame ionization detector; FPD = flame photometric detector; GC = gas chromatography; HCl = hydrochloric acid; HgCl = mercuric chloride; HPLC = high performance liquid chromatography; H_2_SO_4_ = sulfuric acid; ICl =iodine monochloride; MgO = magnesium oxide; NaCl = sodium chloride; NaOH = sodium hydroxide; NaOMe = sodium methoxide; Na_2_SO_4_ = sodium sulfate; NPD = nitrogen phosphorus detector; RPHPLC = reverse phase high performance liquid chromatography; TCD = thermal conductivity detector; TSD = thermionic detector; UV = ultra-violet detection

### 7.3.1 Identification of Data Needs

Methods for Determining Biomarkers of Exposure and Effect.

Exposure. Methods for detecting and quantifying pyrethrins and pyrethroids in blood (Bissacot and Vassilief 1997a, 1997b), plasma (Junting and Chuichang 1991; Wintersteiger et al. 1994), and urine (Junting and Chuichang 1991; Yi-Qun et al. 1994) are available. Chromatographic techniques, such as GC and HPLC, were used to isolate pyrethrins and their degradation products. ECD, FID, UV, and MS were coupled with the separation techniques to detect these compounds. Sensitivity was high (blood: 1 µg/kg; plasma: 2–0.17 µg/kg; urine: 0.2–0.5 µg/L). These methods can accurately detect pyrethrins at background concentrations in blood, plasma, and urine. Methods are available to characterize the metabolites of selected pyrethroids in urine (Angrer and Ritter 1997; Leng et al. 1999a; Yi-Qun et al. 1994). The sensitivity is high and the recovery is good. The existing methods for detecting the pyrethrins in biological samples seem to be adequate.

Effect. Other than the clinical signs of Type I and Type II pyrethroid poisoning discussed in Section 3.8.2, there are no known biomarkers of effect for pyrethrins and pyrethroids. It is important to note that while these effects are characteristic signs of pyrethroid poisoning, they are not exclusive to pyrethroid poisoning. In humans, pyrethroids are rapidly metabolized by esterase, mainly in the liver, and it may be possible to correlate carboxyesterase activity with pyrethroid induced adverse effects (Leng et al. 1999b). However, human plasma contains very little carboxyesterases and the liver is not accessible for routine measurements. As a parameter of carboxyesterase activity for Type II pyrethroids, the production of cyanic acid in human lymphocytes was measured (Leng et al. 1999b). Initial findings indicate that the determination of carboxyesterase activity in lymphocytes may potentially be used as a marker for individual susceptibility.

Methods for Determining Parent Compounds and Degradation Products in Environmental Media. Methods are available to measure pyrethrins in air (EMMI 1997; Pomorska 1999), foods (EMMI 1997), water (EMMI 1997), waste water (EMMI 1997), soil (Alawi et al. 1990), and in formulations (methods by American Society for Testing Materials [ASTM], NIOSH, Food and Drug Administration [FDA], EPA, Environmental Measurements Laboratory Center [EMLC], Engineering and Analysis Division [EAD], and AOAC). Sensitivity and recovery are not mentioned for several of the methods.

### 7.3.2 Ongoing Studies

Z. Elrassi, of Oklahoma State University, is conducting research on the development of high performance capillary electrophoresis (HPCE) and capillary electrochromatography (CEC) methods for the rapid, sensitive, and efficient separation of pesticides and their metabolites (CRIS 2001). B.W. Blair, of the Canadian Food Inspection Agency, Food Inspection Directorate, Lab Services Division, is developing a rapid, simple, and inexpensive immunological assay technology for low molecular weight contaminants of significance in food safety testing, as a tool for monitoring contaminants in foods and other environmental media (CRIS 2001).

In a study sponsored by the National Institute of Environmental Health Sciences at University of California, Davis, research is being performed to develop and validate single compounds, as well as a class selective immunoassay for urinary metabolites of hazardous compounds such as pyrethroids for use as biomarkers of internal exposure to theses compounds (CRISP 2001).