# 5 PRODUCTION, IMPORT/EXPORT, USE, AND DISPOSAL

## 5.1 PRODUCTION

Information regarding the manufacturers of various pyrethrins and pyrethroids in the United States is given in Table 5-1 (SRI 2000). Table 5-2 lists the number of facilities in each state that produce, process, or import pyrethrins and pyrethroids for commercial use. The intended use and the range of maximum amounts of these substances that are stored on site are also included. The data listed in these tables are derived from the Toxics Release Inventory (TRI99 2001). Only certain types of facilities were required to report, and this is not an exhaustive list. The only pyrethroids that are on the list are allethrin, bifenthrin, cyfluthrin, cyhalothrin, fenpropathrin, fluvalinate, permethrin, phenothrin, resmethrin, and tetramethrin (TRI99 2001). Furthermore, data have only been reported for bifenthrin, cyfluthrin, permethrin, resmethrin, and tetramethrin. No data regarding the production volumes are available.

Naturally-occurring pyrethrins are produced by certain species of chrysanthemum plants (Chrysanthemum cinerariaefolium and Chrysanthemum cineum). Either the flowers are dried and powdered or the oils within the flowers are extracted with solvents such as petroleum ether, acetone, or acetic acid (Metcalf 1995). Synthetic pyrethroids are manufactured by the esterification of an appropriate acid with an appropriate alcohol (Table 5-3).

Technical-grade (concentrated) pyrethroids are usually formulated for use in commercial products. The formulated product may contain up to 99% inert (“secret”) ingredients that improve storing, application handling, or effectiveness. The EPA publishes a complete list of all inert ingredients found in pesticide products registered in the United States, and categorizes them along the following four classes: (1) inert ingredients of toxicological concern; (2) potentially toxic inert ingredients; (3) inert ingredients of unknown toxicity; and (4) inerts of minimal concern (EPA 2003). Even though the EPA publishes a list of all inert ingredients used in currently registered pesticides, it does not specify which ingredients are contained in any specific formulated product, and federal law does not require the pesticide label to identity the inert ingredients unless they are categorized as class one inert ingredients. A common formulation used in pyrethrin and pyrethroid products is an emulsifiable concentrate (EC). The primary inert ingredients in a pesticide product formulated as an EC are an emulsifier and a petroleum solvent, such as kerosene. Other popular formulations are aerosol dispenser (AE), wettable powder (WP), dustable powder (DP), and water dispersible granules (WG) (Tomlin 1997).

Table 5-1 U.S. Producers of Pyrethrins and Pyrethroids

Pyrethroid | Producer | Production site
Bifenthrin | FMC Corporation | Baltimore, Maryland
Cyfluthrin | Bayer Corporation | Kansas City, Missouri; Shawnee, Kansas
Cypermethrin | Astra Zeneca | Cold Creek, Alabama
| FMC Corporation | Baltimore, Maryland
Esfenvalerate | Du Pont | Axis, Alabama
Fluvalinate | BASF Corporation | Beaumont, Texas
Permethrin | Astra Zeneca | Cold Creek, Alabama
| FMC Corporation | Baltimore, Maryland
Pyrethrins (Pyrethrum) | McLaughlin Gormley King | Chaska, Minnesota
| SureCo Incorporated | Fort Valley, Georgia

Source: SRI 2000

Table 5-2 Facilities that Produce, Process, or Use Pyrethroids

State^a^ | Number of facilities | Minimum amount on site in pounds^b^ | Maximum amount on site in pounds^b^ | Activities and uses^c^
Bifenthrin
FL | 1 | 100,000 | 999,999 | 8
IL | 1 | 10,000 | 99,999 | 8
TX | 1 | 10,000 | 99,999 | 2, 3, 8
Cyfluthrin
MO | 1 | 100,000 | 999,999 | 8
TX | 1 | 10,000 | 99,999 | 8
Permethrin
AL | 1 | 100,000 | 999,999 | 1, 4
AR | 1 | 10,000 | 99,999 | 8
FL | 1 | 1,000,000 | 9,999,999 | 8
GA | 1 | 100,000 | 999,999 | 8
IL | 1 | 10,000 | 99,999 | 8
LA | 1 | 1,000 | 9,999 | 8
MD | 1 | 1,000,000 | 9,999,999 | 1, 4
NJ | 1 | 1,000 | 9,999 | 8
TN | 1 | 10,000 | 99,999 | 8
TX | 2 | 10,000 | 99,999 | 2, 3, 8, 10
WI | 1 | 10,000 | 99,999 | 8
Resmethrin
TX | 1 | 10,000 | 99,999 | 8
Tetramethrin
WI | 1 | 10,000 | 99,999 | 8

a Post office state abbreviations used

b Amounts on site reported by facilities in each state

c Activities/Uses:

1. Produce
2. Import
3. Onsite use/processing
4. Sale/Distribution
5. Byproduct
6. Impurity
7. Reactant
8. Formulation Component
9. Article Component
10. Repackaging
11. Chemical Processing Aid
12. Manufacturing Aid
13. Ancillary/Other Uses

Source: TRI99 2001

Table 5-3 Acid and Alcohol Feedstocks in the Pyrethroids Synthesis

Pyrethroid | Acid | Alcohol
Allethrin | [image] | [image]
Bifenthrin | [image] | [image]
Bioresmethrin | [image] | [image]
Cyfluthrin | [image] | [image]
Cyhalothrin | [image] | [image]
Cypermethrin | [image] | [image]
Deltamethrin | [image] | [image]
Esfenvalerate | [image] | [image]
Fenproparthrin | [image] | [image]
Flucythrinate | [image] | [image]
Flumethrin | [image] | [image]
Fluvalinate | [image] | [image]
Permethrin | [image] | [image]
Phenothrin | [image] | [image]
Resmethrin | [image] | [image]
Tefluthrin | [image] | [image]
Tralomethrin | [image] | [image]
Tetramethrin | [image] | [image]

Source: HSDB 2001

## 5.2 IMPORT/EXPORT

No data regarding the import or export volumes of pyrethrins and pyrethroids are available.

## 5.3 USE

Naturally-occurring pyrethrins were first used around 1800 in the Transcaucasus region of Asia to control human lice, mosquitoes, cockroaches, beetles, and flies. Pyrethroids are broad-spectrum insecticides, effective against a wide range of flying, crawling, chewing, and sucking insects of the orders Coleoptera, Diptera, Hemiptera (Homoptera and Heteroptera), Hymenoptera, Lepidoptera, Orthoptera, and Thysanoptera. They are used as household insecticides, as grain protectants, and to control pests on edible products just prior to harvest (Metcalf 1989). They are used in a variety of locations including residential, public, and commercial buildings, animal houses, warehouses, fields, and green houses. They are also extensively used in the field of veterinary medicine (Davies 1985).

All concentrated formulations of pyrethroids were classified as restricted use pesticides by the EPA in 1995 (EPA 2000a). This classification restricts a pesticide to be used only by a certified applicator, or under the direct supervision of a certified applicator. Detailed information regarding the amounts applied and use of individual pyrethroids is provided in Table 5-4. The data shown in Table 5-4 were developed from state-wide estimates of pesticide use rates on cropland and do not include pesticide applications to noncropland areas (i.e., home use, greenhouse use, etc.).

## 5.4 DISPOSAL

All pyrethrins and pyrethroids as well as piperonyl butoxide are listed as toxic substances under Section 313 of the Emergency Planning and Community Right to Know Act (EPCRA) under Title III of the Superfund Amendments and Reauthorization Act (SARA) (EPA 1995). Disposal of wastes containing these compounds is controlled by a number of federal regulations (see Chapter 8). According to the TRI, in 1999, an estimated 1,239 pounds of permethrin were transferred off-site, presumably for disposal (TRI99 2001). No other pyrethroids or pyrethrins were reported as having off-site transfers in 1999 (TRI99 2001).

Table 5-4 Uses of Pyrethroids

Pyrethroid | Amount^a^ (pounds) | Insects^b,c,d^ | Crops^b,c,d^ | Other locations and applications^b,c^
Allethrin | NA | Flies, mosquitoes, ants | N/A | Residential, public health, animal houses, topical application in pet sprays and shampoos
Bifenthrin | 114,377 | Beetles, weevils, houseflies, mosquitoes, lice, bedbugs, aphids, moths, cockroaches, locusts | Alfalfa hay, beans, cantaloupes, cereals, corn, cotton, field and grass seed, hops, melons, oilseed rape, potatoes, peas, raspberries, watermelons, squash | NA
Bioresmethrin | NA | Houseflies, mosquitoes, cockroaches | NA | Household, public health, animal houses
Cyfluthrin | 151,422 | Aphids, cabbage stem flea beetle, cockroaches house flies, mosquitoes, rape winter stem weevil | Alfalfa, cereals, cotton, citrus, deciduous fruit, ground nuts, maize, oilseed rape, pears, potatoes, rice, sugar beet, sugarcane, tobacco, vegetables | Green houses
Cyhalothrin | NA | Bedbugs, beetles, houseflies, ked, lice, mosquitoes, moths, weevils | N/A | Public health, animal houses, inert surfaces
Cypermethrin | 215,066 | Cockroaches, flies, mosquitoes, moths | Cotton, lettuce, onions, pears, peaches, pecans, sugar beets | Residential and commercial buildings, animal houses
Deltamethrin | NA | Aphids, beetles, bollworm, bud-worm, caterpillars, cicadas, codling moths, tortrix moths, weevils, whitefly, winter moths | Alfalfa, beet, cereals, coffee, cotton, figs, fruits, hops, maize, oilseed rape, olives, oil palms, potatoes, rice, soybeans, sunflowers, tea, tobacco, vegetables | Forests, households, animal houses, stored products
Esfenvalerate | 215,919 | Beetles, moths | Cabbage, corn, cotton, fruit trees, grains, groundnuts, maize, pecan, potatoes, sorghum, soybeans, sugar cane, sunflowers, sweet corn, tomatoes, vegetables, wheats | Ornamentals, non-crop land
Fenproparthrin | 146,707 | Aphids, armyworms, bollworms, bud-worms, cabbage looper, cabbage-worms, cutworms, diamondback moth, fruit moths, leaf-miners, leafrollers, leaf-worms, lepidopterous larvae, mites, mosquito, psyllas, stem-borers, ticks, tortrixies, tuber-worms, whiteflies | Cotton, citrus, fruits, pome, tomatoes, vegetables, vines | Glasshouse, ornamental trees
Flucythrinate | NA | Boll-worms, leaf-worms, sucking insects, whiteflies, beetles | Cotton, vines, strawberries, citrus fruit, bananas, pineapples, olives, coffee, cocoa, hops, vegetables, soybeans, cereals, maize, alfalfa, sugarbeet, sunflowers, tobacco | NA
Flumethrin | NA | Lice, ticks, psoroptic, chorioptic and sarcoptic munge | NA | NA
Fenvalerate | 61,582 | Beetles, cockroaches, flies, locusts, mosquitos, moths | Alfalfa hay, apples, beet, cereals, cotton, corn, cucurbita, fruit, green beans, groundnuts, hops, maize, nuts, oilseed rape, olives, potatoes, sorghum, soybeans, squash, sugarcane, sunflower, vegetables, vines, tobacco | Ornamentals, forestry, non-crop land
Fluvalinate | NA | Aphids, leaf-hoppers, moths, spider mites, thrips, white-flies | Apples, cereals, cotton, pears, peaches, tobacco, vegetables, vines | Outdoor and indoor ornamentals, turf
Permethrin | 1,055,097 | Ants, beetle, boll-worm, bud-worm, fleas, flies, lice, moths, mosquitos, termites, weevils | Alfalfa hay, corn, cotton, grains, lettuce, onion, peaches, potatoes, sweet corn, tomatoes, wheat | Home gardens, green houses, pet sprays, and shampoos
Phenotrhin | NA | Ants, bedbugs, cockroaches, fleas, houseflies, lice, mosquitoes, ticks | NA | Public buildings, stored grain, pet sprays, and shampoos
Resmethrin | NA | Flying and crawling insects, mosquitoes houseflies, german cockroaches | NA | Homes, greenhouses, indoor landscapes, mushroom houses, industrial sites
Tefluthrin | 423,973 | Beetles, houseflies, mosquitoes moths, weevils | Corn, maize, sugar beet, sweet corn | NA
Tetramethrin | NA | Flies, cockroaches, mosquitoes, wasps | NA | Public health, home and garden use
Tralomethrin | 53,331 | Aphids, beetles, cockroaches, moths, weevils | Cereals, coffee, cotton, fruit, maize, oilseed rape, rice, soybeans, tobacco, vegetables | Wood protection, homes, public health, stored grain, animal houses

a USGS 2001

b HSDB 2001

c Metcalf 1995

d Tomlin 1997

N/A = not available

The EPA Office of Pesticide Programs has detailed labels for the use, storage, and disposal of all pesticides, including registered products containing pyrethrins and pyrethroids. All pesticide products are required to bear instructions for the storage and disposal of the pesticides and the pesticide containers. Storage and disposal instructions cover the appropriate storage of the pesticide product; disposal of any unused pesticide product or any rinse liquids resulting from cleaning of pesticide application equipment; and the disposal of the pesticide container. State and local regulations may be stricter than the federal requirements listed on the label.