# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

The naturally-occurring pyrethrins, extracted from chrysanthemum flowers, are esters of chrysanthemic acid (Pyrethrin I, Cinerin I, and Jasmolin I) and esters of pyrethric acid (Pyrethrin II, Cinerin II, and Jasmolin II). In the United States, the pyrethrum extract is standardized as 45–55% w/w total pyrethrins. The typical proportion of Pyrethrins I to II is 0.2:2.8, while the ratio of pyrethrins:cinerins:jasmolins is 71:21:7 (Tomlin 1997). Information regarding the chemical identity of the pyrethrins is presented in Table 4-1.

Pyrethroids are synthetic esters derived from the naturally-occurring pyrethrins. One exception to the axiom that all pyrethroids are esters of carboxylic acids is noteworthy. There is a group of oxime ethers that exhibits insecticidal activity similar in nature to the pyrethrins and pyrethroid esters (Davies 1985). Little data exist regarding these compounds, and no commercial products have been produced. Commercially available pyrethroids include allethrin, bifenthrin, bioresmethrin, cyfluthrin, cyhalothrin, cypermethrin, deltamethrin, esfenvalerate (fenvalerate), flucythrinate, flumethrin, fluvalinate, fenpropathrin, permethrin, phenothrin, resmethrin, tefluthrin, tetramethrin, and tralomethrin. Information regarding the chemical identity of pyrethroids is shown in Table 4-2.

With the exception of deltamethrin, pyrethroids are a complex mixture of isomers rather than one single pure compound. For pyrethroids possessing the cyclopropane moiety, isomerism about the cyclopropane ring greatly influences the toxicity of these insecticides. The presence of two chiral centers in the ring results in two pairs of diastereomers. The diastereomers and their nonsuperimposable mirror images (enantiomers) are illustrated in Figure 4-1. In this figure, the C-1 position of the ring is assigned to the carbon atom bonded to the ester moiety. It is also customary to designate the stereochemistry at the C-3 position as simply cis or trans relative to the ester group bonded to C-1 rather than assigning its absolute configuration. The 1R conformations about the cyclopropane ring are considerably more toxic than the 1S isomers. Both the cis and trans isomers show insecticidal activity, but have differing mammalian toxicities, with the cis isomers being more potent (Ray 1991). Pyrethroids that contain a cyano substituent at the alcohol moiety (Type II pyrethroids) demonstrate differing toxicity based upon the optical isomerism of the alpha carbon. It has been demonstrated that the S conformation about the alpha carbon is considerably more toxic towards insects when compared to the R conformation (Dorman and Beasley 1991). Figure 4-2 illustrates the S conformation of the type II pyrethroid cyhalothrin about the alpha carbon. Pyrethroids such as cyfluthrin, cypermethrin, and cyhalothrin possess three chiral centers, and thus consist of eight possible isomers. The production of pyrethroids with differing isomeric ratios is one reason for the wide variation in reported toxicities of these compounds. For example, cypermethrin is formulated as four different insecticides (alpha-, beta-, theta- and zeta-cypermethrin) depending upon the ratio of the different isomers; and each of these products has different toxicologic properties. The complex compositions of several important pyrethroids are illustrated in Table 4-3.

Table 4-1 Chemical Identity of the Pyrethrins^a^

Characteristic | Pyrethrin I | Cinerin I | Jasmolin I
Synonym(s)^b^ | (Z)-(S)-2-methyl-4-oxo-3-(penta-2,4-dienyl)cyclo pent-2-enyl (1R)-trans-2,2-dimethyl-3-(2-methylprop-1-enyl)cyclopropanecarboxylate | (Z)-(S)-3-(but-2-enyl)-2-methyl-4-oxocyclopent-2-enyl (1R)-trans-2,2-dimethyl-3-(2-methylprop-1-enyl)cyclopropanecarboxylate | (Z)-(S)-2-methyl-4-oxo-3-(pent-2-enyl)cyclopent-2-enyl (1R)-trans-2,2-dimethyl-3-(2-methylprop-1-enyl)-cyclopropanecarboxylate
Ratio of isomers | Pure isomer | Pure isomer | Pure isomer
Registered trade name(s) | Alfadex, Evergreen, ExciteR, Milon, Pycon, Pyrocide, Pyronyl | Alfadex, Evergreen, ExciteR, Milon, Pycon, Pyrocide, Pyronyl | Alfadex, Evergreen, ExciteR, Milon, Pycon, Pyrocide, Pyronyl
Chemical formula | C_21_H_28_O_3_ | C_20_H_28_O_3_ | C_21_H_30_O_3_
Chemical structure | [image] | [image] | [image]
Identification numbers:
CAS registry | 121-21-1 | 25402-06-6 | 4466-14-2
NIOSH RTECS^c^ | GZ1725000 | GZ1540000 | No data
EPA hazardous wasted | No data | No data | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMCO shipping | No data | No data | 6302
HSDB^d^ | 6302 | 6837 | No data
NCI | No data | No data | No data

Characteristic | Pyrethrin II | Cinerin II | Jasmolin II
Synonym(s)^b^ | (Z)-(S)-2-methyl-4-oxo-3-(penta-2,4-dienyl)cyclo pent-2-enyl (E)-(1R)-trans-3-(2-methoxy carbonylprop-1-enyl)-2,2-dimethylcyclopropanecarboxylate | (Z)-(S)-3-(but-2-enyl)-2-methyl-4-oxocyclopent-2-enyl (E)-(1 R)-trans-3-(2-methoxycarbonylprop-1-enyl)-2,2-dimethylcyclopropanecarboxylate | (Z)-(S)-2-methyl-4-oxo-3-(pent-2-enyl)cyclopent-2-enyl (E)-(1 R)-trans-3-(2-methoxycarbonylprop-1-enyl)-2,2-dimethylcyclopropanecarboxylate
Ratio of isomers | Pure isomer | Pure isomer | Pure isomer
Registered trade name(s) | Alfadex, Evergreen, ExciteR, Milon, Pycon, Pyrocide, Pyronyl | Alfadex, Evergreen, ExciteR, Milon, Pycon, Pyrocide, Pyronyl | Alfadex, Evergreen, ExciteR, Milon, Pycon, Pyrocide, Pyronyl
Chemical formula | C_22_H_28_O_5_ | C_21_H_28_O_5_ | C_22_H_30_O_3_
Chemical structure | [image] | [image] | [image]
Identification numbers:
CAS registry | 121-29-9 | 121-20-0 | 1172-63-0
NIOSH RTECS^c^ | GZ0700000 | No data | No data
EPA hazardous wasted | No data | No data | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMCO shipping | No data | No data | No data
HSDB^d^ | 6303 | 6838 | No data
NCI | No data | No data | No data

a All information obtained from Tomlin, 1997 except where noted.

b Chemical names used are those currently indexed by the Chemical Abstracts Service.

c NIOSH 1987

d HSDB 2001

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS =Registry of Toxic Effects of Chemical Substances

Table 4-2 Chemical Identity of Selected Pyrethroids^a^

Characteristic | Allethrin | Bifenthrin | Bioresmethrin
Synonym(s)^b^ | 2-methyl-4-oxo-3-(2-propenyl)-2-cyclopenten-1-yl 2,2-dimethyl-3-(2-methyl-1-propenyl)cyclopranecarboxylate | (2-methyl[1,1’-biphenyl]-3-yl)methyl 3-(2-chloro-3,3,3-trifluoro-1-propenyl)-2,2-dimethylcyclopropanecarboxylate | (1R-trans)-[5-phenylmethyl)-3-furanyl]mehtyl 2,2-dimethyl-3-(2-methyl-1-propenyl)cyclopropanecarboxylate
Ratio of isomers | ≥95% (1R)-isomers; ≥75% trans-isomers | ≥97% cis-isomer | ≥90% (1R)-trans-isomer
Registered trade name(s) | Pyresin, Pynamin Forte, Exthrin | Talstar | Isathrine
Chemical formula | C_19_H_26_O_3_ | C_23_H_22_ClF_3_O_2_ | C_22_H_26_O_3_
Chemical structure | [image] | [image] | [image]
Identification numbers:
CAS registry | 584-79-2 | 82657-04-3 | 28434-01-7
NIOSH RTECS^c^ | GZ1925000 | GZ1227800 | GZ1227800
EPA hazardous waste | No data | No data | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMCO shipping | NA2902, NA2588, UN2588, UN2902, UN2903, UN3201, IMO3.2, IMO6.1 | No data | No data
HSDB^d^ | 1511 | 6568 | 6568
NCI | No data | No data | No data

Characteristic | Cyfluthrin | Cyhalothrin | Cypermethrin
Synonym(s)^b^ | Cyano(4-fluoro-3-phenoxyphenyl)methyl 3-(2,2-dichloroethenyl)-2,2-dimethylcyclopropanecarboxylate | [1α,3α(Z)]-(±)-Cyano-(3-phenoxyphenyl)methyl 3-(2-chloro-3,3,3-trifluoro-1-propenyl)2,2-dimethylcyclopropanecarboxylate | Cyano(3-phenoxyphenyl)methyl 3-(2,2-dichloroethenyl)-2,2-dimethylcyclopropanecarboxylate
Ratio of isomers | Unstated stereochemistry | ≥95% cis-isomers | Unstated stereochemistry
Registered trade name(s) | Baythroid, Baygon aerosol, Solfac^b^ | Cyhalon, Grenade | Arrivo, Cymbush, Cymperator, Cynoff, Ripcord, Basathrin, Demar, Grand, Starcyp^b^
Chemical formula | C_22_H_18_Cl_2_FNO_3_ | C_23_H_19_ClF_3_NO_3_ | C_22_H_19_Br_2_NO_3_
Chemical structure | [image] | [image] | [image]
Identification numbers:
CAS registry | 68359-37-5 | 68085-85-8 | 52315-07-8
NIOSH RTECS^c^ | GZ1253000 | GZ122770 | GZ1250000
EPA hazardous waste | No data | No data | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMCO shipping | No data | No data | No data
HSDB^d^ | 6599 | 6791 | 6600
NCI | No data | No data | No data

Characteristic | Deltamethrin | Esfenvalerate | Fenpropathrin
Synonym(s)^b^ | [1R-[1α(S*),3α]]-Cyano(3-phenoxyphenyl)methyl 3-(2,2-dibromo ethenyl)-2,2-dimethylcyclopropanecarboxylate, decamethrin | {S-R*,R*]-Cyano(3-phenoxyphenyl)methyl 4-chloro-2-(1-methylethyl)benzeneacetate, fenvalerate | Cyano(3-phenoxyphenyl)methyl 2,2,3,3-tetramethylcyclopropanecarboxylate(racemate) fenpropanate (unspecified)
Ratio of isomers | ≥98% single isomer | ≥75% (S,S)-isomers | Unstated stereochemistry
Registered trade name(s) | Butox, Decis, K-Othrin, Kordon, Sadethrin^b^ | Sumi-alfa, Sumi-alpha, Asana (esfenvalerate), Pydrin, Ectrin,Sumicidin, Arfen, Dufen, Fenval (fenvalerate)^b^ | Danitol, Herald, Meothrin, Rody, Digital^b^
Chemical formula | C_22_H_19_Br_2_NO_a_ | C_25_H_22_ClNO_3_ | C_22_H_23_NO_3_
Chemical structure | [image] | [image] | [image]
Identification numbers:
CAS registry | 52918-63-5 | 66230-04-4, 51630-58-1 (fenvalerate) | 64257-84-7 (racemic), 39515-41-8 (stereochemistry)
NIOSH RTECS^c^ | GZ1233000, GZ1232000 | CY1576367, CY1576350 | GZ2090500, GZ2090000
EPA hazardous waste | No data | CY1576350 | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMCO shipping | No data | No data | No data
HSDB^d^ | 6604 | 6625, 6640 | 6636
NCI | No data | No data | No data

Characteristic | Flucythrinate | Flumethrin | Fluvalinate
Synonym(s)^b^ | Cyano(3-phenoxyphenyl)methyl 4-(difluoromethoxy)-α-(1-methylethyl)benzeneacetate | α-Cyano-4-fluoro-3-phenoxybenzyl 3-(β,4-dichlorostyryl)-2,2-dimethylcyclopropanecarboxylate | Cyano(3-phenoxyphenyl)methyl N-N-[2-chloro-4-(trifluoromethyphenyl)-DL-valinate, D-valinate
Ratio of isomers | No data | Unstated stereochemistry | Tau-fluvalinate is a 1:1 mixture of (R)-a-cyano, 2-(R) and (S)-a- cyano, 2-(R) diasteriomers
Registered trade name(s) | Cybolt, Cythrin, Pay-off, Fluent | Bayticol, Bayvarol | Klartan, Mavrik
Chemical formula | C_26_H_23_F_2_NO_4_ | C_28_H_22_Cl_2_FNO_3_ | C_26_H_22_ClF_3_N_2_O_3_
Chemical structure | [image] | [image] | [image]
Identification numbers:
CAS registry | 70124-77-5 | 69770-45-2 | 69409-94-5, 102851-06-9 (tau-fluvalinate)
NIOSH RTECS^c^ | CY1578620 | No data | YV9397100
EPA hazardous waste | No data | No data | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMCO shipping | No data | No data | No data
HSDB^d^ | 6647 | No data | 6659
NCI | No data | No data | No data

Characteristic | Permethrin | Phenothrin | Resmethrin
Synonym(s)^b^ | (3-Phenoxyphenyl)methyl3-(2,2-dichloroehenyl)-2,2-dimethylcyclopropanecarboxylate | (3-Phenoxyphenyl)methyl-2,2-dimethyl-3-(2-methyl-1-propenyl)-cyclopropanecarboxylate | [5-Phenylmethyl)-3-furanyl]mehtyl 2,2-dimethyl-3-(2-methyl-1-propenyl)cyclopropanecarboxylate
Ratio of isomers | (1R, trans):(1R,cis):(1S, trans):(1S, cis)=3:2:3:2^e^ | Mixed isomers | 20–30% (1 RS)-cis-isomers; 80–70% (1(RS)-trans-isomers)
Registered trade name(s) | Ambush, Assithrin, Cliper, Coopex, Corsair, Dragnet, Dragon, Kafil, Eksmin, Perkill, Pounce | Sumithrin | Synthrin, Chrysron
Chemical formula | C_21_H_20_Cl_2_O_3_ | C_23_H_26_O_3_ | C_22_H_26_O_3_
Chemical structure | [image] | [image] | [image]
Identification numbers:
CAS registry | 52645-53-1 | 26002-80-2 | 10453-86-8
NIOSH RTECS^c^ | GZ1255000 | GZ1975000 | GZ1310000
EPA hazardous wasted | No data | No data | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMCO shipping | No data | No data | No data
HSDB^d^ | 6740 | 3922 | 6790
NCI | No data | No data | No data

Characteristic | Tefluthrin | Tetramethrin | Tralomethrin
Synonym(s)^b^ | [1α,3α(Z)]-(±)-(2,3,5,6-Tetrafluoro-4-methylphenyl)methyl 3-(2-chloro-3,3,3-trifluoro-1propenyl)-2,2-dimethyl-cyclopropanecarboxylate | (1,3,4,5,6,7-Hexahydro-1,3-dioxo-2H-isoindol-2-yl)methyl 2,2-dimethyl-3-(2-methyl-1-propenyl)-cyclopropanecarboxylate | Cyano(3-phenoxyphenyl)-methyl 2,2-dimethyl-3-(1,2,2,2-tetrabromoethyl)-cyclopropanecarboxylate
Ratio of isomers | Mixture of isomers | (1R, trans):(1R,cis):(1S, trans):(1S, cis)=4:1:4:1^e^ | Unstated stereochemistry
Registered trade name(s) | Force, Fireban | Neo-Pynamin, Duracide | Saga, Scout, Tralox, Tracker, Tralate
Chemical formula | C_17_H_14_ClF_7_O_2_ | C_19_H_25_NO_4_ | C_22_H_19_Br_4_NO_3_
Chemical structure | [image] | [image] | [image]
Identification numbers:
CAS registry | 79538-32-2 | 7696-12-0 | 66841-25-6
NIOSH RTECS^c^ | GZ1227850 | GX1730000 | GZ2009500
EPA hazardous waste | No data | No data | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMCO shipping | No data | No data | No data
HSDB^d^ | No data | 6738 | 6604
NCI | No data | No data | No data

a All information obtained from Tomlin, 1997 except where noted.

b Chemical names used are those currently indexed by the Chemical Abstracts Service.

c NIOSH 1987

d HSDB 2001

e WHO 2001

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS =Registry of Toxic Effects of Chemical Substances

Figure 4-1 Four Possible Isomers of Type I Pyrethroids

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of the pyrethrins and selected pyrethroids are located in Tables 4-4 and 4-5, respectively. Generally, pyrethrins and pyrethroids have low vapor pressures, low Henry’s law constants, and large octanol/water coefficients (K_ow_), and are not very soluble in water. Aside from their interaction with polarized light, enantiomers possess identical physical properties (e.g., boiling point, melting point, solubility, etc.). Diastereomers have different physical properties however, and changes in the geometrical isomeric composition can lead to different values in the properties reported for the pyrethroids listed in Table 4-5.

Table 4-3 Stereoisomers of Selected Pyrethroids^a^

Pyrethroid | Different products | Isomer composition
Cypermethrin | alpha-cypermethrin | Racemic mixture comprised of:; (S)-alpha-cyano-3-phenoxybenzyl-(1R)-cis-3-(2,2-dichlorovinyl)-2,2-dimethylcyclopropanecarboxylate and (R)-alpha-cyano-3-phenoxybenzyl-(1S)-cis-3-(2,2-dichlorovinyl)-2,2-dimethylcyclopropanecarboxylate
| beta-cypermethrin | Mixture comprised of two enantiomeric pairs in a 2:3 ratio:; (S)-alpha-cyano-3-phenoxybenzyl-(1R)-cis-3-(2,2-dichlorovinyl)-2,2-dimethylcyclopropanecarboxylate and (R)-alpha-cyano-3-phenoxybenzyl-(1S)-cis-3-(2,2-dichlorovinyl)-2,2-dimethylcyclopropanecarboxylate with (S)-alpha-cyano-3-phenoxybenzyl-(1R)-trans-3-(2,2-dichlorovinyl)-2,2-dimethylcyclopropanecarboxylate and (R)-alpha-cyano-3-phenoxybenzyl-(1S)-trans-3-(2,2-dichlorovinyl)-2,2-dimethylcyclopropanecarboxylate
| theta-cypermethrin | Racemic mixture comprised of:; (S)-alpha-cyano-3-phenoxybenzyl-(1R)-trans-3-(2,2-dichlorovinyl)-2,2-dimethylcyclopropanecarboxylate and (R)-alpha-cyano-3-phenoxybenzyl-(1S)-trans-3-(2,2-dichlorovinyl)-2,2-dimethylcyclopropanecarboxylate
| zeta-cypermethrin | Mixture of the stereoisomers:; (S)-alpha-cyano-3-phenoxybenzyl(1RS,3RS;1RS,3SR)-3-(2,2-dichlorovinyl)-2,2-dimethylcyclopropanecarboxylate where the ratio of the (S); (1RS,3RS) isomeric pair to the (S);(1RS,3SR) isomeric pair lies in the range of 45-55 to 55-45.
Cyfluthrin | cyfluthrin | Comprised of a mixture of the 4 diastereomeric pairs of enantiomers:; I = (R)-alpha-cyano-4-fluoro-3-phenoxybenzyl-(1R)-cis -3-(2,2-dichlorovinyl)-2,2-dimethylcyclopropanecarboxylate + (S)-alpha, (1S)-cis; II = (S)-alpha-cyano-4-fluoro-3-phenoxybenzyl-(1R)-cis -3-(2,2-dichlorovinyl)-2,2-dimethylcyclopropanecarboxylate + (R)-alpha, (1S)-cis; III = (R)-alpha-cyano-4-fluoro-3-phenoxybenzyl-(1R)-trans -3-(2,2-dichlorovinyl)-2,2-dimethylcyclopropanecarboxylate + (S)-alpha, (1S)-trans; IV = (S)-alpha-cyano-4-fluoro-3-phenoxybenzyl-(1R)-trans -3-(2,2-dichlorovinyl)-2,2-dimethylcyclopropanecarboxylate + (R)-alpha, (1S)-trans; The technical grade product consists of 23-26% I, 16-19% II, 33-36% III and 22-25% IV.
| beta-cyfluthrin | Mixture of II and IV in a 1:2 ratio.
Cyhalothrin | cyhalothrin | (RS)-alpha-cyano-3-phenoxybenzyl (Z) (1RS)-cis-3-(2-chloro-3,3,3-trifluoropropenyl)-2,2-dimethylcyclopropanecarboxylate
| lambda-cyhalothrin | Racemic mixture comprised of:; (S)-alpha-cyano-3-phenoxybenzyl (Z) (1R)-cis-3-(2-chloro-3,3,3-trifluoropropenyl)-2,2-dimethylcyclopropanecarboxylate and (R)-alpha-cyano-3-phenoxybenzyl (Z) (1S)-cis-3-(2-chloro-3,3,3-trifluoropropenyl)-2,2-dimethylcyclopropanecarboxylate

a All information obtained from Tomlin 1997.

Table 4-4 Physical and Chemical Properties of Pyrethrins^a^

Property | Pyrethrin I | Cinerin I | Jasmolin I
Molecular weight | 328.5 | 316.4 | 330.5
Color | No data | No data | No data
Physical state | Viscous liquid^b^ | No data | No data
Melting point, °C | No data | No data | No data
Boiling point, °C | 146–150 at 0.0005 mm Hg, 170 at 0.1 mm Hg^c^ | 136–138 at 0.008 mm Hg^d^ | No data
Density, g/cm^3^ at 25 °C | 1.51 (18 °C) | No data | No data
Odor | No data | No data | No data
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water, mg/L | 0.2 | Insoluble | 0.03^i^
Organic solvent(s) | Soluble | Soluble | No data
Partition coefficients:
Log K_ow_ | 5.9 | 5.93^i^ | 6.42^i^
Vapor pressure, mm Hg at 25 °C | 2.03×10^−5^ | 1.1×10^−6i^ | 4.8×10^−7i^
Henry’s Law constant, atm-m^3^/mol at 25 °C | 7.7×10^−7i^ | 9.6×10^−7i^ | 1.3×10^−6i^
Autoignition temperature | No data | No data | No data
Flashpoint, °C (Pensky-Martens closed cup) | No data | No data | No data
Flammability limits, °C | No data | No data | No data
Conversion factors
Air (25 °C1)^e^ | 1 mg/m^3^=0.074 ppm | 1 mg/m^3^=0.077 ppm | 1 mg/m^3^=0.074 ppm
Explosive limits | No data | No data | No data

Property | Pyrethrin II | Cinerin II | Jasmolin II
Molecular weight | 372.5 | 360.4 | 357.7
Color | No data | No data | No data
Physical state | Viscous liquid^b^ | Viscous oil^b^ | No data
Melting point, °C | No data | No data | No data
Boiling point, °C | 192–193 at 0.007 mm Hg, 200 at 0.1 mm Hg^c^ | 182–184 at 0.001 mm Hg | No data
Density, g/cm^3^ at 25 °C | No data | No data | No data
Odor | No data | No data | No data
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water, mg/L | 9.0 | Insoluble | 0.09^i^
Organic solvent(s) | Soluble | Soluble | No data
Partition coefficients:
Log K_ow_ | 4.3 | 4.98^i^ | 5.47^i^
Vapor pressure, mm Hg at 25 °C | 3.98×10^−7^ | 4.6×10^−7i^ | 1.9×10^−7i^
Henry’s Law constant, atm-m^3^/mol at 25 °C | 7.4×10^−10i^ | 9.2×10^−10i^ | 1.2×10^−9i^
Autoignition temperature | No data | No data | No data
Flashpoint, °C (Pensky-Martens closed cup) | No data | No data | No data
Flammability limits, °C | No data | No data | No data
Conversion factors
Air (25 °C1)^e^ | 1 mg/m^3^=0.066 ppm | 1 mg/m^3^=0.068 ppm | 1 mg/m^3^=0.065 ppm
Explosive limits | No data | No data | No data

a All information obtained from HSDB 2001 except where noted

b Technical grade

c Tomlin 1997

d Budavari 1996

g USDA 2001a

e These air conversion factors were calculated by using the average molecular weight and ideal gas law.

f Milne 1995

h Howard and Meylan 1997

i Estimated value from EPIWIN (Syracuse Research Corporation)

Table 4-5 Physical and Chemical Properties of Selected Pyrethroids^a^

Property | Allethrin | Bifenthrin | Bioresmethrin^b^
Molecular weight | 302.4 | 422.9 | 338.4
Color | Pale yellow^b,c^ | Light brown^c^ | Yellow to brown^c^
Physical state | Viscous liquid | Viscous oil | Viscous liquid^c^
Melting point, °C | ~4 | 68–70 | 71.5-83^d^
Boiling point, °C | 281.5 | No data | Dec. >180
Density, g/cm^3^ at 25 °C | 1.01 (25 °C) | 1.212 (25 °C) | 1.050 (20 °C)
Odor | No data | No data | No data
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water, mg/L | 4.6 (25 °C) | 0.1 | <0.3 (25 °C)
Organic solvent(s) | Soluble | Soluble | Soluble
Partition coefficients:
Log K_ow_ | 4.8 | 6^e^ | >4.7
Vapor pressure, mm Hg at 25 °C | 1.2×10^−6^ (21 °C) | 1.8×10^−4d^ | 1.4×10^−8^
Henry’s Law constant, atm-m^3^/mol at 25 °C | 6.1×10^−7i^ | <1.0×10^−3d^ | 1.3×10^−7f^
Autoignition temperature | No data | No data | No data
Flashpoint, °C (Pensky-Martens closed cup) | 87^b^ | 165^b^ | 92^b^
Flammability limits | No data | No data | No data
Conversion factors
Air (25 °C1)^g^ | 1 mg/m^3^=0.081 ppm | 1 mg/m^3^=0.058 ppm | 1 mg/m^3^=0.072 ppm
Explosive limits | No data | No data | No data

Property | Cyfluthrin | Cyhalothrin | Cypermethrin
Molecular weight^c^ | 453.3 | 449.9 | 416.3
Color | Yellowish brown^c^ | Yellow-brown^c^ | Yellow brown^b,c^
Physical state | Oil (A) | Viscous liquid^c^ | Viscous semi-solid^b,c^
Melting point, °C | 60 (A) | 49.2^g^ | 80.5
Boiling point, °C | No data | 187–190 | No data
Density, g/cm^3^ at 25 °C | No data | 1.25 | 1.25
Odor | Aromatic | Mild | Odorless
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water, mg/L | 0.002 (20 °C)^g^ | 0.003 (20 °C) | 0.004 (20 °C)
Organic solvent(s) | Soluble | Soluble | Soluble
Partition coefficients:
Log K_ow_ | 5.94 | 6.9 | 6.6
Vapor pressure, mm Hg at 25 °C | 2.03×10^−9d^ | 1.5×10^−9^ (20 °C)^d^ | 3.07×10^−9^ (20 °C)
Henry’s Law constant, atm-m^3^/mol at 25 °C | 9.5×10^−7h^ | 1.8×10^−7d^ | 4.2×10^−7d^
Autoignition temperature | No data | No data | No data
Flashpoint, °C (Pensky-Martens closed cup) | 107^b^ | >100^b^ | No data
Flammability limits, °C | No data | No data | No data
Conversion factors
Air (25 °C1)^e^ | 1 mg/m^3^=0.054 ppm | 1 mg/m^3^=0.054 ppm | 1 mg/m^3^=0.059 ppm
Explosive limits | No data | No data | No data

Property | Deltamethrin | Esfenvalerate | Fenpropathrin
Molecular weight^c^ | 505.2 | 419.9 | 349.4
Color | Colorless | Colorless | Yellow brown^c^
Physical state | Crystals | Crystals | Solid^c^
Melting point, °C | 101–102 | 59–60.2 | 45–50
Boiling point, °C | No data | 151–167 | No data
Density, g/cm^3^ at 25 °C | 0.55^b^ | 1.175 | 1.15 (25 °C)
Odor | Odorless | No data | No data
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water, mg/L | <0.002 | 0.0002 (25 °C) | 0.014 (25 °C)^d^
Organic solvent(s) | Soluble | Soluble | Soluble
Partition coefficients:
Log K_ow_ | 6.1 | 4.0 | 6.0 (20 °C)
Vapor pressure, mm Hg at 25 °C | 1.5×10^−8^ | 1.5×10^−9^ | 5.5×10^−6^ (20 °C)
Henry’s Law constant, atm-m^3^/mol at 25 °C | 1.2×10^−4^ | 4.1×10^−7d^ | 1.8×10^−4g^
Autoignition temperature | No data | No data | No data
Flashpoint, °C (Pensky-Martens closed cup) | No data | 256^b^ | No data
Flammability limits, °C | No data | No data | No data
Conversion factors
Air (25 °C1)^g^ | 1 mg/m^3^=0.048 ppm | 1 mg/m^3^=0.058 ppm | 1 mg/m^3^=0.070 ppm
Explosive limits | No data | No data | No data

Property | Flucythrinate | Flumethrin^b^ | Fluvalinate
Molecular weight^c^ | 451.5 | 510.4 | 502.9
Color | Dark amber^b,c^ | Yellowish^c^ | Yellow-amber^c^
Physical state | Viscous liquid^c^ | Viscous oil^c^ | Viscous liquid^c^
Melting point, °C | No data | No data | No data
Boiling point, °C | 108 at 0.35 mm Hg | >250 | >450; 164 at 0.07 mm Hg^b^
Density, g/cm^3^ at 25 °C | 1.189 (22 °C) | No data | 1.29
Odor | No data | No data | No data
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water, mg/L | 0.5 (21 °C) | 9.7×10^−5f^ | 0.002
Organic solvent(s) | Soluble | No data | Soluble
Partition coefficients:
Log K_ow_ | 4.7^d^ | 7.65^i^ | 4.26^g^
Vapor pressure, mm Hg at 25 °C | 8.5×10^−9d^ | 3.9×10^−9f^ | 5.7×10^−7d^
Henry’s Law constant, atm-m^3^/mol at 25 °C | 8.47×10^−8d^ | 4.2×10^−8f^ | 3.05×10^−5d^
Autoignition temperature | No data | No data | No data
Flashpoint, °C (Pensky-Martens closed cup) | No data | No data | 90c
Flammability limits, °C | No data | No data | No data
Conversion factors
Air (25 °C1)^e^ | 1 mg/m^3^=0.054 ppm | 1 mg/m^3^=0.048 ppm | 1 mg/m^3^=0.049 ppm
Explosive limits | No data | No data | No data

Property | Permethrin | Phenothrin | Resmethrin
Molecular weight^c^ | 391.3 | 350.5 | 338.4
Color | Colorless to yellow^c^ | Colorless | Colorless
Physical state | Crystals to viscous liquid^c^ | Liquid | Crystals
Melting point, °C | 34–35 | No data | 56.5
Boiling point, °C | 220 at 0.05 mm Hg^f^ | >290 | Dec. at >180 °C
Density, g/cm^3^ at 25 °C | 1.19–1.27 (20 °C) | 1.061 | 0.96-0.97 (20 °C)
Odor | No data | No data | Chrysanthemate
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water, mg/L | 0.006 (20 °C) | 2.0 (30 °C) | 0.037 (25 °C)^b^
Organic solvent(s) | Soluble | Soluble | Soluble
Partition coefficients:
Log K_ow_ | 6.5 | 7.54^f^ | 5.43
Vapor pressure, mm Hg at 25 °C | 2.2×10^−8^ | 1.4×10^−7b^ | 1.13×10^−8i^
Henry’s Law constant, atm-m^3^/mol at 25 °C | 1.9×10^−6d^ | 1.4×10^−6f^ | <8.9×10^7d^
Autoignition temperature | No data | No data | No data
Flashpoint, °C (Pensky-Martens closed cup) | >100^b^ | 107^b^ | 129^b^
Flammability limits, °C | No data | No data | No data
Conversion factors
Air (25 °C1)^e^ | 1 mg/m^3^=0.062 ppm | 1 mg/m^3^=0.070 ppm | 1 mg/m^3^=0.072 ppm
Explosive limits | No data | No data | No data

Property | Tefluthrin^b^ | Tetramethrin | Tralomethrin
Molecular weight | 418.7 | 331.4 | 665.0
Color | Colorless | Colorless | Yellow orange
Physical state | Solid | Crystals | Resinoid
Melting point, °C | 44.6 | 65–80 | 138–148
Boiling point, °C | 153 at 1 mm Hg | 180–190 | No data
Density, g/cm^3^ at 25 °C | 1.48 | 1.1 (20 °C) | 1.70 (20 °C)
Odor | No data | No data | No data
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water, mg/L | 0.002 (20 °C) | 1.83^b^ | 0.08
Organic solvent(s) | Soluble | Soluble | Soluble
Partition coefficients:
Log K_ow_ | 6.5 | 4.6^c^ | 7.6^f^
Vapor pressure, mm Hg at 25 °C | 6.0×10^−5^ | 7.1×10^−6b^ | 3.6×10^−11^
Henry’s Law constant, atm-m^3^/mol at 25 °C | 4.6×10^−4f^ | 8.3×10^−9f^ | 3.9×10^−15d^
Autoignition temperature | No data | No data | No data
Flashpoint, °C (Pensky-Martens open cup) | 124 | No data | No data
Flammability limits, °C | No data | No data | No data
Conversion factors
Air (25 °C1)^g^ | 1 mg/m^3^=0.058 ppm | 1 mg/m^3^=0.074 ppm | 1 mg/m^3^=0.074 ppm
Explosive limits | No data | No data | No data

a All information obtained from HSDB 2001 except where noted

b Tomlin 1997

c Technical grade

d USDA 2001a

e Milne 1995

f Estimated value from EPIWIN (Syracuse Research Corporation)

g These air conversion factors were calculated by using the average molecular weight and ideal gas law

h Budavari 1996

i Howard and Meylan 1997

Figure 4-2 Illustration of the S Conformer about the Alpha Carbon for the Type II Pyrethroid Cyhalothrin