# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as a hundredfold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agency wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop E-29, Atlanta, Georgia 30333.

## Permethrin Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Permethrin
CAS Number: | 52645-53-1
Date: | August 25, 2003
Profile Status: | Third Draft Post Public
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 20
Species: | Rat

[underlined: Minimal Risk Level]: 0.3 [X] mg/kg/day [ ] ppm

[underlined: Reference]: McDaniel KL, Moser VC. 1993. Utility of a neurobehavioral screening battery for differentiating the effects of two pyrethroids, permethrin and cypermethrin. Neurotoxicol Teratol 15:71–83.8510610

[underlined: Experimental design and effects noted:] The acute-duration oral MRL is based on the results of a study in which the critical effect was neurological impairment in rats. Groups of Long-Evans rats (8/sex/dose) were administered permethrin (95% purity; 50/50 cis/trans; in corn oil vehicle) in single gavage doses of 0, 25, 75, or 150 mg/kg. Selected rats from each dose group were subjected to FOB and motor activity assessment at 2 and 4 hours following dosing. A LOAEL of 75 mg/kg was identified for neurological impairment that included increased excitability and aggressiveness, abnormal motor movement, and decreased grip strength and motor activity. The NOAEL was 25 mg/kg.

[underlined: Dose and end point used for MRL derivation]: 25 mg/kg; multiple neurological effects.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

[ ] 10 for use of a LOAEL

[X] 10 for extrapolation from animals to humans

[X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] No

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:] NA

[underlined: Was a conversion used from intermittent to continuous exposure?] No

[underlined: Agency Contact (Chemical Manager):] G. Daniel Todd, Ph.D.

## Cypermethrin Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Cypermethrin
CAS Number: | 52315-07-8
Date: | August 25, 2003
Profile Status: | Third Draft Post Public
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 21
Species: | Rat

[underlined: Minimal Risk Level]: 0.02 [X] mg/kg/day [ ] ppm

[underlined: Reference]: McDaniel KL, Moser VC. 1993. Utility of a neurobehavioral screening battery for differentiating the effects of two pyrethroids, permethrin and cypermethrin. Neurotoxicol Teratol 15:71–83.8510610

[underlined: Experimental design and effects noted:] The acute-duration oral MRL is based on the results of a study in which the critical effect was neurological impairment in rats. Groups of Long-Evans rats (8/sex/dose) were administered cypermethrin (97% purity; 50/50 cis/trans; in corn oil vehicle) in single gavage doses of 0, 20, 60, or 120 mg/kg. Selected rats from each dose group were subjected to FOB and motor activity assessment at 2 and 4 hours following dosing. A LOAEL of 20 mg/kg was identified for neurological impairment that included statistically significantly altered gait and decreased motor activity. A NOAEL was not established.

[underlined: Dose and end point used for MRL derivation]: 20 mg/kg; neurological effects.

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

[X] 10 for use of a LOAEL

[X] 10 for extrapolation from animals to humans

[X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] No

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:] NA

[underlined: Was a conversion used from intermittent to continuous exposure?] No

[underlined: Agency Contact (Chemical Manager):] G. Daniel Todd, Ph.D.

## Cyhalothrin Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Cyhalothrin
CAS Number: | 68085-85-8
Date: | August 25, 2003
Profile Status: | Third Draft Post Public
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 38
Species: | Dog

[underlined: Minimal Risk Level]: 0.01 [X] mg/kg/day [ ] ppm

[underlined: Reference]: EPA. 1981. Data evaluation record: Chronic toxicity (dog). Tox review 005100 (excerpt).

[underlined: Experimental design and effects noted:] The acute-duration oral MRL is based on the results of a study in which the critical effect was increased fluid feces (diarrhea) in dogs. Groups of 4–5-month-old male and female beagle dogs (6/sex/dose) were administered cyhalothrin (in corn oil vehicle) in gelatin capsules at doses of 0, 1.0, 2.5, or 10.0 mg/kg/day for 26 weeks. The dosing volume was 0.1 mL/kg body weight. A dose-related increase in diarrhea was observed throughout the study, including the first week of treatment (7, 26, and 39% greater incidences of diarrhea in low-, mid-, and high-dose dogs, respectively, relative to controls). The 7% increased incidence of diarrhea at the 1.0 mg/kg/day dose level may not be clear indication of an adverse treatment-related effect. However, the 26% increased incidence of diarrhea at 2.5 mg/kg/day is considered to represent a definitive adverse effect. Thus, 1.0 mg/kg/day is interpreted as a NOAEL and 2.5 mg/kg/day is considered a LOAEL for gastrointestinal effects. A detailed description of the test substance was not provided in the study. The acute-duration oral MRL is based on the assumption that the test substance consisted of technical-grade cyhalothrin with a purity of approximately 90%.

[underlined: Dose and end point used for MRL derivation]: 1.0 mg/kg/day; gastrointestinal effects (diarrhea).

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

[ ] 10 for use of a LOAEL

[X] 10 for extrapolation from animals to humans

[X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] No

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:] NA

[underlined: Was a conversion used from intermittent to continuous exposure?] No

[underlined: Agency Contact (Chemical Manager):] G. Daniel Todd, Ph.D.

## Permethrin Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Permethrin
CAS Number: | 52645-53-1
Date: | August 25, 2003
Profile Status: | Third Draft Post Public
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 41
Species: | Rat

[underlined: Minimal Risk Level]: 0.2 [X] mg/kg/day [ ] ppm

[underlined: Reference]: EPA. 1994b. Memorandum: Permethrin: Review of series 81-8ss and 82-7ss acute and subchronic neurotoxicity screen studies and a literature publication on the neurotoxicity and commentary on a special positive control study with acrylamide. U.S. Environmental Protection Agency. Office of Pesticides and Toxic Substances.

[underlined: Experimental design and effects noted:] The intermediate-duration oral MRL is based on the results of a study in which the critical effect was neurological impairment (tremors, impaired gait, hindlimb splay) in rats. Groups of Sprague-Dawley rats (10/sex/dose) were administered permethrin (technical grade; 50/50 cis/trans) in the diet for 13 weeks at concentrations of 0, 250, 1,500, or 2,500 ppm (time-weighted average doses of 0, 15.5, 91.5, or 150.4 mg/kg/day for males and 0, 18.7, 111.4, or 189.7 mg/kg/day for females). Hindlimb splay was observed as early as days 38 and 18 in some 1,500-ppm males and females, respectively. Other signs of neurotoxicity in the 1,500-ppm rats first appeared between treatment days 35 and 68. Signs of neurotoxicity appeared earlier and were more prevalent in rats of the 2,500-ppm treatment group. There were no signs of neurotoxicity in rats of the 250-ppm treatment group. This study identified a LOAEL of 1,500 ppm (91.5 and 111.4 mg/kg/day in males and females, respectively) for neurotoxicity and a NOAEL of 250 ppm (15.5 and 18.7 for males and females, respectively).

[underlined: Dose and end point used for MRL derivation]: 15.5 mg/kg/day; neurological effects (tremors, impaired gait, hindlimb splay).

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

[ ] 10 for use of a LOAEL

[X] 10 for extrapolation from animals to humans

[X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] Yes, conversion was performed by the study authors.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:] NA

[underlined: Was a conversion used from intermittent to continuous exposure?] No

[underlined: Agency Contact (Chemical Manager):] G. Daniel Todd, Ph.D.

## Cyhalothrin Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Cyhalothrin
CAS Number: | 68085-85-8
Date: | August 25, 2003
Profile Status: | Third Draft Post Public
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 38
Species: | Dog

[underlined: Minimal Risk Level]: 0.01 [X] mg/kg/day [ ] ppm

[underlined: Reference]: EPA. 1981. Data evaluation record: Chronic toxicity (dog). Tox review 005100 (excerpt).

[underlined: Experimental design and effects noted:] The intermediate-duration oral MRL is based on the results of a study in which the critical effect was increased fluid feces (diarrhea) in dogs. Groups of 4–5-month-old male and female beagle dogs (6/sex/dose) were administered cyhalothrin (in corn oil vehicle) in gelatin capsules at doses of 0, 1.0, 2.5, or 10.0 mg/kg/day for 26 weeks. The dosing volume was 0.1 mL/kg body weight. A dose-related increase in diarrhea was observed throughout the study (7, 26, and 39% greater incidences of diarrhea in low-, mid-, and high-dose dogs, respectively, relative to controls). The 7% increased incidence of diarrhea at the 1.0 mg/kg/day dose level may not be clear indication of an adverse treatment-related effect. However, the 26% increased incidence of diarrhea at 2.5 mg/kg/day is considered to represent a definitive adverse effect. Thus, 1.0 mg/kg/day is interpreted as a NOAEL and 2.5 mg/kg/day is considered a LOAEL for gastrointestinal effects. A detailed description of the test substance was not provided in the study. The intermediate-duration oral MRL is based on the assumption that the test substance consisted of technical-grade cyhalothrin with a purity of approximately 90%.

[underlined: Dose and end point used for MRL derivation]: 1.0 mg/kg/day; gastrointestinal effects (diarrhea).

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

[ ] 10 for use of a LOAEL

[X] 10 for extrapolation from animals to humans

[X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] No

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:] NA

[underlined: Was a conversion used from intermittent to continuous exposure?] No

[underlined: Agency Contact (Chemical Manager):] G. Daniel Todd, Ph.D.