# UPDATE STATEMENT

A Technical Report for propylene glycol was released in May 1993. This edition supersedes any previously released draft or final profile or report.

Toxicological profiles are revised and republished as necessary, but no less than once every three years. For information regarding the update status of previously released profiles, contact ATSDR at:

- Agency for Toxic Substances and Disease Registry
  Division of Toxicology and Environmental Medicine/Applied Toxicology Branch
  1600 Clifton Road NE
  Mailstop F-32
  Atlanta, Georgia 30333