# 7 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding propylene glycol in air, water, and other media are summarized in Table 7-1. An MRL of 0.009 ppm has been derived for intermediate-duration inhalation exposure (1.5-364 days) to propylene glycol based on a LOAEL of 51 ppm for nasal hemorrhaging (Suber et al. 1989).

Propylene glycol is regulated under Clean Air Act New Source Performance Standards for the synthetic organic chemical manufacturing industry (EPA 1993b). Propylene glycol is regulated by the Clean Water Act Effluent Guidelines for organic chemicals, plastics, and synthetic fibers (OCPSF). The waste water generated by the production of these chemicals has effluent limitations on biochemical oxygen demand (BOD5), total suspended solids (TSS), and pH (EPA 1987d).

Table 7-1 Regulations and Guidelines Applicable to Propylene Glycol

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
WHO | Acceptable daily intake | 0-25 mg/kg | FAO/WHO 1974
[underlined: NATIONAL]
Regulations and guidelines:
a. Air
EPA OAR | App. A – Chemicals defining synthetic organic chemical and polymer manufacturing | Yes | 40 CFR 52; EPA 1972a
EPA OAR | Subpart VV – Std. of performance for equipment leaks of VOC in SOCMI: Chemicals produced by affected facilities | Yes | 40 CFR 60.489; EPA 1983
EPA OAR | Definitions of emissions from polymer manufacturers: Definition of “polymerization reaction section” | Yes | 40 CFR 60.561; EPA 1990b
EPA OAR | Subpart NNN – Std. of performance for VOC emissions from SOCMI distillation operations: Chemical affected | Yes | 40 CFR 60.667; EPA 1990b
EPA OAR | Subpart RRR – Std. of performance for VOC emissions from SOCMI process reactors: Chemicals affected | Yes | 40 CFR 60.707; EPA 1993b
EPA OAR | New source performance standard | Yes | 58 FR45962; EPA 1993c
b. Water
EPA OW | Bulk organic chemicals under the Clean Water Act | Yes | 40 CFR 414.70; EPA 1987d
EPA OW | App. A – Non-complexed metal-bearing waste | Yes | 40 CFR 414; EPA 1987d
EPA OWRS | Pesticide subject to registration and reregistration | Yes | 40 CFR 152.146; EPA 1989b; EPA 1989a
c. Food
FDA | Generally recognized as safe | Yes | 21 CFR 184.1666; FDA 1982
FDA | 2,4-D: Food tolerances for residues 2,4-D Applied in the form of polyethylene glycol and/or propylene glycol | | 40 CFR 180.142; EPA 1982
FDA | Max. 2,4-D tolerance: Pastu re and rangeland grasses | 1,000 ppm | 40 CFR 180.142; EPA 1982
FDA | Min. 2,4-D tolerance: Blueberries and rice | 0.1 ppm | 40 CFR 180.142; EPA 1982
FDA | Inert ingredients exempt from tolerances | Yes | 40 CFR 180.1001; EPA 1971
d. Other
EPA OPTS | Temperature correction factors for organic solvents | 0.043 K°C/mmHg | 40 CFR 796.1220; EPA 1985a
EPA OPTS | Avian dietary testing procedures – sample diluents | Yes | 40 CFR 797.2050; EPA 1985b
EPA OPTS | Sample Diluents for Bobwhite reproductive tests | Yes | 40 CFR 797.2130; EPA 1985b
EPA OPTS | Sample diluents for Mallard reproductive Tests | Yes | 40 CFR 797.2150; EPA 1985b
EPA OPTS | Sample carriers for avian acute toxicity test | Yes | 40 CFR 797.2175; EPA 1985b
[underlined: STATE]
Regulations and guidelines:
a. Air: | Acceptable ambient air concentrations
VA | 24 hours | 1.10x10^3^ µg/m^3^ | NATICH 1991

EPA = Environmental Protection Agency; FDA = Food and Drug Administration; NATICH = National Air Toxics Information Clearinghouse; OAR = Office of Air and Radiation; OPTS = Office of Pesticides and Toxic Substances; OW = Office of Water; OWRS = Office of Waste Regulations and Standards; SOCMI = Synthetic Organic Chemical Manufacturing Industry; VOC = Volatile Organic Compound