# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Information regarding the chemical identity of propylene glycol is located in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of propylene glycol is located in Table 3-2.

Table 3-1 Chemical Identity of Propylene Glycol^a^

Characteristic | Information
Chemical name | Propylene glycol
Synonyms and trade names | 1,2-Dihydroxypropane; 1,2-propanediol; 1,2-propylene glycol; 2,3-propanediol; hydroxy-propanol; alpha-propylene glycol; methyl glycol; methylethyl glycol; monopropylene glycol; trimethyl glycol.
Registered trade name(s) | PG-12; Sirlene
Chemical formula | C_3_H_8_O_2_
Chemical structure^b^ | Chemical identity of propylene glycol
Identification numbers:
CAS registry | 57-55-6
NIOSH RTECS | TY2000000
EPA hazardous waste | No data
OHM/TADS | 7216877
DOT/UN/NA/IMDG shipping | No data
HSDB | 174
NCI | No data

a All information obtained from HSDB 1994b, except where noted.

b EPA 1987a

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 3-2 Physical and Chemical Properties of Propylene Glycol^a^

Property | Propylene glycol
Molecular weight | 76.11^b^
Color | Colorless^d^
Physical state | Liquid^b^
Melting point | -60 °C^e,b^ (forms glass)
Boiling point | 187.6; 188.2 °C^b^
Density:
at 20 °C (g/cm^3^) | 1.0361^c^
Odor | Odorless
Odor threshold | No data
Solubility:
Water at 20 °C | Miscible with water
Organic solvent(s) | Soluble in alcohol, ether, benzene, soluble in acetone, chloroform^b^.
Partition coefficients:
Log K_ow_ | -0.92^f,g^
Log K_oc_ | 0.88^f^, 0.76^g^
Vapor pressure at 20 °C | 0.07 mm Hg ^also^ ^d^
Henry’s law constant at 25 °C | 1.2x10^-8^ atm-m^3^/mole; 1.7x10^-8^ atm-m^3^/mole^g^
Autoignition temperature | 421.26 °C^h^; 371 °C^i^
Flashpoint | 99.04 °C^h,i^
Flammability limits | 2.6–12.5%^h,i^
Conversion factors | 1 ppm = 3.11 mg/m^3j^; 1 mg/L = 321.6 ppm^j^
Explosive limits | No data

a All information obtained from HSDB 1995b, except where noted.

b Merck 1989

c Weast 1988

d Lewis 1993

e Daubert and Danner 1980

f EPA 1987a

g ASTER 1995

h Daubert and Danner 1989

i NFPA 1994

j Rowe and Wolf 1982