# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

## Propylene glycol Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Propylene glycol
CAS Numbers: | 57-55-6
Date: | December 1995
Profile Status: | Third Draft Post Public Comment
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 1
Species: | Rat

[underlined: Minimal Risk Level]: 0.009 [ ] mg/kg/day [X] ppm

[underlined: Reference]: Suber et al. 1989

[underlined: Experimental design]: Young, healthy adult Sprague-Dawley rats were divided into 4 groups of 19 males and 19 females each. Three groups were exposed for 5 days per week, 6 hours per day for 13 weeks by nose-only inhalation to mean target aerosol concentrations of 51, 321, or 707 ppm propylene glycol. The fourth, the control group, was exposed to humidified, filtered room air. Nasal hemorrhaging occurred in all exposed groups of male and female rats indicating that propylene glycol can act as a dehydrogenating agent. From week 2-14, the average of nasal hemorrhaging in male rats was <1%, 64%, 74%, and 75% in controls, low-exposure, medium-exposure, and high-exposure groups, respectively. In females, the average indices were < 1% in controls, 14% in the low-exposure group, and 71% in the medium and high-exposure groups. Animals recovered during non-exposure weekend periods. Similar trends were observed for ocular discharge, with females having generally less ocular discharge than males. A significant reduction in body weight of 5-7% starting on day 50 and continuing until the end of the study was observed in female rats receiving the highest dose of 707 ppm propylene glycol. Similar observation was made in the group receiving 321 ppm of propylene glycol but later in the study starting on day 64. This body weight reduction was correlated with a significant reduction in food consumption beginning on study day 43 and 50 for the high- and medium-exposure females, respectively. Female rats exposed to 321 ppm propylene glycol had a significant decrease in white blood cell count and lymphocyte numbers. Female rats exposed to 707 ppm propylene glycol had a significant decrease in hemoglobin concentration, white blood cell count and lymphocyte numbers. Male rats in the medium (321 ppm) and high (707 ppm) groups had a significant decrease in serum sorbitol dehydrogenase and gamma-glutamyl transferase. A significant decrease in total serum protein was observed in male rats treated with high (707 ppm) dose of propylene glycol while females treated with a medium (321 ppm) dose of propylene glycol had an increase in total serum protein. These changes were considered as being sporadic. Kidney weight was decreased at 321 ppm in both sexes. Although there were no treatment-related gross pathology changes, light microscopy revealed thickening of respiratory epithelium with increase in the number of goblet cells and their mucin content in both female and male animals receiving medium and high propylene glycol dose. Minute volume, tidal volume, and respiratory rates were not significantly altered in rats exposed to 51, 321, or 707 ppm propylene glycol for 13 weeks, suggesting that animals adapted to the exposure concentrations.

[underlined: Effects noted in study and corresponding doses:] Nasal hemorrhaging was observed in all PG-treated groups:

51 ppm PG = low dose (64% in males, 14% in females; less serious LOAEL)

321 ppm PG = mid dose (74% in males, 71% in females)

707 ppm PG = high dose (75% in males, 71% in females)

[underlined: Dose and end point used for MRL derivation]:

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

[ ] 1 [ ] 3 [X] 10 (for use of a LOAEL)

[ ] 1 [ ] 3 [X] 10 (for extrapolation from animals to humans)

[ ] 1 [ ] 3 [X] (10 for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? If so, explain: No conversion was used.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Doses were converted from mg/L to ppm:

0.16 mg/L × 1,000 = 160 mg/m3. 160 mg/m^3^ × 24.45/76.09 (MW PG) = 51.4 ppm

1.0 mg/L = 321.3 ppm

2.2 mg/L = 706.9 ppm

[underlined: Was a conversion used from intermittent to continuous exposure]?

If so, explain: Animals were exposed for 6 hours per day, 5 days per week. Since the effect (nasal hemorrhaging) subsided when exposure was discontinued during the weekend periods, it seemed relevant to adjust the exposure period not only to a continuous 24 hour, but also to a 7-day exposure. Therefore conversion factors of 6/24 and 5/7 were used: 51 ppm × 6/24 × 5/7 = 9 ppm

[underlined: Other additional studies or pertinent information that lend support to this MRL]: This was the only suitable intermediate-duration inhalation exposure study available

[underlined: Agency Contacts (Chemical Managers)]: Ed Murray