# 8 REFERENCES

*Cited in text

Aardema MJ, Gibson DP, Kerckaert GA, . 1990. Aneuploidy and nonrandom structural chromosome changes associated with early and late stages of benzo[a]pyrene-induced neoplastic transformation of Syrian hamster embryo. Environ Mol Mutagen Suppl 15(17):3.
*Abe S, Nemoto N, Sasaki M. 1983a. Comparison of aryl hydrocarbon hydroxylase activity and inducibility of sister-chromatid exchanges by polycyclic aromatic hydrocarbons in mammalian cell lines. Mutat Res 122:47–51.6312306
*Abe S, Nemoto N, Sasaki M. 1983b. Sister-chromatid exchange induction by indirect mutagens/carcinogens, aryl hydrocarbon hydroxylase activity and benzo[a]pyrene metabolism in cultured human hepatoma cells. Mutat Res 109:83–90.6300668
Abe S, Sasaki M. 1977. Chromosome aberrations and sister chromatid exchanges in Chinese hamster cells exposed to various chemicals. J Natl Cancer Inst 58:1635–1641.864744
ACGIH. 1986. Documentation of the threshold limit values and biological exposure indices. 5th ed. American Conference of Governmental Industrial Hygienists, Cincinnati, OH, 143.
ACGIH. 1991. Documentation of the threshold limit values and biological exposure indices. 6th ed. American Conference of Governmental Industrial Hygienists. Cincinnati, OH, 504–505.
*ACGIH. 1992. 1993 Threshold limit values for chemical substances and physical agents and biological exposure indicies. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*ACGIH. 1993. 1993-1994 Threshold limit values for chemical substances and physical agents and biological exposure indicies. American Conference of Governmental Industrial Hygienists. Cincinnati, OH. Pp. 36–37.
Achard S, Perderiset M, Jaurand M-C. 1987. Sister chromatid exchanges in rat pleural mesothelial cells treated with crocidolite, attapulgite, or benzo 3-4 pyrene. Br J Ind Med 44:281–283.3032231
*Adams JD, O’Mara-Adams J, Hoffmann D. 1987. Toxic and carcinogenic agents in undiluted mainstream smoke and sidestream smoke of different types of cigarettes. Carcinogenesis 8:729–731.3581431
*Adler I-D, Ingwersen I. 1989. Evaluation of chromosomal aberrations in bone marrow of lC3Fl mice. Mut Res 224(3):343–345 2811922
*Adler ID, Kliesch U, Kiefer F. 1989. Clastogenic effects of benzo[a]pyrene in postimplantation embryos with different genetic background. Teratogenesis Carcinog Mutagen 9(6):383–92.2576817
*Agarwal R, Gupta KP, Kumar S, . 1986. Assessment of some tumorigenic risks associated with fresh and used cutting oil. Indian J Exp Biol 24:508–510.3817891
*Agarwal R, Medrano EE, Khan IU, . 1991. Metabolism of benzo(a)pyrene by human melanocytes in culture. Carcinogenesis 12(10): 1963–1966.1934279
Agrelo C, Amos H. 1981. DNA repair in human fibroblasts. In: Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:528–532.
*Akin FJ, Snook ME, Severson RE, . 1976. Identification of polynuclear aromatic hydrocarbons in cigarette smoke and their importance as tumorigens. J Natl Cancer Inst 57:191–195.826646
Alarie JP, Vo-Dinh T. 1991. Fibre-optic cyclodextrin-based sensor. Talanta 38(5):529–534.18965183
*Alben K. 1980. Gas chromatographic-mass spectrometric analysis of chlorination effects on commercial coal-tar leachate. Anal Chem 52: 1825–1828.
*Albert RE, Miller ML, Cody T, . 1991a. Benzo(a)pyrene-induced skin damage and tumor promotion in the mouse. Carcinogenesis 12(7):1273–1280.2070493
*Albert RE, Miller ML, Cody TE, . 1991b. Cell kinetics and benzo[a]pyrene-DNA adducts in mouse skin tumorigenesis. Prog Clin Biol Res 369:115–22.1946511
*Aldrich. 1986. Catalog handbook of fine chemicals. Milwaukee, WI: Aldrich Chemical Company.
*Alexandrov K, Rojas-Moreno M. 1990. In vivo DNA adduct formation by benzo(a)pyrene in mouse and rat epidermal and dermal fibroblasts after topical application of an initiating dose of benzo(a)pyrene. Arch Geschwulstforsch 60(5):329–340.2241509
*Alexandrov K, Rojas-Moreno M, Goldberg M, . 1990. A new sensitive fluorometric assay for the metabolism of (--)-7 8-dihydroxy-7 8-dihydrobenzo[a]pyrene by human hair follicles. Carcinogenesis 11(12):2157–2161.2265467
Alfheim I, Randahl T. 1984. Contribution of wood combustion to indoor air pollution as measured by mutagenicity in salmonella and polycyclic aromatic hydrocarbon concentration. Environ Mutagen 6:121–130.6368216
Allen-Hoffman BL, Rheinwald JG. 1984. Polycyclic aromatic hydrocarbon mutagenesis of human epidermal keratinocytes in culture. Proc Natl Acad Sci USA 81:7802–7806.6440145
*Alzieu P, Cassand P, Colin C, . 1987. Effect of vitamins A, C and glutathione on the mutagenicity of benzo[a]pyrene mediated by S9 from vitamin A-deficient rats. Mutat Res 192:227–231.2446127
Amacher DE, Paillet SC. 1982. Hamster hepatocyte-mediated activation of procarcinogens to mutagens in the L5178Y/TK mutation assay. Mutat Res 106:305–316.7155171
Amacher DE, Paillet SC. 1983. The activation of procarcinogens to mutagens by cultured rat hepatocytes in the L5178Y/TK mutation assay. Mutat Res 113:77–88.6828044
Amacher DE, Turner GN. 1980. Promutagen activation by rodent-liver postmitochondrial fractions in the L5178Y/TK cell mutation assay. Mutat Res 74:485–501.7464853
Amacher DE, Paillet SC, Turner GN, . 1980. Point mutations at the thymidine kinase locus in L5178Y mouse lymphoma cells: II. Test validation and interpretation. Mutat Res 72:447–474.7453708
*Amin S, LaVoie EJ, Hecht SS. 1982. Identification of metabolites of benzo(b)fluoranthene. Carcinogenesis 3:171–174.7067045
*Amin S, Hussain N, Brielmann H, . 1984. Synthesis and mutagenicity of dihydrodiol metabolites of benzo(b)fluoranthene. J Org Chem 49:1091–1095.
*Amin S, Huie K, Hecht S. 1985a. Mutagenicity and tumor-initiating activity of methylated benzo(b)fluoranthenes. Carcinogenesis 6: 1023–1025.3893781
*Amin S, Hussain N, Balanikas G, . 1985b. Mutagenicity and tumor initiating activity of methylated benzo[k]fluoranthenes. Cancer Lett 26:343–347.3995506
*Ampy FR, Saxena S, Verma K. 1988. Mutagenicity of benzo-a-pyrene in uninduced tissues from Balb-c mice and Sprague-Dawley rats as an index of possible health risks using the Salmonella mutagenicity assay. Cytobios 56(225):81–88.3251684
*Andersson K, Levin J-O, Nilsson C-A. 1983. Sampling and analysis of particulate and gaseous polycyclic aromatic hydrocarbons from coal tar sources in the working environment. Chemosphere 12:197–207.
*Andrews AW, Thibault LH, Lijinsky W. 1978. The relationship between carcinogenicity and mutagenicity of some polynuclear hydrocarbons. Mutat Res 51:311–318.362176
*Andrews FJ, Halliday GM, Muller HK. 1991a. A role for prostaglandins in the suppression of cutaneous cellular immunity and tumour development in benzo(a)pyrene but not dimethylbenz(a)anthracene-treated mice. Clin Exp Immunol 85(1):9–13.1906386
*Andrews FJ, Halliday GM, Narkowicz CK, . 1991b. Indomethacin inhibits the chemical carcinogen benzo(a)pyrene but not dimethylbenz(a)anthracene from altering Langerhans cell distribution and morphology. Br J Dermatol 124(1):29–36.1899617
*Antignac E, Koch B, Grolier P, . 1990. Prochloraz as potent inhibitor of benzo[a]pyrene metabolism and mutagenic activity in rat liver fractions. Toxicol Lett 54(2–3):309–315.2260127
*Apostoli P, Crippa M, Fracasso ME, . 1993. Increases in polycyclic hydrocarbon content and mutagenicity in a cutting fluid as a consequence of its use. Int Arch Occup Environ Health 64:473–477.8482586
Arce GT, Allen JW, Doerr CL, . 1987. Relationships between benzo(a)pyrene-DNA adduct levels and genotoxic effects in mammalian cells. Cancer Res 47:3388–3395.3581076
*Arcos JC, Argus MF. 1968. Molecular geometry and carcinogenic activity of aromatic compounds. Adv Cancer Res 11:305–471.4181096
*Ariese F, Kok SJ, Verkaik M, . 1993. Monitoring benzo(a)pyrene exposure using laser-excited Shpol’skii spectroscopy of benzo(a)pyrene metabolites. In: T. Vo-Dinh and K. Cammann, eds. International conference on monitoring of toxic chemicals and biomarkers. SPIE Proceedings Series, volume 1716, 212–222.
Armstrong DW, DeMond W. 1984. Cyclodextrin bonded phases for the liquid-chromatographic separation of optical geometrical and structural isomers. J Chromatogr Sci 22(9): 411–415.
*Asher SA. 1984. UV resonance Raman spectrometry for detection and speciation of trace polycyclic aromatic hydrocarbons. Anal Chem 56:720–724.
*Assennato G, Ferri GM, Foa V, . 1993. Correlation between PAH airborne concentration and PAH-DNA adduct levels in coke-oven workers. Int Arch Occup Environ Health 65:S143–S145.8406912
*ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
*ATSDR. 1990. Toxicological profile for creosote. Agency for Toxic Substances and Disease Registry, Atlanta, GA.
*ATSDR. 1994. Materials submitted in support of comments on toxicological profile for PAHs, regulations and advisories. Agency for Toxic Substances and Disease Registry. Atlanta, GA.
*ATSDR/CDC. 1990. Subcommittee report on biological indicators of organ damage. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention, Atlanta, GA.
*Autrup H, Seremet T. 1986. Excretion of benzo[a]pyrene-Gua adduct in the urine of benzo[a]pyrene- treated rats. Chem Biol Interact 60:217–226.3791489
*Autrup H, Harris CC, Stoner GD, . 1978. Metabolism of [^3^H]benzo[a]pyrene by cultured human bronchus and cultured human pulmonary alveolar macrophages. Lab Invest 38:217–224.633846
*Avigdor S, Zakheim D, Bamea ER. 1992. Quinone reductase activity in the first trimester placenta: Effect of cigarette smoking and polycyclic aromatic hydrocarbons. Reprod Toxicol 6(4):363–336.1521010
*Awogi T, Sato T. 1989. Micronucleus test with benzo[a]pyrene using a single peroral administration and intraperitoneal injection in males of the MS/Ae and CD-l mouse strains. Mutat Res 223(4):353–356.2747717
*Ayrton AD, McFarlane M, Walker R, . 1990. Induction of the P-450 I family of proteins by polycyclic aromatic hydrocarbons: Possible relationship to their carcinogenicity. Toxicology 60(1–2):173–186.2315940
*Azuine MA, Kayal JJ, Bhide SV. 1992. Protective role of aqueous turmeric extract against mutagenicity of direct-acting carcinogens as well as benzo [alpha] pyrene-induced genotoxicity and carcinogenicity. J Cancer Res Clin Oncol 118(6):447–452.1618892
*Babich H, Sardana MK, Borenfreund E. 1988. Acute cytotoxicities of polynuclear aromatic hydrocarbons determined in vitro with the human liver tumor cell line, HepG2. Cell Biol Toxicol 4(3):295–309.2852052
Babson JR, Russo-Rodriquez SE, Rastetter WH, . 1986. In vitro DNA-binding of microsomally-activated fluoranthene: Evidence that the major product is a fluoranthene N_2_-deoxyguanosine adduct. Carcinogenesis 7:859–865.3708750
*Badiali D, Marcheggiano A, Pallone F, . 1985. Melanosis of the rectum in patients with chronic constipation. Dis Colon Rectum 28:241–245.3979226
*Back SO, Field RA, Goldstone ME, . 1991. A review of atmospheric polycyclic aromatic hydrocarbons: Sources fate and behavior. Water Air Soil Pollut 60(3–4):279–300.
*Baird WM, Salmon CP, Diamond L. 1984. Benzo(e)pyrene-induced alterations in the metabolic activation of benzo(a)pyrene and 7,12-dimethylbenz(a)anthracene by hamster embryo cells. Cancer Res 44(4):1445–1452.6322978
Baker JE, Eisenreich SJ. 1990. Concentrations and fluxes of polycyclic aromatic hydrocarbons and polychlorinated biphenyls across the air-water interface of Lake Superior (USA and Canada). Environ Sci Technol 24(3):342–352.
*Baker JE, Eisenreich SJ, Eadie BJ. 1991. Sediment trap fluxes and benthic recycling of organic carbon, polycyclic aromatic hydrocarbons, and polychlorinated congeners in Lake Superior. Environ Sci Technol 25:500–509.
Barbieri O, Ognio E, Rossi O, . 1986. Embryotoxicity of benzo[a]pyrene and some of its synthetic derivatives in Swiss mice. Cancer Res 46:94–98.3753553
Barfknecht TR, Hites RA, Cavaliers EL, . 1982. Human cell mutagenicity of polycyclic aromatic hydrocarbon components of diesel emissions. Dev Toxicol Environ Sci 10:277–294.6176427
*Barnes ER, Shurtz-Swirski R. 1992. Modification of pulsatile human chorionic gonadotrophin secretion in first trimester placental explants induced by polycyclic aromatic hydrocarbons. Hum Reprod 7(3):305–310.1587934
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Barnes DG, Bellin J, DeRosa C, . 1987. Reference dose (RfD): Description and use in health risk assessments. Volume 1, Appendix A: Integrated risk information system supportive documentation. Cincinnati, OH: US Environmental Protection Agency, Office of Health and Environmental Assessment. EPA 600/g-86/0322.
Bamsley E. 1975. The bacterial degradation of fluoranthene and benzo[a]pyrene. Can J Microbial 21:1004–1008.
Barratt RW, Tatum EL. 1958. Carcinogenic mutagens. Ann NY Acad Sci 71:1072–1084.13583871
*Barrick RC. 1982. Flux of aliphatic and polycyclic aromatic hydrocarbons to central Puget Sound from Seattle (Westpoint) primary sewage effluent. Environ Sci Technol 16:682–692.
*Bartosek I, Guaitani A, Modica R, . 1984. Comparative kinetics of oral benz(a)anthracene, chrysene and triphenylene in rats: Study with hydrocarbon mixtures. Toxicol Lett 23:333–339.6549236
*Bassett DJP, Bowen-Kelly E, Seed JL. 1988. Rat lung benzo[a]pyrene metabolism following three days continuous exposure to 0.6 ppm ozone. Res Commun Chem Pathol Pharmacol 60:291–307.3175329
*Basu DK, Saxena J. 1978a. Monitoring of polynuclear aromatic hydrocarbons in water: II. Extraction and recovery of six representative compounds with polyurethane foams. Environ Sci Technol 12:791–795.
*Basu DK, Saxena J. 1978b. Polynuclear aromatic hydrocarbons in selected U.S. drinking waters and their raw water sources. Environ Sci Technol 12:795–798.
*Bayer U. 1979. In vivo induction of sister chromatid exchanges by three polyaromatic hydrocarbons. Carcinogenesis 3:423–428.
*Becher G. 1986. Determination of exposure to PAH by analysis of urine samples. Banbury Report., 33–44.
*Becher G, Bjorseth A. 1983. Determination of exposure to polycyclic aromatic hydrocarbons by analysis of human urine. Cancer Lett 17:301–311.6831387
*Becher G, Bjorseth A. 1985. A novel method for the determination of occupational exposure to polycyclic aromatic hydrocarbons by analysis of body fluids. In: Cooke M, Dennis AJ, eds. Polynuclear aromatic hydrocarbons: Mechanisms, methods and metabolism. Columbus, OH: Battelle Press, 145–155.
*Becher G, Haugen A, Bjorseth A. 1984. Multimethod determination of occupational exposure to polycyclic aromatic hydrocarbons in an aluminum plant. Carcinogenesis 5:647–651.6722981
*Bechtold WE, Sun JD, Wolff RK, . 1991. Globin adducts of benzo[a]pyrene: Markers of inhalation exposure as measured in F344/N rats. J Appl Toxicol 11(2):115–118.2061548
*Behymer TD, Hites RA. 1988. Photolysis of polycyclic aromatic hydrocarbons adsorbed on fly ash. Environ Sci Tech 22:1311–1319.
*Beniot FM, Lebel GL, Williams DT. 1979. The determination of polycyclic aromatic hydrocarbons at the ng/L level in Ottawa, Canada tap water. Int J Environ Anal Chem 6:277–288.489217
*Benjamin H, Storkson J, Tallas PG, . 1988. Reduction of benzo[a]pyrene-induced forestomach neoplasms in mice given nitrite and dietary soy sauce. Food Chem Toxicol 26(8):671–678.3198035
*Benner BA Jr., Gordon GE. 1989. Mobile sources of atmospheric polycyclic aromatic hydrocarbons: a roadway tunnel study. Environ Sci Technol 23:1269–1278.
Benson JM, Royer RE, Galvin JB, . 1983. Metabolism of phenanthridone to phenanthridone by rat lung and liver microsomes after induction with benzo(a)pyrene and Aroclor. Toxicol Appl Pharmacol 68(1):36–42.6302951
*Berenblum I, Haran H. 1955. The influence of croton oil and of polyethylene glycol-400 on carcinogenesis in the forestomach of the mouse. Cancer Res 15:510.13250515
Bevan DR, Sadler VM. 1992. Quinol diglucuronides are predominant conjugated metabolites found in bile of rats following intratracheal instillation of benzo[a]pyrene. Carcinogenesis 13(3):403–407.1547530
*Bevan DR, Ulman MR. 1991. Examination of factors that may influence disposition of benzo(a)pyrene in vivo: Vehicles and asbestos. Cancer Lett 57(2):173–180.2025889
*Bevan DR, Weyand EH. 1988. Compartmental analysis of the disposition of benzo[a]pyrene in rats. Carcinogenesis 9(11):2027–2032.3180340
*Bewley R, Ellis B, Theile P, . 1989. Microbial clean-up of contaminated soil. Chem Indus 4:778–783.
Bhatia AL, Tausch H, Stehlik G. 1987. Mutagenicity of chlorinated polycyclic aromatic compounds. Ecotoxicol Environ Safety 14:48–55.3322794
*Biancifiori C, Caschera F. 1962. The relation between pseudopregnancy and the chemical induction by four carcinogens of mammary and ovarian tumours in BALB/c mice. Br J Cancer 16:722–730.13968066
Bieri RH, Greaves J. 1987. Characterization of benzo(a)pyrene metabolites by high performance liquid chromatography-mass spectrometry with a direct liquid introduction interface and using negative chemical ionization. Biomed Environ Mass Spectrum 14:555–561.
Bieri RH, Hein C, Huggett RJ, . 1986. Polycyclic aromatic hydrocarbons in surface sediments from the Elizabeth river subestuary. Int J Environ Anal Chem 26:97–113.
*Bingham E, Falk HL. 1969. Environmental carcinogens: The modifying effect of carcinogens on the threshold response. Arch Environ Health 19:779–783.4187174
*Bingham E, Horton AW, Tye R. 1965. The carcinogenic potency of certain oils. Arch Environ Health 10:449–451.14247342
*Bjorseth A, Olufsen BS. 1983. Long-range transfer of polycyclic aromatic hydrocarbons. In: Bjorseth A, ed. Handbook of PAH. New York, NY: M. Dekker, Inc., 507.
*Bjorseth A, Bjorseth 0, Fjedstad PE. 1978a. Polycyclic aromatic hydrocarbons in the work atmosphere: I. Determination. Stand J Work Environ Health 4:212–223.
Bjorseth A, Bjorseth 0, Fjedstad PE. 1978b. Polycyclic aromatic hydrocarbons in the work atmosphere: II. Determination in a coke plant. Stand J Work Environ Health 4:224–236.
Bjorseth A, Bjorseth 0, Fjedstad PE. 1981. Polycyclic aromatic hydrocarbons in the work atmosphere: Determination of area-specific concentrations and job-specific exposure in a vertical pin Soderberg aluminum plant. Stand J Environ Health 7:223–232.
*Bjelogrlic NM, Makinen M, Stenback F, . 1994. Benzo(a)pyrene-7,8-diol- 9,10-epoxide-DNA adducts and increased ~53 protein in mouse skin. Carcinogenesis 15(4):771–774.8149494
Black JJ, Dymerski PP, Zapisek WF. 1979. Routine liquid chromatographic method for assessing poly nuclear aromatic hydrocarbon pollution in fresh water environments. Bull Environ Contam Toxicol 22:278–284.465787
*Black WV, Kosson DS, Ahlert RC. 1989. Characterization and evaluation of environmental hazards in a large metropolitan landfill. In: Bell JM, ed. Proceedings of the Industrial Waste Conference. Chelsea, MI: Lewis Publishers, Inc. 147–152.
*Blackbum GM, Taussig PE. 1975. The photocarcinogenicity of anthracene: Photochemical binding to deoxyribonucleic acid in tissue culture. Biochem J 149:289–291.1191261
*Blanton RH, Myers MJ, Bick PH. 1988. Modulation of immunocompetent cell populations by benzo(a)pyrene. Toxicol Appl Pharmacol 93:267–274.3258678
*Blanton RJ, Lyte M, Myers MJ, . 1986. Immunomodulation by polyaromatic hydrocarbons in mice and murine cells. Can Res 46:2735–2739.
Bock FG, King DW. 1959. A study of the sensitivity of the mouse forestomach toward certain polycyclic hydrocarbons. J Natl Cancer Inst 23:833.13801881
*Bock FG, Mund R. 1958. A survey of compounds for activity in the suppression of mouse sebaceous glands. Cancer Res 18:887–892.13573359
*Bornpart G. 1990. In vivo effect of molybdenum on benzo(a)pyrene metabolism in liver and lung rat microsomes. J Toxicol Clin Exp 10(2):95–104.2388179
*Bornpart G, Claments S. 1990. In vitro and in vivo benzo(a)pyrene metabolism in rat liver and lung microsomes: effect of sodium selenite. J Toxicol Clin Exp 10(1):3–14.2163448
*Bornpart G, Puig P, Pipy B, . 1989. In vitro influence of molybdenum on benzo[a]pyrene metabolism in hepatic and pulmonary rat microsomes. J Toxicol Environ Health 26(4):459–468.2709440
*Bond JA, Harkema JR, Russell VI. 1988. Regional distribution of xenobiotic metabolizing enzymes in respiratory airways of dogs. Drug Metab Dispos 16:116–124.2894939
*Borden RC, Lee MD, Thomas JM, . 1989. In situ measurement and numerical simulation of oxygen limited biotransformation. Groundwater Monit Rev (winter):83–91.
*Borlakoglu JT, Scott A, Wolf CR, . 1993. Treatment of lactating rats with PCBs induces CYPlAl and enhances the formation of BP 7,8-dihydrodiol, the proximate carcinogen of benzo(a)pyrene. Int J Biochem 25(8):1209–1214.8405664
Bos RP, Prinsen WJ, Van Rooy JG, . 1987. Fluoranthene: A volatile mutagenic compound, present in creosote and coal tar. Mutat Res 187:119–125.3547111
Bos RP, Theuws JL, Jongeneelen FJ, . 1988. Mutagenicity of bi-, tri-, and tetracylcic aromatic hydrocarbons in the “taped-plate assay” and in the conventional salmonella mutagenicity assay. Mutat Res 204:203–206.3278211
*Bossert ID, Bartha R. 1986. Structure-biodegradability relationships of polycyclic aromatic hydrocarbons in soil. Bull Environ Contam Toxicol 37:490–495.3768542
Bottomly AC, Twort CC. 1934. The carcinogenicity of chrysene and oleic acid. Am J Cancer 21:781–786.
Boyland E. 1986. The metabolism of foreign compounds and the induction of cancer. Xenobiotica 16 899–913.3541399
Boyland E, Sims P. 1967. The carcinogenic activities in mice of compounds related to benz(a)anthracene. Int J Can 2:500–504.
Bozicevic Z, Cvitas T, Curie M, . 1987. Airborne polycyclic aromatic hydrocarbons in the city of Zagreb, Yugoslavia. Sci Total Environ 66:127–136.2446385
*Brandt HCA, Molyneux MKB. 1985. Sampling and analysis of bitumen fumes. Part 2: Field exposure measurements. 47–58.
*Brandys J, Lipniak M, Piekoszewski W. 1989. Determination of polycyclic aromatic hydrocarbons in rat tissue by HPLC. Chem Anal 34(3–6): 449–452.
Brauze D, Mikstacka R, Baer-Dubowska W. 1991. Formation and persistence of benzo[a]pyrene-DNA adducts in different tissues of C57BL/10 and DBA/2 mice. Carcinogenesis 12(9):1607–1611.1909937
Breuer GM. 1984. Solvents and techniques for the extraction of polynuclear aromatic hydrocarbons from filter samples of diesel exhaust. Anal Lett 17:1293–1306.
*Broman D, Naf C, Lundbergh I, . 1990. An in situ study on the distribution biotransformation and flux of polycyclic aromatic hydrocarbons (PAHs) in an aquatic food chain (seston Mytilus edulis L and Somateria mollissima L) from the Baltic: An ecotoxicological perspective. Environ Toxicol Chem 9(4):429–442.
*Bronstein AC, Currance PL. 1988. Emergency care for hazardous materials exposure. Washington, DC: The C.V. Mosby Company, 221–222.
*Brown RA, Weiss FT. 1978. Fate and effects of polynuclear aromatic hydrocarbons in the aquatic environment. Washington, D.C: American Petroleum Institute. Publication no. 4297.
Bruce WR, Heddle JA. 1979. The mutagenic activity of 61 agents as determined by the micronucleus, salmonella, and sperm abnormality assays. Can J Genet Cytol 21:319–334.393369
Bruchlos E, Dogra S, Pauly K, . 1989. Formation of micronuclei in mouse bone marrow by benzo(a)pyrene and benzo(a)pyrene metabolites, and the role of induction of xenobiotic-metabolizing enzymes. Mutagenesis 4:307.
*Brune H, Deutsch-Wenzel RP, Habs M, . 1981. Investigation of the tumorigenic response to benzo(a)pyrene in aqueous carreine solution applied orally to Sprague-Dawley rats. J Cancer Res Clin Oncol 102(2):153–157.7338532
*Brunnemann KD, Prokopczyk B, Hoffmann D, . 1986. Laboratory studies on oral cancer and smokeless tobacco. Banbury Report 23:197–213.
Bryant MF, Erexson GL, Kwanyuen P, . 1989. Sister chromatid exchange and micronucleus analysis in rat peripheral blood lymphocytes after in vivo exposure to benzo(a)pyrene. Environ Mol Mutagen 14(suppl 15):30.2659328
Bryant MF, Kwanyuen P, Atwater AL, . 1991. Cytogenetic effects of benzo-b-fluoranthene in Sprague-Dawley rat peripheral blood lymphocytes after in-vivo exposure. Environ Mol Mutagen Suppl 19:13–17.
*Buckley TJ, Lioy PJ. 1992. An examination of the time course from human dietary exposure to polycyclic aromatic hydrocarbons to urinary elimination of 1-hydroxypyrene. Br J Ind Med (England) 49(2):113–124.
*Buening MK, Levin W, Karle JM, . 1979a. Tumorigenicity of bay region epoxides and other derivatives of chrysene and phenanthrene in newborn mice. Cancer Res 39:5063–5068.498133
Buening MK, Levin W, Wood A, . 1979b. Tumorigenicity of the dihydrodiols of dibenz(a,h)anthracene on mouse skin and in newborn mice. Cancer Res 39:1310–1314.421214
*Bui QQ, Tran MB, West WL. 1986. A comparative study of the reproductive effects of methadone and benzo[a]pyrene in the pregnant and pseudopregnant rat. Toxicol 42:195–204.
*Bulay QM, Wattenberg LW. 1971. Carcinogenic effects of polycyclic hydrocarbon carcinogen administration to mice during pregnancy on the progeny. J Natl Cancer Inst 46:397–402.5115907
Buonicore AJ. 1979. Analyzing organics in air emissions. Environ Sci Technol 13:1340–1342.
*Burford MD, Hawthorne SB, Miller DJ. 1993. Extraction rates of spiked versus native PAHs from heterogeneous environmental samples using supercritical fluid extraction and sonication in methylene chloride. Anal Chem 65:1497–1505.
Burlinson B, Ashby J. 1988. Inactivity of benzo(a)pyrene in a weanling rat liver, unscheduled DNA synthesis assay. In: Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:389–390.
*Busbee DL, Norman JO, Ziprin RL. 1990. Comparative uptake, vascular transport and cellular internalization of aflatoxin B 1 and benzo(a)pyrene. Arch Toxicol 64(4):285–290.2117431
Busby WF, Goldman ME, Newbeme PM, . 1984. Tumorigenicity of fluoranthene in a newborn mouse lung adenoma bioassay. Carcinogenesis 5:1311–1316.6488452
Busby WF Jr, Stevens EK, Martin CN, . 1989. Comparative lung tumorigenicity of parent and mononitro-polynuclear aromatic hydrocarbons in the BLU:Ha newborn mouse assay. Toxicol Appl Pharmacol 99(3):555–563.2749740
*Bushby B, Femandes A, Wallace D, . 1993. Determination of trace organic micropollutants in atmospheric deposition. Sci Tot Environ 135:81–94.
*Butler JD, Crossley P. 1981. Reactivity of polycyclic aromatic hydrocarbons adsorbed on soot particles. Atmos Environ 15:91–94.
Butler HT, Coddens ME, Poole CF. 1984a. Qualitative identification of polycyclic aromatic hydrocarbons by high performance thin-layer chromatography and fluorescence scanning densitometry. J Chromatogr 290:113–126.
Butler JD, Butterworth V, Kellow C, . 1984b. Some observations on the polycyclic aromatic hydrocarbon (PAH) content of surface soils in urban areas. Sci Total Environ 38:75–85.
*Butler JP, Post GB, Lioy PJ, . 1993. Assessment of carcinogenic risk from personal exposure to benzo(a)pyrene in the total human environmental exposure study (THEES). J Air Waste Manag Assoc 43:970–977.
Byczkowski JZ, Gessner T. 1989. Effects of inhibition of NADPH:cytochrome P-450 reductase on benzo(a)pyrene metabolism in mouse liver microsomes. Grace Cancer Drug Center, Roswell Park Memorial Institute, New York State Department of Health, Buffalo, NY. Int J Biochem 21(5):525–529.2503403
*Calabrese E. 1978. Pollutants and high risk groups: The biological basis of increased human susceptibility to environmental and occupational pollutants. New York, NY: John Wiley and Sons.
*Callahan MA, Slimak MW, Gabel NW, . 1979. Water-related environmental fate of 129 priority pollutants volume II. Washington, DC: U.S. Environmental Protection Agency. EPA-440/4-79-029B.
*Carraway JW, Doyle JR. 1991. Innovative remedial action at a wood-treating Superfund site. Tappi J 74:113–118.
Carver JH, Machado ML, MacGregor JA. 1986. Application of modified salmonella/microsome prescreen to petroleum-derived complex mixtures and polynuclear aromatic hydrocarbons (PAHs). Mutat Res 174:247–253.3526138
Casto BC. 1973. Enhancement of adenovirus transformation by treatment of hamsters with ultraviolet irradiation, DNA base analogs, and dibenz(a,h)anthracene. Cancer Res 33:402–407.4688887
Casto BC, Pieczynski WJ, Dipaolo JA. 1973. Enhancement of adenovirus transformation be pretreatment of hamster cells with carcinogenic polycyclic hydrocarbons. Cancer Res 33:819–824.4121284
Casto BC, Janosko N, DiPaolo JA. 1977. Development of a focus assay model for transformation of hamster cells in vitro by chemical carcinogens. Cancer Res 37:3508–3515.908003
*Cavalieri EL, Mailander P, Pelfrene A. 1977. Carcinogenic activity of anthanthrene on mouse skin. Z Krebsforsch Klin 89:113–118.
*Cavalieri EL, Devanesan PD, Cremonesi P, . 1987. Radical cations of polycyclic aromatic hydrocarbons (PAHs) in the binding. Proceedings of the American Association for Cancer Research Annual Meeting 28:129.
Cavalieri EL, Devanesan PD, Rogan EG. 1988a. Radical cations in the horseradish peroxidase and prostaglandin H synthase mediated metabolism and binding of benzo[a]pyrene to deoxyribonucleic acid. Biochem Pharmacol 37:2183–2187.3132173
*Cavalieri EL, Rogan E, Cremonesi P, . 1988b. Tumorigenicity of 6-halogenated derivatives of benzo[a]pyrene in mouse skin and rat mammary gland. J Cancer Res Clin Oncol 114:10–15.3350835
Cavalieri EL, Rogan E, Sinha D. 1988c. Carcinogenicity of aromatic hydrocarbons directly applied to rat mammary gland. J Cancer Res Clin Oncol 114:3–9.3350839
*CavaIieri EL, Higginbotham S, Ramakrishna N VS, . 1991. Comparative dose-response tumorigenicity studies of dibenzo(a)pyrene versus 7,12-dimethylbenz(a)anthracene, benzo(a)pyrene and two dibenzo(a)pyrene dihydrodiols in mouse skin and rat mammary gland. Carcinogenesis 12(10):1939–1944.1934274
*CELDS. 1994. Computer-aided Environmental Legislative Data Systems. United States Army Corps of Engineers Environmental Technical Information systems, University of Illinois, Urbana, IL. September 1992.
*Cerniglia CE. 1993. Biodegradation of polycyclic aromatic hydrocarbons. Curr Opinion Biotechnol 4:331–338.
*Cemiglia CE, Gibson DT. 1979. Oxidation of benzo[a]pyrene by the filamentous fungus Cunninghamella elegans. J Biol Chem 254:12174–12180.500703
*Cemiglia CE, Heitkamp MA. 1989. Microbial degradation of polycyclic aromatic hydrocarbons in the aquatic environment. In: Varanasi U, ed. Metabolism of polycyclic aromatic hydrocarbons in the aquatic environment. Boca Raton, FL: CRC Press, 41–68.
*Cervello I, Lafuente A, Giralt M, . 1992. Enhanced glutathione S-transferase (GST) activity in pregnant rats treated with benzo(a)pyrene. Placenta (England) 13(3):273–280.
*Chae YH, Ho DK, Cassady JM, . 1992. Effects of synthetic and naturally occurring flavonoids on metabolic activation of benzo[a]pyrene in hamster embryo cell cultures. Chem Biol Interact (Ireland) 82(2):181–193.
*Chakradeo PP, Kayal JJ, Bhide SV. 1993. Effect of benzo(a)pyrene and methyl(acetoxymethyl)nitrosamine on thymidine uptake and induction of aryl hydrocarbon hydroxylase activity in human fetal oesophageal cells in culture. Cell Biol Int 17(7):671–676.8374598
*Chaloupka K, Harper N, Krishnan V, . 1993. Synergistic activity of polynuclear aromatic hydrocarbon mixtures as aryl hydrocarbon (Ah) receptor agonists. Chem-Bio Interact 89:141–158.
*Chang LH. 1943. The fecal excretion of polycyclic hydrocarbons following their administration to the rat. J Biol Chem 151:93–99.
*Chang RL, Levin W, Wood AW, 1981. Tumorigenicity of the diastereomeric bay-region benzo(e)pyrene 9,10-diol-11,12-epoxides in newborn mice. Cancer Res 41:915–918.7459878
*Cheung Y-L, Gray TJB, Ioannides C. 1993. Mutagenicity of chrysene, its methyl and benzo derivatives, and their interactions with cytochromes P-450 and the Ah-receptor; relevance to their carcinogenic potency. Toxicology 81:69–86.8396278
*Chipman JK, Bhave NA, Hirom PC, . 1982. Metabolism and excretion of benzo(a)pyrene in the rabbit. Xenobiotica 12:397–404.6291260
*Chou MW, Kong J, Chung K-T, . 1993. Effect of caloric restriction on the metabolic activation of xenobiotics. Mutat Res 295:223–235.7507559
*Christou M, Moore CJ, Gould MN, . 1987. Induction of mammary cytochromes P-450: An essential first step in the metabolism of 7,12-dimethylbenz[a]anthracene by rat mammary epithelial cells. Carcinogenesis 8:73–80.3100087
*Chu EW, Malmgren RA. 1965. An inhibitory effect of vitamin A on the induction of tumors in the forestomach and cervix in the Syrian hamster by carcinogenic polycyclic hydrocarbons. Cancer Res 25:884–895.5891010
*Chuang JC, Mack GA, Kuhlman MR, . 1991. Polycyclic aromatic hydrocarbons and their derivatives in indoor and outdoor air in an eight-home study. Atmos Environ Part B Urban Atmos 25(3):369–380.
Clive D, Johnson KO, Spector JFS, . 1979. Validation and characterization of the L5178Y/TK+/l- mouse lymphoma mutagen assay system. Mutat Res 59:61–108.372791
*Clonfero E, Jongeneelen F, Zordan M, . 1989. Biogical monitoring of human exposure to coal tar urinary mutagenicity assays and analytical determination of polycyclic aromatic hydrocarbon: Metabolites in urine. In: Vainio H, Sorsa M, McMichael J, eds. Complex mixtures, No. 104. Lyon, France: International Agency for Research on Cancer, 215–222.
*Clonfero E, Jongeneelen FJ, Zordan M, . 1990. Biological monitoring of human exposure to coal tar. Urinary mutagenicity assays and analytical determination of polycyclic aromatic hydrocarbon metabolites in urine. In: Vainio H, Sorsa M, McMichael AJ, eds. Complex mixtures and cancer risk. International Agency for Research on Cancer. Lyon, France: IARC Sci. Publ. No. 104, 215–222.
*CLPSD. 1988. Contract Laboratory Program Statistical Database. US Environmental Protection Agency, Contract Laboratory Program.
Coccioli F, Ronchetti M, . 1986. Determination of polycyclic aromatic hydrocarbons in natural waters by thin-layer chromatography and high-performance liquid chromatography. J Chromatogr 370:157–163.
Cohen GM. 1990. Pulmonary metabolism of foreign compounds its role in metabolic activation. Environ Health Perspect 85:31–42.2200668
*Cohen GM, Haws SM, Moore BP, . 1976. Benzo(a)pyren-3-yl hydrogen sulfate, a major ethyl acetate-extractable metabolite of B(a)P in human, hamster and rat lung cultures. Biochem Pharmacol 25:2561–2570.985577
*Cole RH, Frederick RE, Nealy RP, . 1984. Preliminary findings of the priority pollutant monitoring project of the nationwide urban runoff program journal. J Water Pollut Control Fed 56:898–908.
Collins JF, Brown JP, Dawson SV, . 1991. Risk assessment for benzo(a)pyrene. Regul Toxicol Pharmacol 13(2):170–184.1852928
Coombs MM, Dixon C, Kissonerghis A-M. 1976. Evaluation of the mutagenicity of compounds of known carcinogenicity, belonging to the benz(a)anthracene, chrysene, and cyclopenta(a)phenanthrene series, using Ames’ tests. Cancer Res 36:4525–2529.793712
*Coover MP, Sims RC. 1987. The effects of temperature on polycyclic aromatic hydrocarbon persistence. Haz Waste Haz Mat 4:69–82.
Cosma GN, Jamasbi R, Marchok AC. 1988. Growth inhibition and DNA damage induced by benzo[a]pyrene and formaldehyde in primary cultures of rat tracheal epithelial cells. Mutat Res Sep 201(1):161–168.
Cosma GN, Marchok AC. 1988. Benzo[a]pyrene- and formaldehyde-induced DNA damage and repair in rat tracheal epithelial cells. Toxicology 51(2–3):309–320.3176033
*Cottini GB, Mazzone GB. 1939. The effects of 3,4-benzpyrene on human skin. Am J Cancer 37:186–195.
*Creasia DA, Poggenburg JK, Nettesheim P. 1976. Elution of benzo(a)pyrene from carbon particles in the respiratory tract of mice. J Toxicol Environ Health 1:967–975 966324
Crespi CL, Liber HL, Behymer TD, . 1985. A human cell line sensitive to mutation by particle-borne chemicals. Mutat Res 157:71–75.4010699
*Csaba C, Inczefi-Gonda A. 1992. Benzpyrene exposure at 15 days of prenatal life reduces the binding capacity of thymic glucocorticoid receptors in adulthood. Gen Pharmacol 23(1):123–124.1592220
*Csaba G, Inczefi-Gonda A, Szeberenyi S. 1991. Lasting impact of a single benzpyrene treatment in pre-natal and growing age on the thymic glucocorticoid receptors of rats. Gen Pharmacol 22(5):815–818.1761186
*Gulp SJ, Beland FA. 1994. Comparison of DNA adduct formation in mice fed coal tar or benzo(a)pyrene. Carcinogenesis 15(2):247–252.8313515
*Dahl AR, Coslett DC, Bond JA, . 1985. Metabolism of benzo(a)pyrene on the nasal mucosa of Syrian hamsters: Comparison to by other extrahepatic tissues and possible role of nasally produced metabolites in carcinogenesis. J Natl Cancer Inst 75:135–139.3859686
*Dale MJ, Jones AC, Pollard JT, . 1993. Application of two-step laser mass spectrometry to the analysis of polynuclear aromatic hydrocarbons in contaminated soils. Environ Sci Technol 27:1693–1695.
*Danheiser SL, Liber HL, Thilly WG. 1989. Long-term low-dose benzo-alpha-pyrene-induced mutation in human lymphoblasts competent in xenobiotic metabolism. Mutat Res 210(1):143–148.2909866
*Daniel PM, Pratt OE, Prichard MML. 1967. Metabolism of labelled carcinogenic hydrocarbons in rats. Nature 215:1142–1146.4168737
*Dankers J, Groenenboom M, Scholtis LHA, . 1993. High-speed supercritical fluid extraction method for routine measurement of polycyclic aromatic hydrocarbons in environmental soils with dichloromethane as a static modifier. J Chromatogr 641:357–362.
*Dankovic DA, Wright CW, Zangar RC, . 1989. Complex mixture effects on the dermal absorption of benzo[a]pyrene and other polycyclic aromatic hydrocarbons from mouse skin. J Appl Toxicol 9(4):239–244.2778258
*Danz M, Brauer R. 1988. Carcinogenic and non-carcinogenic fluorene derivatives: Induction of thymocyte stimulating serum factors by 2-acetylaminofluorene (AAF) and their synergy with lymphocyte mitogens. Exp Pathol 34(4):217–221.3234511
*Danz M, Hartmann A, Otto M, . 1991. Hitherto unknown additive growth effects of fluorene and 2-acetylaminofluorene on bile duct epithelium and hepatocytes in rats. Arch Toxicol Suppl 14:71–74.1805764
*Darby FW, Willis AF, Winchester RV. 1986. Occupational health hazards from road construction and sealing work. Ann Occup Hyg 30(4):445–454.3813349
*Dasgupta PS, Lahiri T. 1992. Alteration of brain catecholamines during growth of benzo(a)pyrene induced murine fibrosarcoma. Neoplasma 39(3): 163–165.1528321
*Davidson GE, Dawson GWP. 1976. Chemically induced presumed somatic mutations in the mouse. Mutat Res 38:151–154.1272273
*Davidson GE, Dawson GWP. 1977. Induction of somatic mutations in mouse embryos by benzo[a]pyrene. Arch Toxicol 38:99–103.578718
Davis BR, Whitehead JK, Gill ME, . 1975. Response of rat lung to 3,4-benzpyrene administered by intratracheal instillation in infusine with or without carbon black. Br J Cancer 31:443–452.1156525
*Day BW, Skipper PL, Wishnok JS, . 1990. Identification of an in vivo chrysene diol epoxide adduct in human hemoglobin. Chem Res Toxicol 3(4):340–343.2133082
*De Bruin A. 1976. Metabolism of chemical carcinogens and their interactions with macromolecules. In: Biochemical toxicology of environmental agents. Amsterdam, Netherlands: Elsevier/North-Holland Biomedical Press, 230–231.
*De Flora S, D’Agostini F, Izzotti A, . 1991. Prevention by N-acetylcysteine of benzo[a]pyrene clastogenicity and DNA adducts in rats. Mutat Res 250(1–2):87–93.1944365
*de Vos RH, Van Dokkum W, Schouten A. 1990. Polycyclic aromatic hydrocarbons in Dutch total diet samples (1984-1986). Food Chem Toxicol 28(4):263–268.2358252
Dean BJ. 1981. Activity of 27 coded compounds in the RLl chromosome assay. In: Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1 570–579.
*Dean RG, Bynum G, Jacobson-Kram D, . 1983. Activation of polycyclic hydrocarbons in Reuber H4-II-E hepatoma cells. Mutat Res 111:419–427.6316133
Delclos KB, Heflich RH. 1992. Mutation induction and DNA adduct formation in Chinese hamster ovary cells treated with 6-nitrochrysene, 6-aminochrysene and their metabolites. Mutat Res 279(3):153–164.1377330
*DeLeon IR, Byrne CJ, Peuler EL, . 1986. Trace organic and heavy metal pollutants in the Mississippi River. Chemosphere 15:795–805.
*Demuth S, Casillas E, Wolfe DA, . 1993. Toxicity of saline and organic solvent extracts of sediments from Boston Harbor, Massachusetts and the Hudson River-Raritan Bay Estuary, New York using the Microtox bioassay. Arch Environ Contam Toxicol 25:377–386.
Den Hollander H, Van de Meent D, Van Noort P, . 1986. Wet deposition of polycyclic aromatic hydrocarbons in the Netherlands. Sci Total Environ 52:211–219.3738501
*Desiderie PG, Lepri L, Heimler D, . 1984. Concentration, separation and determination of hydrocarbons in sea water. J Chromatogr 284:167–178.
Desilets DJ, Kissinger PT, Lytle FE, . 1984. Determination of polycyclic aromatic hydrocarbons in biomass gasifier effluents with liquid chromatography-diode array spectroscopy. Environ Sci Technol 18:386–391.22280090
Deutsch-Wenzel RP, Bmne H, Grimmer G, . 1983. Experimental studies in rat lungs on the carcinogenicity and dose-response relationships of eight frequently occurring environmental polycyclic aromatic hydrocarbons. J Natl Cancer Inst 71:539–544.6577228
*Diamond L, Kruszewski F, Knowles BB, . 1980. Metabolic activation of B[a]P by a human hepatoma cell line. Carcinogenesis 1:871–875.11219860
*DiGiovanni J, Rymer J, Slaga TJ, . 1982. Anticarcinogenic and cocarcinogenic effects of benzo[e]pyrene and dibenz[u,c]anthracene on skin tumor initiation by polycyclic hydrocarbons. Carcinogenesis 3(4):371–375.6284398
DiPaolo JA, Casto BC. 1976. In vitro transformation--Interaction of chemical carcinogens with viruses and physical agents. Int Agency Res. Cancer Scientific Publications 12:415–432.
DiPaolo JA, Donovan JP, Nelson RL. 1969. Quantitative studies of in vitro transformation by chemical carcinogens. J Natl Cancer Inst 42:867–876.4182072
DiPaolo JA, Donovan JP, Nelson RL. 1971. Transformation of hamster cells in vitro by polycyclic hydrocarbons without cytotoxicity. Proc Natl Acad Sci (USA) 68:2958–2961.5289241
Dipple A, Bigger CAH. 1991. Mechanism of action of food-associated polycyclic aromatic hydrocarbon. Carcinogens. Mutat Res 259(3–4):263–276.2017212
*Doak SMA, Brown VKH, Hunt PF, . 1983. The carcinogenic potential of twelve refined mineral oils following long-term topical application. Br J Cancer 48:429–436.6615701
Dock L, Scheu G, Jemstrom B, . 1988. Benzo[a]pyrene metabolism and induction of enzyme-altered foci in regenerating rat liver. Chem Biol Interact 67(3–4):243–253.3142693
Dorman BH, Genta VM, Mass MJ, . 1981. Benzo(a)pyrene binding to DNA in organ cultures of human endometrium. Cancer Res 41:2718–2722.6265065
*DOT. 1990. Department of Transportation. Code of Federal Regulations. 49 CFR 172.101.
*DOT. 1991. Hazardous materials transport. Department of Transportation. Code of Federal Regulations. 49 CFR 171.2.
*Dufresne A, Lesage J, Perrault G. 1987. Evaluation of occupational exposure to mixed dusts and polycyclic aromatic hydrocarbons in silicon carbide plants. Am Ind Hyg Assoc J 48(2):160–166.3565270
*Dumont J, Larocque-Lazure F, Iorio C. 1993. An alternative isolation procedure for the subsequent determination of benzo(a)pyrene in total particulate matter of cigarette smoke. J Chromatogr Sci 31:371–374.
Duncan ME, Brookes P. 1972. Metabolism and macromolecular binding of dibenz(a,c)anthracene and dibenz(a,h)anthracene by mouse embryo cells in culture. Int J Cancer 9(2):349–352.5064938
Dunkel VC, Pienta R-J, Sivak A, . 1981. Comparative neoplastic transformation responses of Balb 3T3 cells, Syrian hamster embryo cells, and Rauscher mm-me leukemia virus-infected Fischer 344 rat embryo cells to chemical carcinogens. J Natl Cancer Inst 67:1303–1315.6947113
Dunkel VC, Zeiger E, Brusick D, . 1984. Reproducibility of microbial mutagenicity assays: 1. Tests with Salmonella typhimurium and Escherichia coli using a standardized protocol. Environ Mutagen 6: 1–251.
*Dynamac Corp. 1985. Industrial hygeine assessment of petroleum refinery turnaround activities. Washington, DC: American Petroleum Institute.
*Eadie BJ, Faust W, Gardner WS, . 1982. Polycyclic aromatic hydrocarbons in sediments and associated benthos in Lake Erie, USA. Chemosphere 11:185–102.
*Eadie BJ, Faust WR, Landrum PF, . 1983. Bioconcentrations of PAH by some benthic organisms of the Great Lakes. In: Cooke M, Dennis AJ, eds. Polynuclear aromatic hydrocarbons: Formation, metabolism and measurement. Columbus, OH: Battelle Press, 437–449.
*Edwards NT. 1983. Polycyclic aromatic hydrocarbons (PAHs) in the terrestrial environment - a review. J Environ Qual 12:427–441.
Edwards NT. 1989. Fate and effects of PAHs in the terrestrial environment: An overview. GRA&I Issue 21. Washington, DC: Department of Energy. Contract Number CONF-890692-5, Contract AC05-840R21400.
*Ehrlich GG, Goerlitz DF, Godsy EM, . 1982. Degradation of phenolic contaminants in ground water by anaerobic bacteria: St. Louis Park, MN. Ground Water 20:703–710.
Eiceman GA, Clement R, Karosek F. 1979. Analysis of fly ash from municipal incinerators for trace organic compounds. Anal Chem 51:2343.
*Eisenberg WC, Cunningham DLB. 1985. Analysis of polycyclic aromatic hydrocarbons in diesel emissions using high performance liquid chromatography: A methods development study. In: Cook M, Dennis AJ, eds. Polynuclear aromatic hydrocarbons: Mechanisms, methods and metabolism. Columbus, OH: Battelle Press, 379–393.
*Eisler R. 1983. Polycyclic aromatic hydrocarbon hazards to fish, wildlife, and invertebretes: a synoptic review. U.S. Fish and Wildlife Service, U.S. Department of the Interior. Biological report 85(1.11).
*Eisler R. 1987. Polycyclic aromatic hydrocarbon hazards to fish, wildlife, and invertebrates: A synoptic review. Laurel, MD: US Fish and Wildlife Service, Patuxent Wildlife Research Center.
*Elder JF, Dresler PV. 1988. Bioconcentration of polycyclic aromatic hydrocarbons in a nearshore estuarine environment near a Pensacola, Florida creosote contamination site. Environ Pollut 49(2):117–132.15092667
*Eldridge JE, Shanmugam K, Bobalek EG, . 1983. PAH Emissions from paving asphalt in laboratory simulation. In: Cooke M, Dennis AJ, eds. Polynuclear aromatic hydrocarbons. Columbus, OH: Battelle Press, 471–482.
*Elgjo K. 1968. Growth kinetics of the mouse epidermis after a single application of 3,4-benzpyrene, croton oil, or 1,2-benzpyrene. Acta Pathol Microbial Stand 73:183–190.
*Eller PM. 1984. NIOSH manual of analytical methods. Vol. 2. Cincinnati, OH: US Department of Health and Human Services, National Institute for Occupational Safety and Health, 5506/7–5506/9, 5515/6–5515/7.
*Ellis B, Harold P, Kronberg H. 1991. Bioremediation of a creosote contaminated site. Environ Technol 12:447–459.
Emura M, Mohr U, Riebe M, . 1987. Predispostion of cloned fetal hamster lung epithelial cells to transformation by a precarcinogen, benzo(a)pyrene, using growth hormone supplementation and collagengel substratum. Cancer Res 47:1155–1160.3802097
*Emura M, Richter-Reichhelm HB, Schneider P, . 1980. Sensitivity of Syrian golden hamster fetal lung cells to benzo(a)pyrene and other polycyclic hydrocarbons in vitro. Toxicology 17:149–155.7209996
*Environment Canada. 1991a. Toxic chemicals in the Great Lakes and associated effects: Vol. I. Contaminant levels and trends. Environment Canada, Department of Fisheries and Oceans, Health and Welfare Canada.
*Environment Canada. 1991b. Toxic chemicals in the Great Lakes and associated effects: Volume II. Effects. Environment Canada, Department of Fisheries and Oceans, Health and Welfare Canada.
*EPA. 1975. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.24.
*EPA. 1979a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.6.
*EPA. 1979b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 401.15.
*EPA. 1980a. Ambient water quality criteria document for polynuclear aromatic hydrocarbons. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office. EPA 440/5-8-069.
*EPA. 1980b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.33.
*EPA. 1981a. Engineering handbook for hazardous waste incineration. Washington DC: U.S. Environmental Protection Agency, Office of Solid Waste. EPA/SW-889.
*EPA. 1981b. Toxic pollutants/effluent standards. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 401.15.
*EPA. 1981c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261 App. VII.
*EPA. 1981d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 413.02.
*EPA. 1982a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 420.02.
*EPA. 1982b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 420.13.
*EPA. 1982c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 420.14.
*EPA. 1982d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 465.02.
*EPA. 1982e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 423.
*EPA. 1982f. Test methods. Methods for organic chemical analysis of municipal and industrial wastewater. U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory, Cincinnati, OH.
*EPA. 1983a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 271.l.
*EPA. 1983b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 122.
*EPA. 1983c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 433.11.
*EPA. 1983d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 467.02.
*EPA. 1983e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 468.02.
*EPA. 1984a. Health effects assessment for polynuclear aromatic hydrocarbons (PAH). Cincinnati, OH: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office. First Draft. ECAO-CIN-H013.
*EPA. 1984b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261 App. IX.
*EPA. 1984c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136.
*EPA. 1984d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 421.21.
*EPA. 1984e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 421.23.
*EPA. 1984f. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 421.24.
*EPA. 19848. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 421.26.
*EPA. 1985a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 464.11.
*EPA. 1985b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 464.21.
*EPA. 198%. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 464.3 1.
*EPA. 1985d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 464.41.
*EPA. 1985e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.50.
*EPA. 1986a. Test methods for evaluating solid waste. Volume 1B: Laboratory manual, physical/chemical methods. Washington, D.C.: US Environmental Protection Agency, Office of Solid Waste and Emergency Response. SW-846.
*EPA. 1986b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.10.
*EPA. 1986c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.12.
*EPA. 1986d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 403.
*EPA. 1987a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 246, Appendix XI.
EPA. 1987b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.
*EPA. 1987c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264 App. IX.
*EPA. 1987d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355.
*EPA. 1987e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.32.
*EPA. 1987f. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.40
*EPA. 19878. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 414.91.
*EPA. 1988a. Drinking water criteria document for polycyclic aromatic hydrocarbons (PAHs). Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. ECAO-CIN-D010
EPA. 1988b. Recommendations for and documentation of biological values for use in risk assessment. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office, EPA/600/6-87/008.
*EPA. 1988c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261 App. VIII.
*EPA. 1988d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.43.
*EPA. 1988e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65.
*EPA. 1988f. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 704.225.
*EPA. 1988g. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 716.120.
*EPA. 1988h. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 795.54.
*EPA. 1989a. Interim methods for development of inhalation reference doses. U.S. Environmental Protection Agency. EPA/600/8-90/066F.
EPA. 1989b. Health and environmental effects profile for benzo(g,h,i)perylene. Cincinnati, OH: Environmental Protection Agency, Environmental Criteria and Assessment Office. Contract Number EPA-600-X-87-395.
*EPA. 1989c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
*EPA. 1989d. Designation, reportable quantities, and notification. U.S. Environmental Protection Agency. Code of federal regulations. 40 CFR 302.4
EPA. 1990. Interim methods for development of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency. EPA/600/8-90/066A.
EPA. 1991a. Ambient water quality criteria document: Addendum for acenaphthene. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. Contract Number ECAO-CIN-6 13.
*EPA. 1991b. EPA toxic pollutant effluent standards. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 129.
*EPA. 1991c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 258.
*EPA. 1991d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 265 App. VII.
*EPA. 1991e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.61.
*EPA. 1992a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 721.3764.
*EPA. 1992b. U.S. Environmental Protection Agency. Federal Register. 57 FR 60848.
*EPA. 1993a. Provisional guidance for quantitative risk assessment of polycyclic aromatic hydrocarbons. Environmental Criteria and Assessment Office. Cincinnati, OH. Final Draft. ECAO-CIN-842. March 1993.
*EPA. 1993b. U.S. Environmental Protection Agency. Federal Register. 58 FR 48092.
*EPA. 1993c. U.S. Environmental Protection Agency. Federal Register. 58 FR 54702.
*EPA. 1993d. U.S. Environmental Protection Agency. Federal Register. 58 FR 65622.
*EPA. 1993e. U.S. Environmental Protection Agency. Federal Register. 58 FR 36872.
*EPA. 1994a. U.S. Environmental Protection Agency. Federal Register. 59 FR 15504
*EPA. 1994b. U.S. Environmental Protection Agency. Federal Register. 59 FR 9808.
*EPA. 1994c. U.S. Environmental Protection Agency. Federal Register. 59 FR 1788.
Epstein S. 1968. Chemical mutagens in the human environment. Nature 219:365.
*Estensen RD, Wattenberg LW. 1993. Studies of chemopreventative effects of myo-inositol on benzo[a]pyrene-induced neoplasia of the lung and forestomach of female A/J mice. Carcinogenesis 14(9):1975–1977.8403228
*Evans WH, Thomas NC, Boardman MC, . 1993. Relationships of polycyclic aromatic hydrocarbon yields with particulate matter (water and nicotine free) yields in mainstream and sidestream cigerette smoke. Sci Tot Environ 136:101–109.
Fahmy M, Fahmy OG. 1980. Altered control of gene activity in the soma by carcinogens. Mutat Res 72:165–172.6255324
*Faiderbe S, Chagnaud JL, Geffard M. 1992. Identification and characterization of a specific autoantiphosphatidylinositol immune response during the time course of benzo(a)pyrene-induced malignant tumors in female Sprague-Dawley rats. Cancer Res 52(10):2862–2865.1581900
*Falk HL, Kotin PTS. 1964. Inhibition of carcinogenesis: The effects of polycyclic hydrocarbons and related compounds. Arch Environ Health 9:169–179.14155051
Falkson G, Klein B, Falkson H. 1985. Hematological toxicity: Experience with anthracyclines and anthracenes. Exp Hematol 13:64–71.3857185
*Faoro RB, Manning JA. 1981. Trends in benzo[a]pyrene, 1966-77. J Air Pollut Control Assoc 31:62–64.
*Faulds AJ, Waszczylo Z, Westaway KC. 1981. Polynuclear aromatic hydrocarbons in the underground mine environment. CIM Bull 74:84–90.
Feron VJ. 1972. Respiratory tract tumors in hamsters after intratracheal instillations of benzo[a]pyrene alone and with furfural. Cancer Res 32:28–36.5007686
Feron VJ. 1973. Dose-response correlation for the induction of respiratory-tract tumors in Syrian golden hamsters by intratracheal instillations of benzo[a]pyrene. Eur J Cancer 9:387.
Feron VJ, Kruysse A. 1978. Effects of exposure to furfural vapor in hamsters simultaneously treated with benzo[a]pyrene and diethylnitrosamine. Toxicology 11:127–144.715798
Ferrario JB, DeLeon H, Tracy R. 1985. Evidence for toxic anthropogenic chemicals in human thrombogenic coronary plaques body burdens. Arch Environ Contam Toxicol 14:529–534.4051565
Fielden PR, Packham AJ. 1989. Selective determination of benzo(a)pyrene in petroleum-based products using multi-column liquid chromatography. J Chromatogr 479(1): 117–124.
Finch MA. 1990. What is FT Raman spectroscopy and where can I use it? Spectroscopy (Eugene Oreg) 5(6):12, 14–16.
*Fiume M, Guaitani A, Modica R, . 1983. Effect of fasting, induction, sex and age on clearance of benz(a)anthracene and chrysene by isolated perfused rat liver. Toxicol Lett 19:73–79.6689224
*Forbes PD, Davies RE, Urbach F. 1976. Phototoxicity and photocarcinogenesis: Comparative effects of anthracene and 8-methoxypsoralen in the skin of mice. Food Cosmet Toxicol 14:303–306.985601
*Foreman WT, Bidleman TF. 1990. Semivolatile organic compounds in the ambient air of Denver Colorado. Atmos Environ 24(9):2405–2416.
*Foth H, Kahl R, Kahl GF. 1988a. Pharmacokinetics of low doses of benzo[a]pyrene in the rat. Food Chem Toxicol 26(1):45–51.3345969
*Foth H, Rude11 U, Ritter G, . 1988b. Inhibitory effect of nicotine on benzo(a)pyrene elimination and marked pulmonary metabolism of nicotine in isolated perfused rat lung. Klin Wochenschr 66(Suppl 11):98–104.3184783
*Foumier J, Pezerat H. 1986. Studies on surface properties of asbestos: III. Interactions between asbestos and polynuclear aromatic hydrocarbons. Environ Res 41:276–295.3019660
*Fox MA, Staley SW. 1976. Determination of polycyclic aromatic hydrocarons in atmospheric particulate matter by high pressure liquid chromatography coupled with flourescene techniques. Anal Chem 48:992–998.1267175
*Franklin Associates. 1984. Composition and management of used oil generated in the United States. Washington, D.C.: US Environmental Protection Agency. NTIS PB 85-180-297.
*Fraumeni JR, ed. 1975. Persons at high risk of cancer: An approach to cancer etiology and control. New York, NY: Academic Press, Inc., 172, 187–189.
*Freeman DJ, Cattell CR. 1990. Woodburning as a source of atmospheric polycyclic aromatic hydrocarbons. Environ Sci Technol 24(10):1581–1585.
FSTRAC. 1988. Summary of state and federal drinking water standards and guidelines. Chemical Communication Subcommittee, Federal-State Toxicology and Regulatory Alliance Committee, Washington, D.C. March, 1988.
FSTRAC. 1990. Summary of state and federal drinking water standards and guidelines. Chemical Communication Subcommittee, Federal-State Toxicology and Regulatory Alliance Committee, Washington, D.C. February 1990.
*Fuchs J, Mlcoch J, Platt K-L, . 1993a. Characterization of highly polar bis-dihydrodiol epoxide-DNA adducts formed after metabolic activation of dibenz[a,h]anthracene. Carcinogenesis 14(5):863–867.8504478
*Fuchs J, Mlcoch J, Oesch F, . 1993b. Characterization of highly polar DNA adducts derived from dibenz[a,h]anthracene (DBA), 3,4-dihydroxy-3,4-dihydro-DBA, and 3,4,10,11-tetrahydroxy-3,4,10,11-tetrahydro-DBA. Toxicol Ind Health 9(3):503–509.8367889
*Furman GM, Silverman DM, Schatz RA. 1991. The effect of toluene on rat lung benzo[a]pyrene metabolism and microsomal membrane lipids. Toxicology 68(1):75–87.1871778
*Furuta N, Otsuki A. 1983. Time-resolved fluorometry in detection of ultratrace polycyclic aromatic hydrocarbons in lake waters by liquid chromatography. Anal Chem 55:2407–2413.
*Futagaki SK. 1983. Petroleum refinery workers exposure to PAHs at fluid catalytic cracker, coker, and asphalt processing units. Cincinnati, OH: National Institute for Occupational Safety and Health, NIOSH publ. no. 83-111.
*Futoma DJ, Smith SR, Tanaka J, . 1981. Chromatographic methods for the analysis of polycyclic aromatic hydrocarbons in water systems. Crit Rev Anal Chem 12:69–153.
*Gallagher J, George M, Kohan M, . 1993. Detection and comparison of DNA adducts after in vitro and in vivo diesel emission exposures. Environl Health Perspect 99:225–228.
Galle B, Grennfelt P. 1983. Instrument for polycyclic aromatic hydrocarbon analysis of airborne particules by capillary gas chromatography with laser induced fluorescence detection. J Chromatogr 279:643–648.
*Gao N, Aidoo A, Heflich RH. 1991. Analysis of rat lymphocyte activation of benzo[a]pyrene, 2-acetylaminofluorene, and several of their metabolites to mutagenic and DNA-damaging species in vitro. Teratogen Carcinog Mutagen 11(2):65–76.
*Gardner WS, Lee RF, Tenore KR, . 1979. Degradation of selected polycyclic aromatic hydrocarbons in coastal sediments: Importance of microbes and polychaete worms. Water Air Soil Pollut 11:339–348.
*Garg A, Beach AC, Gupta RC. 1993. Interception of Reactive, DNA aduct-forming metabolites present in rodent serum following carcinogen exposure: Implications for use of body fluids in biomonitoring. Teratogen Carcinog Mutagen 13:151–166.
*Garman JR, Freund T, Lawiess EW. 1987. Testing for groundwater contamination at hazardous waste sites. J Chromatogr Sci 25:328–337.
*Gamer RC, Dvorackova I, Tursi F. 1988. Immunoassay procedures to detect exposure to aflatoxin B-l and benzo-a-pyrene in animals and man at the DNA level. Int Arch Occup Environ Health 60(3):145–150.2838425
*Garrigues P, Ewald M. 1987. High resolution emission spectroscopy (Shpol’skii effect): A new analytical technique for the analysis of polycyclic aromatic hydrocarbons (PAH) in environmental samples. Chemosphere 16:485–494.
*Gay ML Belisle AA, Patton JF. 1980. Quantification of petroleum-type hydrocarbons in avian tissue. J Chromatogr 187:153–160.7358812
Generoso WM, Cain KT, Hellwig CS, . 1982. Lack of association between induction of dominant-lethal mutations and induction of heritable translocations with benzo[a]pyrene in postmeiotic germ cells of male mice. Mutat Res 94: 155–163.6285187
*Gensler HL. 1988. Enhancement of chemical carcinogenesis in mice by systemic effects of ultraviolet irradiation. Cancer Res 48:620–623.3335024
Georgellis A, Parvinen M, Rydstrom J. 1989. Inhibition of stage-specific DNA synthesis in rat spermatogenic cells by polycyclic aromatic hydrocarbons. Chem Biol Interact 72(1–2):79–92.2510950
Georgellis A, Toppari J, Veromaa T, . 1990. Inhibition of meiotic divisions of rat spermatocytes in vitro by polycyclic aromatic hydrocarbons. Mutat Res 231(2): 125–136.2117249
*Gerde P, Medinsky MA, Bond JA. 1991. The retention of polycyclic aromatic hydrocarbons in the bronchial airways and in the alveolar region: A theoretical comparison. Toxicol Appl Pharmacol 107(2):239–252.1994509
*Gerde P, Muggenburg BA, Hoover MD, . 1993a. Disposition of polycyclic aromatic hydrocardons in the respiratory tract of the beagle dog. I. The aveolar region. Toxicol Appl Pharmacol. 121:313–318.8346548
*Gerde P, Muggenburg BA, Sabourin PJ, . 1993b. Disposition of polycyclic aromatic hydrocarbons in the respiratory tract of the beagle dog. II. The conducting airways. Toxicol Appl Pharmacol. 121:319–327.8346549
*Gerde P, Scholander P. 1989. An experimental study of the penetration of polycyclic aromatic hydrocarbons through a model of the bronchial lining layer. Environ Res 48(2):287–295.2924757
*Gershbein LL. 1975. Liver regeneration as influenced by the structure of aromatic and heterocyclic compounds. Res Commun Chem Pathol Pharrnacol 11:445–466.
*Ghaisas SD, Bhide SV. 1994. In vitro studies on chemoprotective effects of pumark against benzo(a)pyrene-induced chromosomal damage in human lymphocytes. Cell Biol Int 18:(1)21–23.8186767
*Gibson TL, Smart VB, Smith LL. 1978. Non-enzymatic activation of polycyclic aromatic hydrocarbons as mutagens. Mutat Res 49:153–161.342930
*Giger W, Blumer M. 1974. Polycyclic aromatic hydrocarbons in the environment: Isolation and characterization by chromatography visible, ultraviolet, and mass spectrometry. Anal Chem 46:1163.
*Giger W, Schaffner C. 1978. Determination of polycyclic aromatic hydrocarbons in the environment by glass,capillary gas chromatography. Anal Chem 50:243–249.
*Gile JD, Collins JC, Gillet JW. 1982. Fate and impact of wood preservatives in a terrestrial microcosm. J Agric Food Chem 30:295–301.
*Ginsberg GL, Atherholt TB. 1989. Transport of DNA-adducting metabolites in mouse serum following benzo[a]pyrene administration. Carcinogenesis 10(4):673–679.2702715
*Ginsberg GL, Atherholt TB, Butler GH. 1989. Benzo[a]pyrene-induced immunotoxicity: Comparison to DNA adduct formation in vivo, in cultured splenocytes, and in microsomal systems. J Toxicol Environ Health 28(2):205–220.2795702
Glatt H, Bucker M, Platt KL, . 1985. Host-mediated mutagenicity experiments with benzo[a]pyrene and two of its metabolites. Mutat Res 156:163–169.3889634
Glatt H, Seidel A, Ribeiro O, . 1987. Metabolic activation to a mutagen of 3-hydroxy-tram-7,8-dihydroxy-7,8- dihydrobenzo(a)pyrene, a secondary metabolite of benzo(a)pyrene. Carcinogenesis 8:1621–1627.3311446
*Glatt H, Wameling C, Elsberg S, . 1993. Genotoxicity characteristics of reverse diol-epoxides of chrysene. Carcinogenesis 14(1):11–19.8425257
*Goates SR, Sin CH, Simons JK, . 1989. Supercritical-fluid chromatography - supersonic-jet spectroscopy: Part II. Capillary-column SFC with a sheath-flow nozzle. Microcolumn Sep 1(4):207–211.
*Golden C, Sawicki E. 1978. Determination of benzo(a)pyrene and other polynuclear aromatic hydrocarbons in airborne paritculates material by ultrasonic extraction and reverse phase pressure liquid chromatography. Anal Lett 11: 1051–1062.
*Goldstein LS, Safe S, Weyand EH. 1994. Carcinogenicity of coal tars: A multidisciplinary approach. Polycyclic Aromatic Compounds 7:161–174.
*Gomaa EA, Gray IJ, Rabie S, . 1993. Polycyclic aromatic hydrocarbons in smoked food products and commerical liquid smoke flavourings. Food Addit Contam 10(5):503–521.8224319
*Games M, Santella RM. 1990. Immunologic methods for the detection of benzo[a]pyrene metabolites in urine. Chem Res Toxicol 3(4):307–310.2133077
Gonzalez BL, Rejthar L. 1986. Quantitative determination of trace concentration of organics in water by solvent extraction and fused silica capillary gas chromatography: aliphatic and polynuclear hydrocarbons. Int J Environ Anal Chem 24:305–318.3710683
*Gordon RJ. 1976. Distribution of airborne polycyclic aromatic hydrocarbons throughout Los Angeles. Env Sci Tech 10:370–373.
*Gorelick NJ, Reeder NL. 1993. Detection of multiple polycyclic aromatic hydrocarbon-DNA adducts by a high-performance liquid chromatography-^32^P-postlabeling method. Environ Health Perspect 99:207–211.8319625
*Gorelick NJ, Wogan GN. 1989. Fluoranthene - DNA adducts: identification and quantification by an HPLC - phosphorus-32 post-labelling method. Carcinogenesis 10(9):1567–1577.2670301
Govindwar SP, Kachole MS, Pawar SS. 1988. Effect of caffeine on the hepatic microsomal mixed function oxidase system during phenobarbital and benzo[a]pyrene treatment in rats. Toxicol Lett 42(2):109–115.3406955
*Granella M, Clonfero E. 1993. Urinary excretion of 1-pyrenol in automotive repair workers. Int Arch Occup Environ Health 65: 241–245.8144234
Grant GA, Roe FJC. 1963. The effect of phenanthrene on tumor induction by 3,4-benzpyrene administered to newly born mice. Br J Cancer 17:261–265.14042727
*Grayson M, ed. 1978. Kirk-Othmer encyclopedia of chemical technology. Vol. 21. New York, NY: John Wiley and Sons.
*Greb W, Strobe1 R, Roehrborn G. 1980. Transformation of BHK 21/CL 13 cells by various polycyclic aromatic hydrocarbons using the method of styles. Toxicol Lett (Amst) 7:143–148.
*Greenberg A, Darack F, Harkov R, . 1985. Polycyclic aromatic hydrocarbons in New Jersey (USA): A comparison of winter and summer concentrations over a two-year period. Atmos Environ 19:1325–1340.
*Greife AL, Warshawsky D. 1993. Influence of the dose levels of cocarcinogen ferric oxide onthe metabolism of benzo(a)pyrene by pulmonary alveolar macrophages in suspension culture. J Toxicol Environ Health 38:399–417.8386775
*Grimmer G, Brune H, Dettbarn G, . 1988. Urinary and faecal excretion of chrysene and chrysene metabolites by rats after oral, intraperitoneal, intratracheal or intrapulmonary application. Arch Toxicol 62(6):401–405.3250370
Grimmer G, Jacob J, Schmoldt A, . 1985. Metabolism of benz(a)anthracene in hamster lung cells in culture in comparison to rat liver microsomes. In: Cooke M, Dennis AJ, eds. Polynuclear aromatic hydrocarbons: Mechanisms, methods and metabolism. Columbus, OH: Battelle Press, 521–532.
*Grimmer G, Naujack KW, Dettbam G. 1987. Gas chromatographic determination of polycyclic aromatic hydrocarbons azarenes aromatic amines in the particle and vapor phase of mainstream and sidestream smoke of cigarettes. Toxicol Lett (AMST) 35(1): 117–124.
*Grimmer G, Dettbarn G, Jacob J. 1993. Biomonitoring of polycyclic aromatic hydrocarbons in highly exposed coke plant workers by measurement of urinary phenanthrene and pyrene metabolites (phenols and dihydrodiols). Int Arch Occup Environ Health 65(3):189–199.8282417
*Grimmer G, Dettbam, G, Naujack KW, . 1994. Relationship between inhaled PAH and urinary excretion of phenanthrene, pyrene and benzo(a)pyrene metabolites in coke plant workers. Polycyclic Aromatic Compounds 5:269–277.
Grolier P, Cassand P, Antignac E, . 1989. Effects of prototypic PCBs on benzo-alpha-pyrene mutagenic activity related to vitamin A intake. Mutat Res 211(1)139–146.2493575
*Grosjean D. 1983. Polycyclic aromatic hydrocarbons in Los Angeles air from samples collected teflon glass and quatz filters. Atmos Environ 17(12):2565–2573.
Grover PL, Sims P, Huberman E, . 1971. In vitro transformation of rodent cells by K-region derivatives of polycyclic hydrocarbons. Proc Nat Acad Sci USA 68:1098–1101.4108174
*Grover PL, Sims P, Mitchley BCU, . 1975. The carcinogenicity of polycyclic hydrocarbon epoxides in newborn mice. Br J Cancer 31:182–188.1164468
*Guerin MR. 1978. Energy sources of polycyclic aromatic hydrocarbons. In: Gelboin HV, Ts’o POP, eds. Polycyclic hydrocarbons and cancer. Vol. 1. New York, NY: Academic Press, 3–55.
*Guillemin MP, Herrera H, Huynh CK, . 1992. Occupational exposure of truck drivers to dust and polynuclear aromatic hydrocarbons: a pilot study in geneva, Switzerland. Int Arch Occup Environ Health. 63: 439–447.1374365
*Gunnison AF, Sellakumar A, Snyder EA, . 1988. The effect of inhaled sulfur dioxide and systemic sulfite on the induction of lung carcinoma in rats by benzo[a]pyrene. Environ Res 46(1):59–73.3371292
Gupta RS, Goldstein S. 1981. Mutagen testing in the human fibroblast diphtheria toxin resistance (HF Dipr) system. Prog Mutat Res 1:614–625.
Gupta RS, Singh B. 1982. Mutagenic responses of five independent genetic loci in CHO cells to a variety of mutagens: Development and characteristics of a mutagen screening system based on selection for multiple drug-resistant markers. Mutat Res 94:449–466.7110183
*Gupta MP, Khanduja KL, Sharma RR. 1987. Effect of cigarette smoke inhalation on (^3^H)benzo(a)pyrene binding to lung DNA of vitamine A-deficient rats. Med Sci Res 15:1323–1324.
Gupta PH, Mehta S, Mehta SK. 1989. Effects of dietary benzo(a)pyrene on intestinal phase I and phase II dmg metabolizing systems in normal and vitamin A-deficient rats. Biochem Int 19(4):709–722.2619743
*Gupta MP, Khanduja KL, Koul IB, . 1990. Effect of cigarette smoke inhalation on benzo[a]pyrene-induced lung carcinogenesis in vitamin A deficiency in the rat. Cancer Lett 55(2):83–88.2265418
*Gupta P, Banerjee DK, Bhargava SK, . 1993. Prevalence of impared lung function in rubber manufacturing factory workers exposed to benzo(a)pyrene and respirable particulate matter. Indoor Environ 2:26–31.
Gurka DF, Pyle SM. 1988. Qualitative and quantitative environmental anaylysis by capillary column gas chromatography/lightpipe Fourier-transforms infrared spectrometry. Environ Sci Technol 22:963–967.22195720
Gurka DF, Titus R, Giffiths PR, . 1987. Evaluation of an improved single-beam gas chromatography/Fourier transform infrared interface for environmental analysis. Anal Chem 59:2362–2369.3674448
*Guyda HJ. 1991. Metabolic effects of growth factors and polycyclic aromatic hydrocarbons on cultured human placental cells of early and late gestation. J Clin Endocrinol Metab 72(3):718–723.1997525
*Guyda HJ, Mathieu L, Lai W, . 1990. Benzo(a)pyrene inhibits epidermal growth factor binding and receptor autophosphorylation in human placental cell cultures. Mol Pharmacol 37(2):137–143.2154666
Ha M, Grover PL. 1988. Stereoselective aspects of the metabolic activation of benzo[a]pyrene by human skin in vitro. Chem Biol Interact 64(3):281–296.3342454
Haas JWI, Buchanan MV, Wise MB. 1988. Differentiation of polycyclic aromatic hydrocarbons using a multimode ionization gas chromatographic detector. J Chromatogr Sci 26:49–54.
*Habs M, Jahn SA, Schmahi D. 1984. Carcinogenic activity of condensate from coloquint seeds (Citrullus colocynthis) after chronic epicutaneous administration to mice. J Cancer Res Clin Oncol 108:154–156.6746706
*Habs M, Schmahl D, Misfeld J. 1980. Local carcinogenicity of some environmentally relevant polycyclic aromatic hydrocarbons after lifelong topical application to mouse skin. Arch Geschwulstforsch 50:266–274.7436704
*Hahon N, Booth JA. 1986. Coinhibition of viral interferon induction by benzo[a]pyrene and chrysotile asbestos. Environ Res 40(1): 103–109.2423322
*Hahon N, Booth JA. 1988. Benzo[a]pyrene: Kinetics of in vitro bioactivation in relation to inhibition of viral interferon induction. J Interferon Res 8(2):151–167.2837519
*Halbrook RS, Kirkpatrick RL, Bevan DR. 1992. DNA adducts detected in muskrats by ^32^P-postlabeling analysis. Envion Toxicol Chem 11:1605–1613.
*Hall M, Grover PL. 1987. Differential stereoselectivity in the metabolism of benzo(a)pyrene and anthracene by rabbit epidermal and hepatic microsomes. Cancer Lett 38:57–64.3690515
*Hall LW Jr., Ziegenfuss MC, Fischer SA. 1993. The influence of contaminant and water quality conditions on larval striped bass in the Potomac river and Upper Chesapeake Bay in 1990. Arch Environ Contam Toxicol 24(1):1–10.
Hall M, Parker DK, Grover PL, . 1990. Effects of 1-ethynylpyrene and related inhibitors of P450 isozymes upon benzo[a]pyrene metabolism by liver microsomes. Chem Biol Interact 76(2):181–192.2225228
*Hammond ED, Selikoff IJ, Lawther PO, . 1976. Inhalation of B[a]P and cancer in man. Ann NY Acad Sci 271:116–124.1069493
*Hampel CA, Hawley GG, eds. 1973. The encyclopedia of chemistry. Third edition. New York, NY: Van Nostrand Reinhold Company.
*Hansen AM, Poulsen OM, Menne T. 1993. Longitudinal study of excretion of Metabolies of Polycyclic Aromatic Hydrocarbons in Urine from two Psoriatic Patients. Acta Derm Venereol (stockh) 73:188–190.8105615
*Harper BL, Ramanujam VMS, Legator MS. 1989. Micronucleus formation by benzene, cyclophosphamide, benzo(a)pyrene, and benzidine in male, female, pregnant female, and fetal mice. Teratogen Carcinogen Mutagen 9(4):239–252.
Harris CC, Autrup H, eds. 1983. Human carcinogenesis. New York, NY: Academic Press.
*Harris CC, Spom MB, Kaufman DG, . 1971. Acute ultrastmctural effects of benzo(a)pyrene and ferric oxide on the hamster tracheobronchial epithelium. Cancer Res 31: 1977–1981.5120295
*Harris CC, Autrup H, Stoner GD, . 1979. Metabolism of B[a]P, N-nitrosodimethylamine, and N-nitrosopyrrolidine and identification of the major carcinogen-DNA adducts formed in cultured human esophagus. Cancer Res 39:4401–4406.498072
Harris CC, Grafstom RC, Shamsuddin AM, . 1984. Carcinogen metabolism and carcinogenic DNA adducts in human tissues and cells. In: Marquardt H, Oesch F, eds. Biochemical basis of chemical carcinogenesis. New York, NY: Raven Press, 123–135.
*Harris J, Perwak J, Coons S. 1985. Exposure and risk assessment for benzo(a)pyrene and other polycyclic aromatic hydrocarbons. Volume 1. Summary:123–135.
*Harrison RM, Perry R, Wellings RA. 1976a. Chemical kinetics of chlorination of some polynuclear aromatic hydrocarbons under conditions of water treatment processes. Environ Sci Technol 10:1156–1160.22175682
*Harrison RM, Perry R, Wellings RA. 1976b. Effect of water chlorination upon levels of some polynuclear aromatic hydrocarbons in water. Environ Sci Technol 10:1151–1156.22175681
Hartwell JL, ed. 1951. Survey of compounds which have been tested for carcinogenic activity. Public Health Series Publication No 149.
*Harvath PV. 1983. Quantitative analysis of multiple polycyclic aromatic hydrocarbons in the coal conversion atmosphere. Am Ind Hyg Assoc J 44:739–745.6650395
Hass BS, Brooks EE, Schumann KE, . 1981. Synergistic, additive, and antagonistic mutagenic responses to binary mixtures of benzo(a)pyrene and benzo(e)pyrene as detected by strains TA98 and TA10 in the Salmonella/microsome assay. Environ Mutagen 3(2):159–166.6263605
Haugen DA, Zegar IS. 1990. Formation of hemoglobin-benzo[a]pyrene adducts in human erythrocytes incubated with benzo[a]pyrene and hamster embryo cells. Toxicology 65(1–2):109–122.2274962
*Haugen A, Becher G, Benestad C, . 1986. Determination of polycyclic aromatic hydrocarbons in the urine, benzo(a)pyrene diol epoxide-DNA adducts in lymphocyte DNA, and antibodies to the adducts in sera from coke oven workers exposed to measured amount of polycyclic aromatic hydrocarbons in the work atmosphere. Cancer Res 46:4178–4183.3731085
*Hawley GG. 1987. The condensed chemical dictionary. New York, NY: Van Nostrand Reinhold Company.
*Hawley GG. 1993. The condensed chemical dictionary. New York, NY: Van Nostrand Reinhold Company.
*Hawthorne SB, Miller DJ. 1987a. Directly coupled supercritical fluid extraction-gas chromatographic analysis of polycyclic aromatic hydrocarbons and polychlorinated biphenyls environmental from solids. J Chromatogr 403:63–76.3119644
*Hawthorne SB, Miller DJ. 1987b. Extraction and recovery of polycyclic aromatic hydrocarbons from environmental solids using supercritical fluids. Anal Chem 59: 1705–1708.3662010
*Hawthorne SB, Miller DJ, Burford MD. . 1993. Factors controlling quantitative supercritical fluid extraction of environmental samples. J Chromatogr 642:301–317.
*HazDat. 1993. Database. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
*HazDat. 1994. Database. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
*He SL, Baker R. 1991. Micronuclei in mouse skin cells following in vivo exposure to benzo[a]pyrene, 7,12-dimethylbenz[a]anthracene, chrysene, pyrene and urethane. Environ Mol Mutagen 17(3):163–168.1902414
Hecht SS, Bondinell WE, Hoffman D. 1974. Chrysene and methylchrysenes: Presence on tobacco smoke and carcinogenicity. J Natl Cancer Inst 53:1121–1133.4427391
*Hecht SS, Grabowski W, Groth K. 1979. Analysis of faeces for B[a]P after consumption of charcoal-broiled beef by rats and humans. Food Cosmet Toxicol 17:223–227.499948
*Hecht SS, La Voie E, Amin S, . 1980. On the metabolic activation of the benzofluoranthenes. In: Polynuclear aromatic hydrocarbons: Chemistry and biological effects. 4th National Symposium 1980. 417–433.
Heinrich U, Pott F, Mohr U, . 1986. Lung tumors in rats and mice after inhalation of PAH-rich emissions. Exp Pathol 29:29–34.3699126
*Heit M, Tan Y, Klusek C, . 1981. Anthropogenic trace elements and polycyclic aromatic hydrocarbon levels in sediment cores from two lakes in the Adirondack acid lake region. Water Air Soil Pollut 15:441–464.
*Helmenstine A, Uziel M, Vo-Dinh T. 1993. Measurement of DNA adducts using surface-enhanced Raman spectroscopy. J Toxicol Environ Health 40(2):195–202.8230295
Henry MC, Port CD, Kaufman DG. 1975. Importance of physical properties of benzo[a]pyrene - ferric oxide mixtures. Cancer Res 35:207–217.1109789
Henry MC, Port DC, Bates RR, . 1973. Respiratory tract tumors in hamsters induced by benzo[a]pyrene. Cancer Res 33:1585–1592.4721222
*Herberg R, Marcus M, Wolff MS, . 1990. A pilot study of detection of DNA adducts in white blood cells of roofers by 32P-postlabelling. IARC Sci Pub 1 (104):205–214.
*Herikstad BV, Ovrebo S, Haugen A, . 1993. Determination of polycyclic aromatic hydrocarbons in urine from coke-oven workers with a radioimmunoassay.
*Hermann M. 1981. Synergistic effects of individual polycyclic aromatic hydrocarbons on the mutagenicity of their mixtures. Mutat Res 90:399–409.7038461
Hess GG, McKenzie DE, Hughes BM. 1986. Selective preconcentration of polycyclic aromatic hydrocarbons and polychlorinated biphenyls by in situ metal hydroxide precipitation. J Chromatogr 366:197–203.3097042
Heston WE, Schneiderman MA. 1953. Analysis of dose-response in relation to mechanisms of pulmonary induction. Science 117: 109.13028302
*Higginbotham S, RamaKirshana NVS, Lohansson SL, . 1993. Tumor-initiating activity and carcinogenicity of dibenzo(a,Z)pyrene versus 7,12-dimethylbenz(a)anthracene and benzo(a)pyrene at low doses in mouse skin. Carcinogenesis 14(5): 875–878.8504480
*Hilali A, Crutzen-Fayt MC, Gerber GB. 1993. Effect of age on the ability of rat liver tissue to transform chemical promutagens to mutagens. Gerontology 39: 125–127.8406054
*Hills JW, Hill HH. 1993. Carbon dioxide supercritical fluid extraction with a reaction solvent modifier for the determination of polycylic aromatic hydrocarbons. J Chromatogr Sci 31(1):6–12.
*Hinga KR, Pilson MEQ. 1987. Persistence of benz(a)anthracene degradation products in an enclosed marine ecosystem. Env Sci Technol 21:648–653.19995041
*Hinoshita F, Hardin JA, Sherr DH. 1992. Fluoranthene induces programmed cell death and alters growth of immature B cell populations in bone marrow cultures. Toxicology 73(2):203–218.1609430
Hirakawa T, Ishikawa T, Nimoto N, . 1979. Induction of enzyme-altered islands in rat liver by a single treatment with B[a]P after partial hepatectomy. Gann 373–394.
*Hites RA, Laflamme RE, Windson JJ. 1980. Polycyclic aromatic hydrocarbons in an anoxic sediment core from the Pettaquamscutt River (Rhode Island, U.S.A.). Geochimica et Cosmochimica Acta 44:873–878.
Hluchan E, Jenik M, Maly E. Determination of airborne polycyclic hydrocarbons by paper chromatography. J Chromatogr 91:531–538.4133392
Hoch-Ligeti C. 1941. Studies on the changes in the lymphoid tissue of mice treated with carcinogenic and non-carcinogenic hydrocarbons. Cancer Res 1:484–488.
*Hoffmann D, Hecht SS. 1991. Mutagenicity and tumor-initiating activity of methylated benzo(b)fluoranthenes. In: Cooper CS, Grover PL, eds. Chemical carcinogenesis and mutagenesis I. New York, NY: Springer Verlag, 63–102.
*Hoffmann D, Hoffmann I. 1993. Tobacco smoke as a respiratory carcinogen. In: Hirsch A, Goldberg M, Martin J-P, ., eds. Prevention of respiratory diseases. New York, NY: Marcel Dekker, Inc., 497–532.
*Hoffmann D, Rathkamp G, Nesnow S, . 1972. Fluoranthenes: Quantitative determination in cigarette smoke, formation by pyrolysis and tumor initiating activity. J Natl Cancer Inst 49:1165–1175.5084125
*Hoffmann D, Wynder EL. 1966. On the carcinogenic activity of dibenzopyrenes. Zeitschrift fur Krebsforschung 68:137–149. (German)4228038
Hogue C Jr, Brewster MA. 1991. The potential of exposure biomarkers in epidemiologic studies of reproductive health. Environ Health Perspect 90:261–270.2050070
*Holloway. MP, Biaglow MC, McCoy EC, . 1987. Photochemical instability of 1-nitropyrene, 3-nitrofluoranthene, 1,8-dinitropyrene and their parent polycyclic aromatic hydrocarbons. Mutat Res 187:199–207.3031495
Horikawa K, Sera N, Otofuji T, . 1991. Pulmonary carcinogenicity of 3,9-dinitrofluoranthene 3,7-dinitrofluoranthene, 3-nitrofluoranthene and benzo(alpha)pyrene in F344 rats. Carcinogenesis 12(6):1003–1008.2044179
*Horton AW, Christian GM. 1974. Cocarcinogenic versus incomplete carcinogenic activity among aromatic hydrocarbons: Contrast between chrysenes and benzo[b]triphenylene. J Natl Cancer Inst 53:1017–1020.4427387
*Horton JK, Rosenior JC, Bend, . 1985. Quantitation of B[a]P metabolite: DNA adducts in selected hepatic and pulmonary cell types isolated from [^3^H]benzo[a]pyrene-treated rabbits. Cancer Res 45:3477–3481.3926299
*Hoshino K, Hyashi Y, Takehira Y, . 1981. Influences of genetic factors on the teratogenicity of environmental pollutants: Teratogenic susceptibility to benzo[a]pyrene and Ah locus in mice. Congenital Anomalies 97–103.
*Hough JL, Baired MB, Sfeir GT, . 1993. Benzo(a)pyrene enhances atherosclerosis in White Carneau and Show Racer pigeons. Arterioscler Thromb 13:1721–1727.8241091
Howard AG, Mills GA. 1983. Identification of polynuclear aromatic hydrocarbons in diesel particulate emissions. Int J Environ Anal Chem 14:43–54.6192102
*Howard J. 1979. Analysis of B[a]P and other polycyclic aromatic hydrocarbons in food. In: Egan H, ed. Environmental carcinogens: Selected methods of analysis: Vol. 3. Analysis of polyaromatic hydrocarbons in environmental samples. Lyon, France: International Agency for Research on Cancer, 175–191.
*HSDB. 1988. Hazardous Substance Data Bank. National Library of Medicine, National Toxicology Program, Bethesda, MD. December 1988.
*HSDB. 1992. Hazardous substances data bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. April 27, 1992.
*HSDB. 1994. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Program (via TOXNET), Bethesda, MD.
Huberman E. 1975. Mammalian cell transformation and cell-mediated mutagenesis by carcinogenic polycyclic hydrocarbons. Mutat Res 29:285–291.1186764
*Hueper WC. 1949. Occupational cancer hazards found in industry. Industrial Hygiene Newsletter 9:7–9.
*Huesemann MH, Moore KO, Johnson RN. 1993. The fate of BDAT polynuclear aromatic compounds during biotreatment of refinery API oil separator sludge. Environ Progress 12(1):30–38.
*Huggett RJ, Defur PO, Bieri RH. 1988. Organic compounds in Chesapeake Bay sediments. Mar Pollut Bull 19(9):454–458.
Huggins C, Yang NC. 1962. Induction and extinction of mammary cancer. Science 137:257–262.14449781
*Hughes NC, Phillips DH. 1990. Covalent binding of dibenzpyrenes and benzo(a)pyrene to DNA: Evidence for synergistic and inhibitory interactions when applied in combination to mouse skin. Carcinogenesis (Eynsham) 11(9):1611–1620.
*Hughes NC, Pfau W, Hewer A . 1993. Covalent binding of polycyclic aromatic hydrocarbon components of coal tar to DNA in mouse skin. Carcinogenesis 14(1):135–144.8425262
*Huh N, Nemoto N, Utakoji T. 1982. Metabolic activation of benzo[a]pyrene, aflatoxin Bl, and dimethylnitrosamine by a human hepatoma cell line. Mutat Res 94:339–348.6287253
Hunt DF, Shabanowitz F, Harvey TM, . 1983. Analysis of organics in the environment by functional group using a triple quadrupole mass spectrometer. J Chromatogr 271:93–105.
*Huntley SL, Bonnevie NL, Wenning RJ, . 1993. Distribution of polycyclic aromatic hydrocarbons(PAHS) in three northern New Jersey waterways. Bull Environ Contam Toxicol 51(6):865–872.8257814
Husgafvel-Pursiainen K, Sorsa M, Miller M, . 1986. Genotoxicity and polycyclic aromatic hydrocarbon analysis of environmental tobacco smoke samples from restaurants. Mutagenesis 1:287–292.3331668
*IARC. 1973. Certain polycyclic aromatic hydrocarbons and heterocyclic compounds. Monographs on the evaluation of carcinogenic risk of the chemical to man. Vol. 3. Lyon, France: World Health Organization, International Agency for Research on Cancer.
*IARC. 1983. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans. Vol. 32: Polynuclear aromatic compounds: Part 1. Chemical, environmental and experimental data. Lyons, France: World Health Organization, International Agency for Research on Cancer, 155–161, 225–231.
*IARC. 1984. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans: Polynuclear aromatic hydrocarbons, part 2, carbon blacks, mineral oils (lubricant base oils and derived products) and some nitroarenes. Volume 33. Lyon, France: World Health Organization, International Agency for Research on Cancer.
*IARC. 1985. Monographs on the evaluation of the carcinogenic risk of chemicals to man. Vol. 35. Polynuclear aromatic compounds: Part 4, bitumens, coal-tars and derived products, shale oils and soots. Lyon, France: World Health Organization, International Agency for Research on Cancer, 104–140.
*IARC. 1987a. Monographs on the evaluation of carcinogenic risks to humans: An updating of IARC monographs. Volumes 1 to 42. Supplement 7. Lyon, France: World Health Organization, International Agency for Research on Cancer, 56–71.
*IARC. 1987b. Monographs on the evaluation of the carcinogenic risk of chemicals to humans: an updating of IARC monographs. Volumes 1 to 42. Supplement 7. Lyon, France: World Health Organization, International Agency for Research on Cancer, 252–254.
*IARC. 1989. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans: occupational exposures in petroleum refining: crude oil and major petroleum fuels. Volume 45. Lyon, France: World Health Organization, International Agency for Research on Cancer.
Imaizumi N, Hayakawa K, Suzuki Y, . 1990. Determination of nitrated pyrenes and their derivatives by high performance liquid chromatography with chemiluminescence detection after online electrochemical reduction. J Biomed Chromatogr 4(3):108–112.
Ingram AJ, King DJ, Grasso P, . 1993. The early changes in mouse skin following topical application of a range of middle distillate oil products. J Appl Toxicol 13(4):247–257.8376725
*IRIS. 1994. Integrated Risk Information System. U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office, Cincinnati, OH.
Ishidate M, Odashima S. 1977. Chromosome tests with 134 compounds on Chinese hamster cells in vitro: A screening for chemical carcinogens. Mutat Res 48:337–354.876270
*ITII. 1982. International Technical Information Institute. Toxic and hazardous industrial chemicals safety manual. Tokyo, Japan: International Technical Information Institute.
Iwagawa M, Maeda T, Izumi K, . 1989. Comparative dose-response study on the pulmonary carcinogenicity of 1,6-dinitropyrene and benzo(a)pyrene in F344 rats. Carcinogenesis 10(7):1285–1290.2736719
*Iwata K, Inui N, Takeuchi T. 1981. Induction of active melanocytes in mouse skin by carcinogens: A new method for detection of skin carcinogens. Carcinogenesis (London) 2:589–594.7273337
Izzotti A, Bagnasco M, Scatolini L, . 1993. Post-mortem stability of benzo(a)pyrene diolepoxide-DNA adducts in rat organs. Carcinogenesis 14(10):2185–2187.8222073
*Jacob J, Schmoldt A, Grimmer G. 1983a. Benzo[e]pyrene metabolism in rat liver microsomes: Dependence of the metabolite profile on the pretreatment of rats with various monooxygenase inducers. Carcinogenesis 4(7):905–910.6872145
*Jacob J, Schmoldt A, Raab G, . 1983b. Induction of specific monooxygenases by isosteric heterocyclic compounds of benz(a)anthracene, benzo(c)phenanthrene and chrysene. Cancer Lett 20:341–348.6688754
*Jacob J, Schmoldt A, Raab G, . 1985. Monooxygenase induction by various xenobiotics and its influence on the rat liver microsomal metabolite profile of benz[a]anthracene. Cancer Lett 27: 105–113.3839164
*Jacob J, Schmoldt A, Hamann M, . 1987. Monooxygenase induction by various xenobiotics and its influence on rat liver microsomal metabolism of chrysene in comparison to benz(a)anthracene. Cancer Lett 34:91–102.3802073
*Jacobs MW, Coates JA, Delfino JJ, . 1993. Comparison of sediment extract Microtox toxicity with semi-volatile organic priority pollutant concentrations. Arch Environ Contam Toxicol 24(4):461–468.
*Jarvholm B, Easton D. 1990. Models for skin tumour risks in workers exposed to mineral oils. Br J Cancer 62:1039–1041.2257210
*Jensen K. 1984. Benzo(a)pyrene input and occurrence in a marine area affected by refinery effluent. Water Air Soil Pollut 22:57–65.
*Jerina DM, Lehr RE, Yagi H, . 1976. Mutagenicity of B[a]P derivatives and the description of a quantum mechanical model which predicts the ease of carbonium ion formation from diol epoxides. In: de Serres FJ, Fouts JR, Bend JR, ., eds. In vitro metabolic activation in mutagenesis testing. Amsterdam, The Netherlands: Elsevier/North Holland, 159–178.
*Jerina DM, Sayer JM, Thakker DR, . 1980. Carcinogenicity of polycyclic aromatic hydrocarbons: The bay-region theory. In: Pullman B, Ts’O POP, Gelboin H, eds. Carcinogenesis: Fundamental mechanisms and environmental effects. Hingham, MA: D. Reidel Publishing Co, 1–12.
*Jin CJ, Miners JO, Burchell B, . 1993. The glucuronidation of hydroxylated metabolites of benzo(a)pyrene and 2-acetylaminofluorene by cDNA-expressed human UDP-glucuronosyltransferases. Arch Environ Toxicol 27(3):47–52.
Joe FLJ, Salemme J, Fazio T. 1982. High performance liquid chromatography with fluorescence and UV detection of polynuclear aromatic hydrocarbons in barley malt. J Assoc Off Anal Chem 65:1395–1402.7174581
*Joe FLJ, Salemme J, Fazio T. 1984. Liquid chromatographic determination of trace residues of polynuclear aromatic hydrocarbons in smoked foods. J Assoc Off Anal Chem 67:1076–1082.6520079
*John ED, Nickless G. 1977. Gas chromatographic method for the analysis of major polynuclear aromatics in particulate matter. J Chromatogr 138:399–412.
*Johnson JH. 1988. Automotive emissions. In: Watson AY, Bates RR, Kennedy D, eds. Air pollution: The automobile and public health. Washington, DC: National Academy Press, 39–76.
Jones KC, Stratford JA, Waterhouse K, . 1987. Polynuclear aromatic hydrocarbons in U.K. soils: Long-term termporal trends and current levels. Trace Subst Environ Health 2:140–148.
*Jones BT, Glick MR, Mignardi MA, . 1988. Determination of polycyclic aromatic hydrocarbons in cooked beef by low-temperature molecular luminescence spectrometry using a moving sample cooling belt. Appl Spectrosc 42(5):850–853.
*Jones KC, Grimmer G, Jacob J, . 1989a. Changes in the polynuclear aromatic hydrocarbon content of wheat grain and pasture grassland over the last century from one site in the UK. Sci Total Environ 78:117–130.2717918
*Jones KC, Stratford JA, Waterhouse KS, . 1989b. Increase in the polynuclear aromatic hydrocarbon content of an agricultural soil over the last century. Environ Sci Technol 23:95–101.
*Jongeneelen FJ, Leijdekkers C-M, Bos RP, . 1985. Excretion of 3-hydroxy-benzo(o)pyrene and mutagenicity in rat urine after exposure to benzo(a)pyrene. J Appl Toxicol 5:277–282.3902943
*Jongeneelen FJ, Bos RP, Anzion R, . 1986. Biological monitoring of polycyclic aromatic hydrocarbons - metabolites in urine. Stand J Work Environ Health 12:137–143.
*Jongeneelen FJ, Anzion RBM, Henderson PTH, . 1987. Determination of hydroxylated metabolites of polycyclic aromatic hydrocarbons in urine. J Chromatogr 413:227–232.3558672
*Jongeneelen FJ, Anzion BM, Scheepers PTJ, . 1988. 1-Hydroxypyrene in urine as a biological indicator of exposure to polycyclic aromatic hydrocarbons in several work environments. Am Ind Hyg 32:35–43.
*Jongeneelen FJ, Anzion RBM, Theuws JLG, . 1989. Urinary 1-Hydroxypyrene levels in workers handling petroleum coke. J Toxicol Environ Health 26:133–136.2913332
*Jongeneelen FJ, van Leeuwen FE, Oosterink S, . 1990. Ambient and biological monitoring of cokeoven workers: determinants of the internal dose of polycyclic aromatic hydrocarbons. British J Indust Med 47:454–461.
Kagan J, Tuveson RW, Gong HH. 1989. The light-dependent cytotoxicity of benzo[a]pyrene: Effect on human erythrocytes, Escherichia coli cells, and Huemophilus influenzae transforming DNA. Mutat Res 216(5):231–242.2552308
*Kamens RM, Fulcher JN, Zhishi G. 1986. Effects of temperature on wood soot: PAH decay in atmospheres with sunlight and low NOx. Atmos Environ 20:1579–1587.
*Kanoh T, Fukuda M, Hayami E, . 1990. Nitro reaction in mice injected with pyrene during exposure to nitrogen dioxide. Mutat Res 245(1):1–4.2202898
*Kanoh T, Fukuda M, Onozuka H, . 1993. Urinary 1-hydroxypyrene as a marker of exposure to polycyclic aromatic hydrocarbons in environment. Environ Res 62:230–241.7688294
*Kao JK, Patterson FK, Hall J. 1985. Skin penetration and metabolism of topically applied chemicals in six mammalian species, including man: An in vitro study with benzo[a]pyrene and testosterone. Toxicol Appl Pharmacol 81:502–516.3936234
*Kapitulnik J, Levin W, Lu AYH, . 1977. Hydration of arene and alkene oxides by epoxide hydrase in human liver microsomes. Clin Pharmacol Ther 21:158–165.65238
Karasek FW, Denney DW, Chan KW, . 1978. Analysis of complex organic mixtures on airborne particulate matter. Anal Chem 50:82–87.
*Karickhoff SW, Brown DS, Scott TA. 1979. Sorption of hydrophobic pollutants on natural sediments. Water Res 13:241–248.
*Karlesky DL, Ramelow G, Ueno Y, . 1987. Survey of polynuclear aromatic compounds in oil refining areas. Environ Poll 43:195–207.
*Katiyar SK, Agarwal R, Mukhtar H. 1993a. Protective effects of green tea polyphenols administered by oral intubation against chemical carcinogen-induced forestomach and pulmonary neoplasia in A/J mice. Cancer Lett 167–172.
*Katiyar SK, Agarwal R, Tarif Zaim M, . 1993b. Protection against N-nitrosodiethylamine and benzo[a]pyrene-induced forestomach and lung tumorigenesis in A/J mice by green tea. Carcinogenesis 14(5):849–855.8504476
Katz M, Pierce RC. 1976. Quantitative distribution of polynuclear aromatic hydrocarbons in relation. In: Freudenthal RI, Jones PW, eds. Carcinogenesis: Polynuclear aromatic hydrocarbons: Chemistry, metabolism, and carcinogenesis.
*Kauss PB. 1991. Biota of the St. Marys River: habitat evaluation and environmental assessment. Hydrobiologia 219:1–35.
*Kawamoto T, Yoshikawa M, Matsuno K, . 1993. Effect of side-stream cigarette smoke on the hepatic cytochrome P450. Arch Environ Contam Toxicol 25:255–259.8368867
*Kawamura Y, Kamata E, Ogawa Y, . 1988. The effect of various foods on the intestinal absorption of benzo-a-pyrene in rats. J Food Hyg Sot Jpn 29(1):21–25.
*Keller GM, Christou M, Pottenger LH, . 1987. Product inhibition of benzo(a)pyrene metabolism in uninduced rat liver microsomes: Effect of diol epoxide formation. Chem Biol Interact 61:159–175.3103934
*Kelly GW, Bartle KD, Clifford AA, . 1993. Identification and quantitation of polycyclic aromatic compounds in air particulate and diesel exhaust particulate extracts by LC-GC. J Chromatogr Sci 31(3):73–76.
*Kemena A, Norpoth KH, Jacob J. 1988. Differential induction of the monooxygenase isoenzymes in mouse liver microsomes by polycyclic aromatic hydrocarbons. In: Cooke M, Dennis AJ, eds. Polynuclear aromatic hydrocarbons: A decade of progress. Proceedings of the Tenth International Symposium. Columbus, OH: Battelle Press, 449–460.
*Kenneway EL. 1924. On cancer-producing tars and tar-fractions. J Ind Hyg 5:462–490.
*Kennicutt MC II, Wade TL, Presley BJ, . 1994. Sediment contaminants in Casco Bay, Maine: Inventories, sources, and potential for biological impact. Environ Sci Technol 28(1):1–15.22175827
Kertesz-Saringer M, Morlin Z. 1975. On the occurrence of polycyclic aromatic hydrocarbons in the urban area of Budapest. Atmos Environ 9:831–834.
Ketkar M, Resnick G, Schneider P, . 1978. Investigations on the carcinogenic burden by air pollution in man: Intratracheal instillation studies with benzo[a]pyrene in bovine serum albumin. Cancer Lett 4:235–239.647664
Ketkar M, Green V, Schnieder P, . 1979. Investigations on the carcinogenic burden by air pollution in man: Intratracheal instillation studies with benzo[a]pyrene in a mixture of Tris buffer and saline in Syrian golden hamsters. Cancer Lett 6:279–284.436122
*Khan MA, Matin MA, Beg MU. 1993. Effect of intratracheally administered lindane on aldrin and benzo[a]pyrene contents in lungs of rats. Toxicol Lett 69:63–67.7689255
*Khanduja KL, Majid S. 1993. Ellagic acid inhibits DNA binding of benzo[a]pyrene activated by different modes. J Clin Biochem Nutr 15: 1–9.
*Kiefer F, Cumpelik O, Wiebel FJ. 1988. Metabolism and cytotoxicity of benzo(a)pyrene in the human lung tumour cell line NCI-H322. Xenobiotica 18:747–755.3420950
*King TL, Uthe JF, Musial CJ. 1993. Polycyclic aromatic hydrocarbons in the digestive glands of the american lobster, Honarus americanus, captured in the proximity of a coal-coking plant. Bull Environ Contam Toxicol 50:907–914.8495069
*King LC, George M, Gallagher JE, . 1994. Separation of ^32^P-postlabeled DNA adducts of polycyclic aromatic hydrocarbons and nitrated polycyclic aromatic hydrocarbons by HPLC. Chem Res Toxicol 7:503–510.7526903
*Kirso U, Belykh L, Stom D, . 1983. Oxidation of benzo[a]pyrene by plant enzymes. In: Cooke M, Dennis AJ, eds. Polynuclear aromatic hydrocarbons: Formation, metabolism and measurement. Columbus, OH: Battelle Press, 679–687.
Klein M. 1952. Effect of croton oil on induction of tumors by 1,2-benzanthracene, deoxychloric or low doses of 20-methylcholanthrene in mice. J Natl Cancer Inst 13:333–341.12991043
Klein M. 1960. A comparison of the initiating and promoting actions of 9,10-dimethyl-1,2-benzanthracene and 1,2,5,6-dibenzanthracene in skin tumorigenesis. Cancer Res 20: 1179.13756670
*Klein M. 1963. Susceptibility of strain B6AFIJ hybrid infant mice to tumorigenesis with 1,2-benzanthracene, deoxycholic acid and 3-methylcholanthrene. Cancer Res 23:1701–1707.14098913
*Klemme JC, Mukhtar H, Elmets CA. 1987. Induction of contact hypersensitivity to dimethylbenz(a)anthracene and benzo(a)pyrene in C3H/HeN mice. Cancer Res 47:6074–6078.3117362
*Knecht U, Elliehausen HJ, Jusas W, . 1987. Polycyclic aromatic hydrocarbons (PAH) in abraded particles of brake and clutch linings. Int J Environ Occup Sot Med 28:227–236.
Knobloch K, Szendzikowski S, Slusarczyk-Zalobna A. 1969. On the acute and sub-acute toxic effects of acenapthene and acenapthylene. Occup Med 20:210–220.
*KNREPC. 1991. Threshold ambient limits and significant emission levels of toxic pollutants. Frankfurt, KY: Kentucky Natural Resources and Environmental Protection Cabinet. 401 KAR 63:022.
Kolarovic L, Traitler H. 1982. Determination of polycyclic aromatic hydrocarbons in vegetable oils by caffeine complexation and glass capillary gas chromatography. J Chromatogr 237:263–272.
*Konash PL, Wise SA, May WE. 1981. Selective quenchofluorimetric detection of fluoranthenic polycyclic aromatic hydrocarbons in high-performance liquid chromatography. J Liq Chromatogr 4(8):1339–1349.
*Koratkar R, Das UN, Sangeetha Sagar P, . 1993. Prostacyclin is a potent anti-mutagen. Prostaglandins Leukotrienes and Essential Fatty Acids 48:175–184.8383336
*Korfmacher WA, Wehry EL, Mamantov G, . 1980. Resistance to photochemical decomposition of polycyclic aromatic hydrocarbons vapor-adsorbed on coal fly ash. Environ Sci Technol 14:1094–1099.
*Kouri RE, Rude TH, Joglekar R, . 1978. 2,3,7,8-Tetrachloro-dibenzo-p-dioxin as cocarcinogen causing 3- methylcholanthrene initiated subcutaneous tumors in mice genetically ‘nonresponsive’ at Ah locus. Cancer Res 38:2777–2783.679184
*Krahn M, Malins DC. 1982. Gas chromatographic-mass spectrometric determination of aromatic hydrocarbon metabolites from livers of fish exposed to fuel oil. J Chromatogr 248:99–107.7142354
*Krahn MM, Moore LK, Bogar RG, . 1988. High-performance liquid chromatographic method for isolating organic contaminants from tissue and sediment extracts. J Chromatogr 437:161–175.3131379
Kraybill HF. 1983. Assessment of human exposure and health risk to environmental contaminants in the atmosphere and water with special reference to cancer. J Environ Sci Health [c] Carcinog Rev 1(2):175–232.
Kunstler K. 1983. Failure to induce tumors by intratracheal instillation of automobile exhaust condensate and fractions thereof in Syrian golden hamsters. Cancer Let 18:105–108.6186363
Kushwaha SC, Clarkson SG, Mehkeri KA. 1985. Polycyclic aromatic hydrocarbons in barbecue briquets. J Food Saf 7:177–201.
*Ladies GS, Kawabata TT, White KL Jr. 1991. Suppression of the in vitro humoral immune response of mouse splenocytes by 7,12-dimethylbenz(a)anthracene metabolites and inhibition of immunosuppression by alpha-naphthoflavone. Toxicol Appl Pharmacol 110(1):31–44.1908145
*La Fontaine M. 1978. Huiles minerales et cancers cutaines. Paris, France: Institut National de Recheche et de Securite. (French)
Laher JM, Barrowman JA. 1987. Role of the lymphatic system in the transport of absorbed 7,12-dimethylbenzanthracene in the rat. Lipids 22:152–155.3106741
*Lai LK, Filseth SV, Sadowski CM, . 1990. Direct determination of benzo(a)pyrene and pyrene in solid environmental samples by jet-cooled spectroscopy. Int J Environ Anal Chem 40(1–4):99–109.
*Lamotte M, Rima J, Garrigues P, . 1985. Quantitative analysis of PAH (polynuclear aromatic hydrocarbons) in environmental samples by fluorometry in Shpol’skii matrices at low temperature. Polynuclear Aromatic Hydrocarbons:785–798.
Laskin S, Kuscher M, Drew RT. 1970. Studies in pulmonary carcinogenesis. In: Hanna MG, Nettesheim P, Gilbert J, eds. Inhalation carcinogenesis. AEC Symposium Series No. 18. Oak Ridge, TN: Oak Ridge Division of Technical Information, U.S. Atomic Energy Commission, 321–351.
Lasnitzki A, Woodhouse DL. 1944. The effect of 1,2,5,6-dibenzanthracene on the lymph nodes of the rat. J Anat 78:121.17104952
*Lau HH, Baird WM. 1991. Detection and identification of benzo[a]pyrene-DNA adducts by [^35^S]phosphorothioate labeling and HPLC. Carcinogenesis 12(5):885–893.2029754
*Lau HH, Baird WM. 1992. The co-carcinogen benzo[e]pyrene increases the binding of a low dose of the carcinogen benzo[a]pyrene to DNA in Sencar mouse epidermis. Cancer Lett (Ireland) 63(3):229–236.
*LaVoie E, Bedenko V, Hirota N, . 1979. A comparison of the mutagenicity, tumor initiating activity and complete carcinogenicity of polynuclear aromatic hydrocarbons. In: Jones PW, Leber P, eds. Polynuclear aromatic hydrocarbons. Ann Arbor, MI: Science Publishers, Inc.
LaVoie EJ, Hecht SS, Amin S, . 1980a. Identification of mutagenic dihydrodiols as metabolites of benzo(j)fluoranthene and benzo(k)fluoranthene. Cancer Res 40:4528–4532.7002294
LaVoie EJ, Tulley L, Bedenko V, . 1980b. Mutagenicity, tumor-initiating activity, and metabolism of tricyclic polynuclear aromatic hydrocarbons. In: Bjorseth A, Dennis AJ, eds. Polynuclear aromatic hydrocarbons: Chemistry and biological effects. Columbus, OH: Batelle Press.
LaVoie EJ, Tulley L, Bedenko V, . 1981a. Mutagenicity of methylated fluorenes and benzofluorenes. Mutat Res 91 (3):167–176.7017394
*LaVoie EJ, Tulley L, Bedenko V, . 1981b. Mutagenicity, tumor-initiating activity and metabolism of methylphenanthrenes. Cancer Res 41:3441–3447.7020927
*LaVoie EJ, Amin S, Hecht SS, . 1982. Tumor initiating activity of dihydrodiols of benzo(b)fluoranthene, benzo(j)fluoranthene and benzo(k)fluoranthene. Carcinogenesis 3:49–52.7067037
*LaVoie EJ, Coleman DT, Tonne RL, . 1983a. Mutagenicity, tumor initiating activity and metabolism of methylated anthracenes. In: Cooke M, Dennis AJ, eds. Proceedings of the Seventh International Symposium. Columbus, OH: Battelle Press, 785–798.
LaVoie EJ, Tulley L, Bedenko V, . 1983b. Mutagenicity of substituted phenanthrenes in Salmonella typhimurium. Mutat Res 116:91–102.6338362
LaVoie EJ, Coleman DT, Rice JE, . 1985. Tumor-initiating activity, mutagenicity, and metabolism of methylated anthracenes. Carcinogenesis (London) 6:1483–1488.3899400
LaVoie EJ, Braley J, Rice JE, . 1987. Tumorigenic activity of non-altemant polynuclear aromatic hydrocarbons in newborn mice. Cancer Let 34:15–20.3802065
*LaVoie EJ, Cai Z-W, Meegalla RL, . 1993a. Evaluation of the tumor-initiating activity of 4-, 5-, 6-, and 7-fluorobenzo[b]fluoranthene in mouse skin. Chem Bio Interact 89:129–139.8269542
*LaVoie EJ, He Z-M, Meegalla RL, . 1993b. Exceptional tumor-initiating activity of 4-fluorobenzoljlfluoroanthene on mouse skin: comparison with benzo[j]fluoranthene, 10-fluoro-benzoIj]fluoranthene, benzo[a]pyrene, dibenzo[a,l]pyrene and 7,12-dimethylbenz[a]anthracene. Cancer Lett 70:7–14.8330304
*Lawrence JF, Das BS. 1986. Determination of nanogram/kilogram levels of polycyclic aromatic hydrocarbons in foods by HPLC with fluorescence detection. Int J Environ Anal Chem 24(2):113–131.3710676
*Lawrence JF, Weber DF. 1984. Determination of polycyclic aromatic hydrocarbons in some Canadian commercial fish, shellfish and meat products by liquid chromatography with confirmation by capillary gas chromatography-mass spectrometry. J Agric Food Chem 32:789–794.
Leadon SA, Stampfer MR, Bartley J. 1988. Production of oxidative DNA damage during the metabolic activation of benzo(a)pyrene in human mammary epithelial cells correlates with cell killing. Proc Natl Acad Sci 85:4365–4368.3380798
*Lecoq S, Chalvet O, Strapelias H, . 1991a. Microsomal metabolism of dibenz(a,c)anthracene, dibenz(a,h)anthracene and dibenz(a,j)anthracene to bisdihydrodiols and polyhydroxylated products. Chem-Biol Interact 80(3):261–280.1954655
*Lecoq S, Ni She M, Grover PL, . 1991b. The in vitro metabolic activation of dibenz[a, hlanthracene, catalyzed by rat liver microsomes and examined by ^32^P-postlabelling. Cancer Lett 57(3):261–269.2032213
*Lecoq S, Perin F, Plessis MJ, . 1989. Comparison of the in vitro metabolisms and mutagenicities of dibenzo[a,c]anthracene, dibenzo[a,h]anthracene and dibenzo[a,j]anthracene: Influence of norharman. Carcinogenesis 10(3):461–469. 0143–3334.2924394
Lee BM, Santella RM. 1988. Quantitation of protein adducts as a marker of genotoxic exposure: Immunologic detection of benzo[a]pyrene-globin adducts in mice. Carcinogenesis 9(10):1773–1777.3168157
*Lee H, Lin JY. 1988. Antimutagenic activity of extracts from anticancer drugs in Chinese medicine. Mutat Res 204:229–234.3278214
*Lee BM, Strickland PT. 1993. Antibodies to carcinogen-DNA adducts in mice chronically exposed to polycyclic aromatic hydrocarbons. Immunol Lett 36:117–124.8349308
*Lee CK, Brown BG, Reed EA, . 1993. Ninety-day inhalation study in rats, using aged and diluted sidestream smoke from a reference cigarette: DNA adducts and alveolar macrophage cytogenetics. Fundam Appl Toxicol 20:393–401.8314456
*Legraverend C, Guenther TM, Nebert DW. 1984. Importance of the route of administration for genetic differences in benzo[a]pyrene-induced in utero toxicity and teratogenicity. Teratology 29:35–47.6322374
*Legraverend C, Harrison DE, Ruscetti W, . 1983. Bone marrow toxicity induced by oral benzo(a)pyrene: Protection resides at the level of the intestine and liver. Toxicol Appl Pharmacol 70:390–401.6314600
*Legzdins AE, McCarry BE, Bryant DW. 1994. Polycyclic aromatic compounds in Hamilton air: Their mutagenicity, ambient concentrations and relationships with atmospheric pollutants. Polycyclic Aromatic Compounds 5(1–4):157–165.
*Lemieux PM, Ryan JV. 1993. Characterization of air pollutants emitted from a simulated scrap tire fire. Air Waste 43: 1106–1115.
Lesage J, Perrault G, Durand P. 1987. Evaluation of worker exposure to polycyclic aromatic hydrocarbons. Am Ind Hyg Assoc J 48:753–759.3687734
*Leung HW, Henderson RF, Bond JA, . 1988. Studies on the ability of rat lung and liver microsomes to facilitate transfer and metabolism of benzo(a)pyrene from diesel particles. Toxicology 51:1–9.2457962
Levin W, Wood AW, Yagi H, . 1976. Carcinogenicity of benzo[a]pyrene 4,5-, 7,8-, 9 and 10-oxides on mouse skin. Proc Natl Acad Sci USA 73:243–247.1061121
Levin W, Wood AW, Chang RL, . 1978. Evidence for bay region activation of chrysene 1,2 dihydrodiol to an ultimate carcinogen. Cancer Res 38:1831.647691
*Levin W, Wood A, Chang R, . 1982. Oxidative metabolism of polycyclic aromatic hydrocarbons to ultimate carcinogens. Drug Metab Rev 13:555–580.6290166
*Levin W, Chang RL, Wood AW, . 1984. High stereoselectivity among the optical isomers of the diastereomeric bay-region diol-epoxides of benz(a)anthracene in the expression of tumorigenic activity in murine tumor models. Cancer Res 44:929–933.6692415
*Lewis RF. 1993. Site demonstration of slurry-phase biodegradation of PAH contaminated soil. Air Waste 43:503–508.
*Lewtas J, Mumford J, Everson RB, . 1993. Comparison of DNA adducts from exposure to complex mixtures in various human tissues and experimental systems. Environ Health Perspect 99:89–97.8319665
*Liao W, Smith WD, Chiang TC, . 1988. Rapid, low-cost cleanup procedure for determination of semivolatile organic compounds in human and bovine adipose tissues. J Assoc Off Anal Chem 71:742–747.3417593
Lijinsky WH, Garcia B, Terracini B. 1965. Tumorigenic activity of hydrogenated derivatives of dibenz(a,h)anthracene. J Natl Cancer Inst 34:1.14287279
Likhachev AJ, Beniashvili DSh, Bykov VJ, . 1992. Relevance of quantitation of benzo(a)pyrene metabolites in animal excretes to evaluate individual human cancer risk. Prog Clin Biol Res 374:435–452.1620717
*Likhachev AJ, Beniashvili DS, BYkov VJ, . 1993. Biomarkers of individual suseceptability to carcinogens: Application for biological monitoring. Int Arch Occup Environ Health 65:S155–S158.8406916
*Limasset J-C, Diebold F, Hubert G. 1993. Assessment of bus drivers’ exposure to the pollutants of urban traffic. Sci Tot Environ 134:39–49. (French)
*Lin CH, Fukii H, Imasaka T, . 1991. Synchronous scan luminescence techniques monitoring resonance and non-resonance fluorescence in supersonic jet spectrometry applied to anthracene derivatives. Anal Chem 63(14):1433–1440.
*Lindemann RA, Park N-H. 1989. The effects of benzo-a-pyrene nicotine and tobacco-specific nitrosamines on the generation of human lymphokine-activated killer cells. Arch Oral Biol 34(4):283–288.2597022
Liotti FS, Bodo M, Mariucci G, . 1989. The role of antioxidant enzymes in benzo(a)pyrene-induced carcinogenesis. Bull Cancer 76(1):43–50.2713514
Liotti FS, Pelliccia C, Pezzetti F. 1988. Different response of chicken embryo fibroblasts and hepatocytes to the interference of certain antioxidants on the binding of [G-^3^H] benzo[a]pyrene to DNA. Cancer Lett 41:235–242.3401847
*Lioy PJ. 1989. Exposure analysis and assessment for low-risk cancer agents. Int J Epidemiol 19(3 Suppl 1):53–61.
*Lioy PJ, Greenberg A. 1990. Factors associated with human exposures to polycyclic aromatic hydrocarbons. Toxicol Ind Health 6(2):209–224.2356563
*Lioy PL, Waldman JM, Greenberg A, . 1988. The total human environmental exposure study (THEES) to benzo(a)pyrene: Comparison of the inhalation and food pathways. Arch Environ Health 43:304–312.3415358
*Lipniak M, Brandys J. 1993. Toxicokinetics of fluoranthene, pyrene and benz(a)anthracene in the rat. Polycyclic Aromatic Hydrocarbons 3:111–119.
Little JB, Vetroys H. 1988. Studies of ionizing radiation as a promoter of neoplastic transformation in vitro. Int J Radiat Biol 53:661–666.
*Lloyd JW. 1971. Long-term mortality study of steelworkers: V. Respiratory cancer in coke plant workers. J Occup Med 13:53–68.5546197
*Lo Jacono F, Stecca C, Duverger M. 1992. Mutagenic activation of benzo[a]pyrene by human red blood cells. Mutat Res 268(1):21–26.1378182
*Loehr RC, Erickson DC, Kelmar LA. 1993. Characteristics of residues at hazardous waste land treatment units. Water Res 27(7):1127–1138.
Lorenz E, Stewart HL. 1948. Tumors of alimentary tract in mice fed carcinogenic hydrocarbons in mineral oil emulsions. J Natl Cancer Inst 9:173.18105868
*Lorenz LF, Gjovik LR. 1972. Analyzing creosote by gas chromatography: Relationship to creosote specifications. Proceedings of the American Wood-Preservers’ Association 68:32–42.
*Low GK-C, Batley GE, Lidgard RO, . 1986. Determination of polycyclic aromatic hydrocarbons in coal fly ash using gas chromatography/negative ion chemical ionization mass spectrometry. Biomed Environ Mass Spectrom 13:95–104.
*Lowenthal DH, Zielinska B, Chow JC, . 1994. Characterization of heavy-duty diesel vehicle emissions. Atmos Environ 28(4):731–743.
*Lu L-J W, Anderson LM, Jones AB, . 1993. Persistence, gestation stage-dependent formation and interrelationship of benzo[a]pyrene-induced DNA adducts in mothers, placentae and fetuses of Erythrocebus patas monkeys. Carcinogenesis 14(9):1805–1813.8403203
*Lubet RA, Brunda MJ, Lemaire B, . 1984. Polycyclic hydrocarbon: Induced immunotoxicity in mice: Role of the Ah locus. In: Cooke M, Dennis AJ, eds. Mechanisms, methods and metabolism: Polynuclear aromatic hydrocarbons. 8th International Symposium. Columbus, OH: Battelle Press, 843–855.
Lubet RA, Connelly GM, Nebert DW, . 1983a. Dibenz[a,h]anthracene-induced subcutaneous tumors in mice. Strain sensitivity and the role of carcinogen metabolism. Carcinogenesis 4:513–517.6850980
Lubet RA, Kiss E, Gallagher MM, . 1983b. Induction of neoplastic transformation and DNA single-strand breaks in C3WlOT1/2 clone 8 cells by polycyclic hydrocarbons and alkylating agents. J Natl Cancer Inst 71:991–998.6316014
*Lunde G, Bjorseth A. 1977. Polycyclic aromatic hydrocarbons in long-range transported aerosols. Nature 268:518.887170
*Luster MI, Rosenthal GJ. 1993. Chemical agents and the immune response. Environ Health Perspect 100:219–226.8354170
*Lyman W, Reehl WF, Rosenblatt DH. 1982. Handbook of chemical property estimation methods. New York, NY: McGraw Hill, Inc., 15/10–15/21.
*Lyte M, Bick PH. 1985. Differential immunotoxic effects of the environmental chemical benzo[a]pyrene in young and aged mice. Mech Aging Dev 30:333–341.3875008
Lyte M, Blanton RH, Myers MJ, . 1987. Effect of in vivo administration of the carcinogen benzo(a)pyrene on interleukin-2 and interleukin-3 production. Int J Immunopharmacol 9:307–312.3497114
*Mabey WR, Smith JH, Podoll RT, . 1981. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environmental Protection Agency. EPA-440/4-81-014.
*Mabey WR, Smith JH, Podoll RT, . 1982. Aquatic fate process data for organic priority pollutants. Washington, D.C: US Environmental Protection Agency, Office of Water Regulations and Standards. EPA 440/4-81-014.
*Machado ML, Beatty PW, Fetzer JC, . 1993. Evaluation of the relationship between PAH content and mutagenic activity of fumes from roofing and paving asphalts and coal tar pitch. Fundam Appl Toxicol 21:492–499.8253302
*Mackenzie KM, Angevine DM. 1981. Infertility in mice exposed in utero to benzo[a]pyrene. Biol Reprod 24:183–191.7470542
*MacKenzie MJ, Hunter JV. 1979. Sources and fates of aromatic compounds in urban stormwater runoff. Environ Sci Technol 13:179–183.
*Mackenzie PI, Rodboum L, Iyanagi T. 1993. Glucuronidation of carcinogen metabolites by complementary DNA-expressed uridine 5’-diphosphate glucuronosyltransferases. Cancer Res 53:1529–1533.8453618
*MacLeod MC, Evans FE, Lay J, . 1994. Identification of a novel, N7-deoxyguanosine adduct as a major DNA adduct formed by a non-bay-region diol epoxide of benzo[a]pyrene with low mutagenic potential. Biochemistry 33:2977–2987.8130212
*Maclure KM, MacMahon B. 1980. An epidemiologic perspective of environmental carcinogenesis. Epidemiol Rev 2:19–48.7000535
MacNicoll AD, Grover PL, Sims P. 1980. The metabolism of a series of polycyclic hydrocarbons by mouse skin maintained in short-term organ culture. Chem Biol Interact 29(2): 169–188.6766358
Mager R, Huberman E, Yang SK, . 1977. Transformation of normal hamster cells by benzo(a)pyrene diol-epoxide. Int J Cancer 19:814–817.873645
*Majer JR, Perry R, Reade MJ. 1970. The use of thin-layer chromatography and mass spectrometry for the rapid estimation of trace quantities of air pollutants. J Chromatogr 48:328–333.5445428
*Malmgren RA. 1952. Reduced antibody titers in mice treated with carcinogenic and cancer chemotherapeutic agents. Proc Sot Biol Med 79:484.
Mamber SW, Bryson V, Katz SE. 1983. The Esherichia coli WP2/WP100 ret assay for detection of potential chemical carcinogens. Mutat Res 119:135–144.6338367
*Matsuoka A, Sofuni T, Miyata N, . 1991. Clastogenicity of I-nitropyrene, dinitropyrenes, fluorene and mononitrofluorenes in cultured Chinese hamster cells. Mutat Res 259(1):103–110.1988818
*Matthews EJ. 1993. Transformation of BALB/c-3T3 cells: II. Investigation of experimental parameters that influence detection of benzo[a]pyrene-induced transformation. Environ Health Perspect 101(Supp 2):293–310.8243399
*Mattison DR, Singh H, Takizawa K, . 1989. Ovarian toxicity of benzo(a)pyrene and metabolites in mice. Reprod Toxicol 3(2):115–126.2485204
*Matzner E. 1984. Annual rates of deposition of polycyclic aromatic hydrocarbons in different forest ecosystems. Water Air Soil Polut 21:425–434.
May WE, Chesler SN, Hertz HS, . 1982. Analytical standards and methods for the determination of polynuclear aromatic hydrocarbons in environmental samples. Int J Environ Anal Chem 12:259–275.
*Mazumdar S, Redmond CK, Sollecito W, . 1975. An epidemiological study of exposure to coal tar pitch volatiles among coke oven workers. J Air Pollut Control Assoc 25:382–389.
McCabe DP, Flynn EJ. 1990. Deposition of low dose benzo(a)pyrene into fetal tissue: Influence of protein binding. Teratology 41(1):85–95.2305376
*McCarthy DJ, Lindamood CI, Hill DL. 1987. Effects of retinoids on metabolizing enzymes and on binding on benzo(a)pyrene to rat tissue DNA. Cancer Res 47:5014–5020.3621188
*McCormick DL, Burns FJ, Alberg RE. 1981. Inhibition of benzo[a]pyrene-induced mammary carcinogenesis by retinyl acetate. J Natl Cancer Inst 66:559–564.6970847
McIntyre AE, Perry R, Lester JN. 1981. Analysis of polynuclear aromatic hydrocarbons in sewage sludges. Anal Lett 14:291–309.
*McVeety BD, Hites RD. 1988. Atmospheric deposition of polycyclic aromatic hydrocarbons to water surfaces a mass balance approach. Atmos Environ 22(3):511–536.
*Melikian AA, Bagheri K, Hecht SS. 1987. Contrasting disposition and metabolism of topically applied benzo(a)pyrene, trans-7,8-dihydroxy-7,8-dihydrobenzo(a)pyrene, and 7 beta, 8 alpha-dihydroxy-9 alpha, 10 alpha-epoxy-7,8,9,10-tetrahydrobenzo(a)pyrene in mouse epidermis in viva. Cancer Res 47:5354–5360.3115566
Melikian AA, Bagheri K, Hecht SS, . 1989. Metabolism of benzo[a]pyrene and 7 beta, 8 alpha-dihydroxy-9 alpha, 10 alpha-epoxy-7,8,9,10-tetrahydrobenzo[a pyrene in lung and liver of newborn mice. Chem Biol Interact 69(2–3):245–257.2495193
*Menzie CA, Potocki BB, Santodonato J. 1992. Ambient concentrations and exposure to carcinogenic pahs in the environment. Environ Sci Technol 26(7):1278–1284.
Mercado Calderon F. 1993. Evaluation of 1-hydroxypyrene as a biological marker of industrial exposure to polycyclic aromatic hydrocarbons. Proc SPIE(Int Sot Opt Eng) 1716:256–267.
*Mane SS, Pumell DM, Hsu IC. 1990. Genotoxic effects of five polycyclic aromatic hydrocarbons in human and rat mammary epithelial cells. Environ Mol Mutagen 15(2):78–82.2307152
*Manila1 VB, Alexander M. 1991. Factors affecting the microbial degradation of phenanthrene in soil. Appl Microbial Biotechnol 35(3):401–405.
*Marcomini A, Sfriso A, Pavoni B. 1987. Variable wavelength absorption in detecting environmentally relevant PAHs by high-performance liquid chromatography. Mar Chem 21:15–24.
*Marcus JM, Swearingen GR, Williams AD, . 1988. Polynuclear aromatic hydrocarbon and heavy metal concentrations in sediments at coastal South Carolina marinas. Arch Environ Contam Toxicol 17(1):103–114.3337549
Marino DJ. 1987. Evaluation of pluronic polyol F127 as a vehicle for petroleum hydrocarbons. Environ Mutagen 9:307–316.3106024
*Marks HS, Anderson JA, Stoewsand GS. 1993. Effect of S-methyl cysteine sulphoxide and its metabolite methyl methane thiosulphinate, both occuring naturally in brassica vegetables, on mouse genotoxicity. Food Chem Toxic 31(7):491–495.
Marquardt H, Kuroki T, Huberman E, . 1972. Malignant transformation of cells derived from mouse prostate by epoxides and other derivatives of polycyclic hydrocarbons. Cancer Res 32:716–720.5014782
*Marshall MV, He Z-M, Weyand EH, . 1993. Mutagenic activity of the 4,5- and 9, 10-dihydrodiols of benzo~]fluoranthene and their syn- and anti-dihydrodiol epoxides in Salmonella typhimurium. Environ Mol Mutagen 22:34–45.8339723
Martin CN, McDermid AC, Gamer RC. 1978. Testing of known carcinogens and noncarcinogens for their ability to induce unscheduled DNA synthesis in HeLa cells. Cancer Res 38:2621–2627.667855
Masclet P, Pistikopoulos P, Beyne S, . 1988. Long range transport and gas/particle distribution of polycyclic aromatic hydrocarbons at a remote site in the Mediterranean sea. Atmos Environ 22:639–650.
Masento MS, Hewer A, Grover PL, . 1989. Enzyme-mediated phosphorylation of polycyclic hydrocarbon metabolites: Detection of non-adduct compounds in the phosphorus-32 post-labelling assay. Carcinogenesis 10(8):1557–1559.2665969
*Mass MJ, Jeffers AJ, Ross JA, . Ki-ras oncogene mutations in tumors and DNA adducts formed by benz[j]aceanthrylene and benzo[a]pyrene in the lungs of strain A/J mice. Mol Carcinogen 8:186–192.
*Matsumoto H, Kashimoto T. 1985. Average daily respiratory intake of polycyclic aromatic hydrocarbons in ambient air determined by capillary gas chromatography. Bull Environ Contam Toxicol 34:17–23.3971056
Matsuoka A, Hayashi M, Ishidate MJ. 1979. Chromasomal aberration tests on 29 chemicals combined with S9 mix in vitro. Mut Res 66:277–290.375085
*Merk HF, Mukhtar H, Kaufmann I, . 1987. Human hair follicle benzo(a)pyrene and benzo(a)pyrene 7,8-diol metabolism: Effect of exposure to a coal tar-containing shampoo. J Invest Dermatol 88:71–76.3794390
*Mersch-Sundermann V, Mochayedi S, Kevekordes S. 1992a. Genotoxicity of polycyclic aromatic hydrocarbons in Escherichia coli. Mutat Res 278(1):1–9.1370113
*Mersch-Sundermann V, Rosenkranz HS, Klopman G. 1992b. Structural basis of the genotoxicity of polycyclic aromatic hydrocarbons. Mutagenesis 7(3):211–218.1602977
*Metivier H, Wahrendorf J, Masse R. 1984. Multiplicative effect of inhaled plutonium oxide and benzo[a]pyrene on lung carcinogenesis in rats. Br J Cancer. 50:215–221.6087866
*Miguel AH, De Andrade JB. 1989. Rapid quantitation of ten polycyclic aromatic hydrocarbons in atmospheric aerosols by direct HPLC separation after ultrasonic acetonitrile extraction. Int J Environ Anal Chem 35(1):35–41.
*Mill T, Mabey W. 1985. Photochemical transformations. In: Neely W, Glau GE, eds. Environmental exposure from chemicals, Vol. I. Boca Raton, FL: CRC Press, Inc., 207.
*Miller MM, Plowchalk DR, Weitzman GA, . 1992. The effect of benzo(a)pyrene on murine ovarian and corpora lutea volumes. Am J Obstet Gynecol 166(5):1535–1541.1595809
*Mile GE, Blakeslee J, Yohn DS, . 1978. Biochemical activation of aryl hydrocarbon hydroxylase activity, cellular distribution of polynuclear hydrocarbon metabolites, and DNA damage by polynuclear hydrocarbon products in human cells in vitro. Cancer Res 38:1638–1644.417805
Miralis JC, Tyson CK, Butterworth BE. 1982. Detection of genotoxic carcinogens in the in vivo-in vitro hepatocyte DNA repair assay. Environ Mutagen 4:553–562.7140674
*Misfeld J. 1980. The tumor-producing effects of automobile exhaust condensate and of diesel exhaust condensate: Health effects of diesel engine emissions. Proceedings of an International Symposium. Cincinnati, OH: US Environmental Protection Agency. EPA 600/9-80-057b., 1012–1025.
Mishra NK, Wilson CM, Pant KJ, . 1978. Simultaneous determination of cellular mutagenesis and transformation by chemical carcinogens in Fischer rat embryo cells. J Toxicol Environ Health 4:79–91.633413
*Mitchell CE. 1979. A method for the determination of polycyclic aromatic hydrocarbons in animal tissue. Bull Environ Contam Toxicol 23:669–676.497480
Mitchell CE, Fischer JP, Dahl AR. 1987. Differential induction of cytochrome P-450 catalyzed activities by polychlorinated biphenyls and benzo[a]pyrene in B6C3F_l_ mouse liver and lung. Toxicology 43:315–323.3103261
*Modica R, Fiume M, Bartosek Z. 1982. Gas-liquid chromatographic assay of polycyclic aromatic hydrocarbon mixtures: Specifically modified method for rat tissues. J Chromatogr 24:352–355.
*Mall N, Chevrier S, Moll M. 1993. Determination and occurence of 3,4-benzo(a)pyrene in smoked fish and meat products. Dev Food Sci 32:233–245.
*Molliere M, Foth H, Kahl R, . 1987. Metabolism of benzo(a)pyrene in the combined rat liver-lung perfusion system. Toxicology 45:143–154.3603580
*Monarca S, Fagioli F. 1981. Evaluation of the potential carcinogenicity of paraffins for medicinal and cosmetic uses - determination of polycyclic aromatic hydrocarbons. Sci Total Environ 17:83–93.7209508
Monarca S, Sforzolini GS, Fagioli F. 1982. Presence of benzo(a)pyrene and other polycyclic aromatic hydrocarbons in suntan oils. Food Chem Toxicol 20: 183–187.6282719
*Monteith DK, Novotny A, Michalopoulos G, . 1987. Metabolism of benzo(a)pyrene in primary cultures of human hepatocytes: Dose-response over a four-log range. Carcinogenesis 8:983–988.3594730
*Moore BP, Hicks RM, Knowles MA, . 1982. Metabolism and binding of benzo[a]pyrene and 2 acetylamino fluorene by short-term organ cultures of human and rat bladder. Cancer Res 42:642–648.6275985
Moore CJ, Pruess-Schwartz D, Mauthe RJ, . 1987. Interspecies differences in the major DNA adducts formed from benzo(a)pyrene but not 7,12-dimethylbenz(a)anthracene in rat and human mammary cell cultures. Cancer Res 47:4402–4406.3111685
*Moore M, Wang X, Lu Y-F, . 1994. Benzo[a]pyrene-resistant MCF-7 human breast cancer cells. J Biol Chem 269(16):11751–11759.7909315
Morel G, Samhan 0, Literathy P, . 1991. Evaluation of chromatographic and spectroscopic methods for the analysis of petroleum-derived compounds in the environment. Fresenius’ J Anal Chem 339(10):699–715.
*Mori Y, Goto S, Onodera S, . 1993. Changes in mutagenic properties and chemical fate of benz(a)anthracene in chlorine-treated water with and without bromide ion. Chemosphere 27(11):2155–2162.
Morris JJ, Seifter E. 1992. The role of aromatic hydrocarbons in the genesis of breast cancer. Med Hypotheses 38(3):177–184.1513270
*Morris DL, Ward JB. 1992. Coumarin inhibits micronuclei formation induced by benzo(a)pyrene in male but not female ICR mice. Environ Mol Mutagen 19(2):132–138.1541254
Morris HP, Velat CA, Wagner BP, . 1960. Studies of carcinogenicity in the rat of derivatives of aromatic amines related to 0-2-fluorenylacetamide. J Natl Cancer Inst 24:149–180.14424329
Morse MA, Baird WM, Carlson GP. 1987. Distribution, covalent binding, and DNA adduct formation of 7,12- dimethylbenz(a)anthracene in Sencar and Balb/c mice following topical and oral administration. Cancer Res 47:4571–4575.2441852
*Morse MA, Carlson GP. 1985. Distribution and macromolecular binding of benzo[a]pyrene in sencar and balblc mice following topical and oral administration. J Toxicol Environ Health 16:263–276.2416943
*Morselli L, Zappoli S. 1988. PAH determination in samples of environmental interest. Sci Total Environ 73:257–266.3212457
Mossanda K, Poncelet F, Fouassin A, . 1979. Detection of mutagenic polycyclic aromatic hydrocarbons in African smoked fish. Food Cosmet Toxicol 17:141–143.383588
Moyer SR, Jurs PC. 1990. An SRA study of the mutagenicity of PAH compounds in Salmonella typhimurium. In: Mendelsohn ML, Albertini J, eds. Progress in clinical and biological research: Vol. 340. Mutation and the environment: Part B. Metabolism, testing methods, and chromosomes. New York, NY: Wiley-Liss, 1–10.
*Mueller JG, Lantz SE, Blattmann BO, . 1991. Bench-scale evaluation of alternative biological treatment processes for the remediation of pentachlorophenol- and cresote-contaminated materials: solid-phase bioremediation. Environ Sci Technol 25(6):1045–1055.
*Mukhtar H, Asokan P, Das M, . 1986. Benzo(a)pyrene diol epoxide-I-DNA adduct formation in the epidermis and lung of sencar mice following topical application of crude coal tar. Cancer Letters 33:287–394.3100019
*Mukhtar H, Das M, Khan WA, . 1988. Exceptional activity in tannic acid among naturally occurring plant phenols in protecteing against 7,12-dimethylbenz(a)anthracene-, benzo[a]pyrene-, 3-methylcholanthrene-, and N-methyl-N-nitrosourea-induced skin tumorigeneis in mice. Cancer Res 48:2361–2365.3128399
Mulik CM, Guyer MF, Semeniuk GM, . 1975. A gas liquid chromatographic fluorescent procedure for the analysis of benzo(a)pyrene in 24 hour atmospheric particulate samples. Anal Lett 8:511–524.
*Mullaart E, Buytenhek M, Brouwer A, . 1989. Genotoxic effects of intragastrically administered benzo[a]pyrene in rat liver and intestinal cells. Carcinogenesis 10(2):393–395.2912590
Muller J, Rohbock E. 1980. Method for measurement of polycyclic aromatic hydrocarbons in particulate matter in ambient air. Talanta 27:673–675.18962756
*Mumford JL, Williams RW, Walsh DB, . 1991. Indoor air pollutants from unvented kerosene heater emissions in mobile homes: Studies on particles, semivolatile organics, carbon monoxide, and mutagenicity. Environ Sci Technol 25:1732–1738.
*Mumford JL, Lee X, Lewtas J, . 1993. DNA adducts as biomarkers for assessing exposure to polycyclic aromatic hydrocarbons in tissues from Xuan Wei women with high exposure to coal combustion emissions and high lung cancer mortality. Environ Health Perspect 99:83–87.8319664
*Murray RW, Kong W. 1994. Activation of PAH by ozone derived oxidants: results at ambient conditions. Polycyclic Aromatic Hydrocarbons 5:139–147.
Myers SR, Flesher JW. 1991a. Characterization of hemoglobin (hb) adducts with polynuclear aromatic hydrocarbons. Proceedings of the Annual Meeting of the American Association for Cancer Research 32:A532.
Myers SR, Flesher JW. 1991b. Metabolism of chrysene, 5methylchrysene, 6-methylchrysene and .5,6-dimethylchrysene in rat liver cytosol, in vitro, and in rat subcutaneous tissue, in vivo. Chem Biol Interact 77(2):203–221.1991338
Myers MJ, Schook LB, Bick PH. 1987. Mechanisms of benzo[a]pyrene-induced modulation of antigen presentation. J Pharmacol Exp Ther 242:399–404.3497259
*Myers MJ, Blanton RH, Bick PH. 1988. Inhibition of IL-2 responsiveness following exposure to benzo(a)pyrene is due to alterations in accessory cell function. Int J Immunopharmacol 10:177–186.3131261
Nagabhushan M, Ng YK, Elias R, . 1990. Acute inhibition of DNA synthesis in hamster buccal pouch epithelium exposed to indirect acting carcinogens. Cancer Lett 53(2–3):163–173 2119880
*Nagata S, Kondo G. 1977. Photo-oxidation of crude oils. Proceedings of the 1977 Oil Spill Conference (prevention, behavior, cleanup, control):617–620.
*Naikwadi KP, Charbonneau GM, Karasek FW, . 1987. Separation and identification of organic compounds in air particulate extracts by high-performance liquid chromatography and gas chromatography-mass spectrometry. J Chromatogr 398:227–238.
*NAS. 1972. Particulate polycyclic organic matter. Washington, D.C: National Academy of Sciences, Division of Medical Science, National Research Council, 28–81.
NAS. 1986. Drinking-water and health. Vol. 6. Washington, D.C: National Academy Press, 139–145.
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
Naslund I, Rubio CA, Auer GU. 1987. Nuclear DNA changes during pathogenesis of squamous carcinoma of the cervix in 3,4-benzopyrene-treated mice. Anal Quant Cytol Histol 9:411–418.3675800
NATICH. 1988. National Air Toxics Information Clearinghouse. Report on state, local, and EPA air toxics activities. US Environmental Protection Agency, Office of Air Quality Planning and Standards, Research Triangle Park, NC. July 1988.
*NATICH. 1992. National Air Toxics Information Clearinghouse. Report on state, local, and EPA air toxics activities. US Environmental Protection Agency, Office of Air Quality Planning and Standards, Research Triangle Park, NC. December 1992.
*Neal J, Rigdon RH. 1967. Gastric tumors in mice fed benzo[a]pyrene: A quantitative study. Tex Rep Biol Med 25:553–557.6082228
*Neff JM. 1979. Polycyclic aromatic hydrocarbons in the aquatic environment - sources, fates and biological effects. London, England: Applied Science Publishers, Ltd.
*Neff JM. 1982. Accumulation and release of polycyclic aromatic hydrocarbons from water, food, and sediment by marine animals. Symposium: Carcinogenic polynuclear aromatic hydrocarbons in the marine environment. Washington, D.C: US Environmental Protection Agency. Report no. 600/9-82-013.
Nettesheim P, Griesemer RA, Martin DH, . 1977. Induction of preneoplastic and neoplastic lesions in grafted rat tracheas continuously exposed to benzo(a)pyrene. Cancer Res 37:1272–1278.856459
*Neubert D, Tapken S. 1988. Transfer of benzo(a)pyrene into mouse embryos and fetuses. Arch Toxicol 62(2–3):236–239.3196162
*Newman MJ, Light BA, Weston A, . 1988. Detection and characterization of human serum antibodies to polycyclic aromatic hydrocarbon diol-epoxide DNA adducts. J Clin Invest (United States) 82:145–153.
*Newman MJ, Weston A, Carver DC, . 1990. Serological characterization of polycyclic aromatic hydrocarbon diolepoxide-DNA adducts using monoclonal antibodies. Carcinogenesis 11(11):1903–1907.2225321
*Ng KM, Chu I, Bronaugh RL, . 1991. Percutaneous absorption/metabolism of phenanthrene in the hairless guinea pig: Comparison of in vitro and in vivo results. Fundam Appl Toxicol 16(3):517–524.1855623
*Ng KM, Chu I, Bronaugh RL, . 1992. Percutaneous absorption and metabolism of pyrene, benzo[a]pyrene, and di(2-ethylhexyl) phthalate: comparison of in vitro and in vivo results in the hairless guinea pig. Toxicol Appl Pharmacol 115(2):216–223.1641855
*Nie S, Dadoo R, Zare RN. 1993. Ultrasensitive fluorescence detection of polycyclic aromatic hydrocarbons in capillary electrophoresis. Anal Chem 65:3571–3575.
*Nielsen PA, Grove A, Olsen H. 1993. The influence of fuel type on the emission of PAH and mutagenic activity from small wood stoves. In: The Thirteenth Polycyclic Aromatic Hydrocarbons Conference Proceedings. 993–1000.
*Nielsen T. 1979. Determination of polycyclic aromatic hydrocarbons in automobile exhaust by means of high-performance liquid chromatography with fluorescence detection. J Chromatogr 170:147–156.
*Niimi AJ. 1987. Biological half-lives of chemicals in fishes. Rev Environ Contam Toxicol. Vol. 99. New York, NY: Springer-Verlag, 1–46.
*Nikonova TV. 1977. The transplacental effect of benzo(a)pyrene and pyrene. Byull Eksp Biol Med 84:1025–1027.
*NIOSH. 1976. National occupational hazard survey (1970). US Department of Health and Human Services, National Institute for Occupational Safety and Health, Cincinnati, OH.
NIOSH. 1977. Criteria for a recommended standard: Occupational exposure to coal tar products. US Department of Health and Human Services, Department of Health and National Institute for Occupational Safety and Health, Cincinnati, OH.
*NIOSH. 1984. National occupational hazard survey (1980-1983). US Department of Health and Human Services, National Institute for Occupational Safety and Health, Cincinnati, OH.
*NIOSH. 1985. Pocket guide to chemical hazards. Washington, D.C.: US Department of Health and Human Services, National Institute for Occupational Safety and Health, 84.
*NIOSH. 1990. National Occupational Exposure Survey 1981-83. U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health, Cincinnati, Ohio.
*NIOSH. 1992. NIOSH recommendations for occupational safety and health: Compendium of policy documents and statements. Cincinnati, OH: U.S. Department of Health and Human Services, 64.
*Nirmalakhandan NN, Speece RE. 1988. QSAR model for predicting Henry’s constant. Environ Sci Technol 22:1349–1357.
*Nisbet ICT, LaGoy PK. 1992. Toxic equivalency factors (TEFs) for polycyclic aromatic hydrocarbons (PAHs). Reg Toxicol Pharmacol 16:290–300.
*NJDEP. 1991. State primary drinking water regulations. Trenton, NJ: New Jersey Department of Environmental Protection. Chapter 10, Subchapter 5,7:10–5.1.
*NOAA. 1989. A summary of data on tissue contamination from the first three years (1986-1988) of the Mussel Watch Program. NOAA Technical Memorandum NOS OMA 49, Rockville, MD: National Oceanic and Atmospheric Administration.
Norpoth K, Kemena A, Jacob J, . 1984. The influence of 18 environmentally relevant polycyclic aromatic hydrocarbons and Clophen A50, as liver monooxygenase inducers, on the mutagenic activity of benz(a)anthracene in the Ames test. Carcinogenesis 5:747–752.6426814
*Nousiainen U, Torronen R, Hanninen 0. 1984. Differential induction of various carboxylesterases by certain polycyclic aromatic hydrocarbons in the rat. Toxicology 32:243–251.6089379
*Nowak D, Meyer A, Schmidt-Preuss U, . 1992. Formation of benzo[a]pyrene-DNA adducts in blood monocytes from lung cancer patients with a familial history of lung cancer. J Cancer Res Clin Oncol 118(1):67–71.1309533
*NRC. 1983. Polycyclic aromatic hydrocarbons: Evaluation of sources and effects. Washington, D.C.: National Research Council, National Academy Press, ES/1–ES/7.
*NRC. 1989a. Biologic markers in reproductive toxicology. National Research Council. Washington, DC: National Academy Press.
*NRC. 1989b. Biologic markers in pulmonary toxicology. National Research Council. Washington, DC: National Academy Press.
*NRC. 1992a. Biological markers in pulmonary immunotoxicology. National Research Council. Washington, DC: National Academy Press.
*NRC. 1992b. Biological markers in pulmonary neurotoxicology. National Research Council. Washington, DC: National Academy Press.
NRC. 1995. Biologic markers in urinary toxicology. National Research Council. Washington, DC: National Academy Press.
NREPC. 1991. Acceptable ambient limits and significant emission levels of toxic air pollutants. Frankfurt, KY: Kentucky Natural Resources and Environmental Protection Cabinet. 401 KAR 63:022.
*NTDB. 1994. The National Trade Data Bank. Washington, DC: U.S. Department of Commerce, Economics and Statistics Administration (CD-ROM).
*NYSDEC. 1994. Water quality standards: surface waters and groundwaters. Albany, NY: New York State Department of Environmental Conservation. Chapter X, Section 703.5.
O’Donovan MR. 1990. Mutation assays of ethyl methanesulphonate, benzidine and benzo[a]pyrene using Chinese hamster V79 cells. Mutagenesis 5:9–13.2184328
O’Gara RW, Kelly MG, Brown J, . 1965. Induction of tumors in mice given a minute single dose of dibenz[a,h]anthracene or 3-methylcholanthrene as newborns: A dose-response study. J Natl Cancer Inst 35(6):1027–1042.5856679
O’Neill IK, Bingham S, Povey AC, . 1990a. Modulating effects in human diets of dietary fibre and beef, and of time and dose on the reactive microcapsule trapping of benzo[a]pyrene metabolites in the rat gastrointestinal tract. Carcinogenesis 11(4):599–607.2157556
O’Neill IK, Povey AC, Bingham S, . 1990b. Systematic modulation by human diet levels of dietary fibre and beef on metabolism and disposition of benzo[a]pyrene in the gastrointestinal tract of Fischer F344 rats. Carcinogenesis 11(4):609–616.2157557
*O’Neill IK, Goldberg MT, El Ghissassi F, . 1991. Dietary fiber, fat and beef modulation of colonic nuclear aberrations and microcapsule-trapped gastrointestinal metabolites of benzo(a)pyrene-treated C57/B6 mice consuming human diets. Carcinogenesis 12(2):175–180.1847318
*O’Neill HJ, Pollock TL, Brun GL, . 1992. Toxic chemical survey of municipal drinking water sources in Atlantic Canada 1985-1988. Water Poll Res J Canada 27(4):715–732.
*Obana H, Hori S, Kashimoto T, . 1981. Polycyclic aromatic hydrocarbons in human fat and liver. Bull Environ Contam Toxicol 27:23–27.7296033
*Oehme M. 1983. Determination of isomeric polycyclic aromatic hydrocarbons in air particulate matter by high-resolution gas chromatography negative ion chemical ionization mass spectrometry. Anal Chem 55:2290–2295.
Oesch F, Golan M. 1980. Specificity of mouse liver cytosolic epoxide hydrolase for K-region epoxides derived from polycyclic aromatic hydrocarbons. Cancer Lett 9:169–175.7226148
Oesch F, Bucker M, Glatt HR. 1981. Activation of phenanthrene to mutagenic metabolites and evidence for at least two different activation pathways. Mut Res 81:1–10.7019683
Ogan K, Katz E, Slavin W. 1979. Determination of polycyclic aromatic hydrocarbons in aqueous samples by reversed-phase liquid chromatography. Anal Chem 51: 315–320.
*Ogawa I, Junk GA, Svec HJ. 1982. Degradation of aromatic compounds in groundwater, and methods of sample preparation. Talanta 28:725–730.
*Old LJ, Benacerraf B, Carswell E. 1963. Contact reactivity to carcinogenic polycyclic hydrocarbons. Nature 198:1215–1216.13939925
*OSHA. 1974. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000.
*OSHA. 1983. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1002.
*OSHA. 1985. Coal tar pitch volatiles; interpretation of term. US Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1002.
*OSHA. 1990. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1450.
Ostman CE, Colmsjo AL, Zebuehr Y. 1986. Polycyclic aromatic compounds in lubricating oil: A study of gasoline, gasoline/methanol, gas and diesel fueled engines. In: Cooke M, Dennis AJ, eds. Polycyclic aromatic hydrocarbons: Chemistry, characterization, and carcinogenesis. Proceedings of the Ninth International Symposium. Columbus, OH: Battelle Press, 729–744.
*OTA. 1990. Neurotoxicology: Identifying and controlling poisons of the nervous system. Office of Technology Assessment, Washington, DC. OTA-BA-438.
*Oueslati R, Alexandrov K, Chouikha M, . 1992. Formation and persistence of DNA adducts in epidermal and dermal mouse skin exposed to benzo(a)pyrene in vivo. In vivo 6(2):231–235.1525345
*Ovrebo S, Haugen A, Fjeldstad PE, . 1994. Biological monitoring of exposure to polycyclic aromatic hydrocarbon in an electrode paste plant. J Occup Med 36(3):303–310.8195900
*Oyler AR, Bodenner DL, Welch KJ, . 1978. Determination of aqueous chlorination reaction products of polynuclear aromatic hydrocarbons by reversed phase high performance liquid chromatography-gaschromatography. Anal Chem 50:837–842.
Pahlman R, Pelkonen O. 1987. Mutagenicity studies of different polycyclic aromatic hydrocarbons: The significance of enzymatic factors and molecular structure. Carcinogenesis 8:773–778.3301044
*Palitti F, Cozzi R, Fiore M, . 1986. An in vitro and in vivo study on mutagenic activity of fluoranthene: Comparison between cytogenetic studies and HPLC analysis. Mutat Res 174: 125–130.3713730
Pallardy M, Mishal Z, Lebrec H, . 1992. Immune modification due to chemical interference with transmembrane signalling: Application to polycyclic aromatic hydrocarbons. Int J Immunopharmacol 14(3):377–382.1319963
*Pankow JF, Storey JME, Yamasaki H. 1993. Effects of relative humidity on gas/particle partitioning of semivolatile organic compounds to urban particulate matter. Environ Sci Technol 27(10):2220–2226.
*Panthanickal A, Marnett LJ. 1981. Arachidonic acid-dependent metabolism of (+/−)-7,8-dihydroxy-7,8- dihydrobenzo[a]pyrene to polyguanylic acid-binding derivatives. Chem Biol Interact 33:239–252.7193097
Park JK, Park SD. 1988. Effects of benzo(a)pyrene on dna strand breaks and replication in the presence of metabolic activation system in mammalian cells. Korean J Genetics 10(4):279–287.
*Park KS, Sims RC, DuPont RR, . 1990. The fate of PAH compounds in two soil types influence of volatilization abiotic loss and biological activity. Environ Toxicol Chem 9(2):187–196.
*Pavanello S, Levis AG. 1992. Coal tar therapy does not influence in vitro benzo[a]pyrene metabolism and DNA adduct formation in peripheral blood lymphocytes of psoriatic patients. Carcinogenesis 13:1569–1573.1394841
*Payne. 1958. The pathological effects of the intraperitoneal injection of 3:4-benzopyrene into rats and mice. Br J Cancer 12:65–74.13536216
*Penn A, Snyder C. 1988. Arteriosclerotic plaque development is ‘promoted’ by polynuclear aromatic hydrocarbons. Carcinogenesis 9(12):2185–2189.3142695
*Perera FP, Hemminki K, Young TL, . 1988. Detection of polycyclic aromatic hydrocarbon-DNA adducts in white blood cells of foundry workers. Cancer Res 48:2288–2291.3127049
*Perera FP, Tang DL, O’Neill JP, . 1988. HPRT and glycophorin A mutations in foundry workers: relationship to PAH exposure and to PAH-DNA adducts. Carcinogenesis 14(5):969–973.
*Pershagen GG, Nordberg G, Bjorklund NE. 1984. Carcinomas of the respiratory tract in hamsters given arsenic trioxide and/or benzo[a]pyrene by the pulmonary route. Environ Res 34:227–241.6086305
*Perwak J, Byrne M, Coons S, . 1982. An exposure and risk assessment for benzo[u]pyrene and other polycyclic aromatic hydrocarbons. Volume IV. Benzo[u]pyrene, acenaphthylene, benz[a]anthracene, benzo[b]fluoranthene, benzo[k]fluroanthene, benzo[g,h,i]perylene, chrysene, dibenz[u,h]anthracene, and indeno[1,2,3-c,apyrene. Washington, D.C.: US Environmental Protection Agency, Office of Water Regulations and Standards. EPA 440/4-85-020-V4.
Peterson AR, Landolph JR, Peterson H, . 1981. Oncogenic transformation and mutation of C3W10T1/2 clone 8 mouse embryofibroblasts by alkylating agents. Cancer Res 41:3095–3099.7248967
*Petridou-Fischer J, Whaley SL, Dahl AR. 1988. In vivo metabolism of nasally instilled benzo(a)pyrene in dogs and monkeys. Toxicology 48(1):31–40.3336881
*Pfeiffer EH. 1977. Oncogenic interaction of carcinogenic and non-carcinogenic polycyclic aromatic hydrocarbons in mice: IARC Scientific Publication No. 16. Air pollution and cancer in man. Lyon, France: International Agency for Research on Cancer, 69–77.
*Pham T, Lum K, Lemieux C. 1993. Sources of PAHs in the St. Lawrence River (Canada) and their relative importance. Chemosphere 27(7):1137–1149.
*Phillips DH, Hewer A, Grover PE. 1987. Formation of DNA adducts in mouse skin treated with metabolites of chrysene. Cancer Res 35:207–214.
*Phillips DH, Hemminki K, Alhonen A, . 1988. Monitoring occupational exposure to carcinogens: Detection by 32P-postlabelling of aromatic DNA adducts in white blood cells from iron foundry workers. Mutat Res 204:531–541.3347220
Phillips DH, Hewer A, Seidel A, . 1991. Relationship between mutagenicity and DNA adduct formation in mammalian cells for fjord- and bay-region diol-epoxides of polycyclic aromatic hydrocarbons. Chem Biol Interact 1991 80(2):177–186.
*Phillipson CE, Ioannides C. 1989. Metabolic activation of polycyclic aromatic hydrocarbons to mutagens in the Ames test by various animal species including man. Mutat Res Mar 211(1):147–151.
*Pitt R, Lalor M, Field R, . 1993. The investigation of source area controls for the treatment of urban stormwater toxicants. Water Sci Technol 28(3–5):271–282.
*Platt ISL, Pfeiffer E, Petrovic P, . 1990. Comparative tumorigenicity of picene and dibenz[a,h]anthracene in the mouse. Carcinogenesis 11(10):1721–1726.2208587
*Plumb RH, Jr. 1991. The occurence of appendix IX organic constituents in disposal site ground water. Ground Water Monitoring Revue 11:157–164.
Pollia JA. 1941. Investigation on the possible carcinogenic effect of anthracene and chrysene and some of their compounds: II. The effect of subcutaneous injection in rats. J Ind Hyg Toxicol 223:449–451.
*Poole SK, Dean TA, Poole CF. 1987. Preparation of environmental samples for the determination of polycyclic aromatic hydrocarbons by thin-layer chromatography. J Chromatogr 400:323–341.2444609
Popescu NC, Tumbull D, DiPaolo JA. 1977. Sister chromatid exchange and chromosome aberration analysis with the use of several carcinogens and noncarcinogens. J Natl Cancer Inst 59:289–293.406414
*Popl M, Stejskal M, Mostecky J. 1975. Determination of polycyclic aromatic hydrocarbons in white petroleum products. Anal Chem 47:1947–1950.1190458
*Pothuluri JV, Freeman JP, Evans FE, . 1993. Biotransformation of fluorene by the fungus Cunninghamella elegans. Appl Environ Microbial 59(6):1977–1980.
Pott P. 1775. Surgical observations relative to the cancer of the scrotum. London. Reprinted in Natl Cancer Institute Monographs 10:7–13. 1973.
*Pott F, Tomingas R, Misfeld J. 1977. Tumors in mice after subcutaneous injection of automobile exhaust condensates. In: Mohr U, Schmaehl D, Tomatis L, eds. IARC Scientific Publication No. 16: Air pollution and cancer in man. Hanover, West Germany: Scientific Publications, 79–87.
*Prahl FG, Crecellus E, Carpenter R. 1984. Polycyclic aromatic hydrocarbons in Washington (USA) coastal sediments: An evaluation of atmospheric and riverine routes of introduction. Environ Sci Technol 18:687–693.
*Prasanna P, Jacobs MM, Yang SK. 1987. Selenium inhibition of benzo(a)pyrene, 3-methylcholanthrene, and 3-methylcholanthrylene mutagenicity in Salmonella typhimurium strains TA98 and Ta100. Mutat Res 190:101–105.3547113
Propper R. 1988. Polycyclic aromatic hydrocarbons (PAH): A candidate toxic air contaminant. Stationary Source Div, California State Air Resources Board, Sacramento, CA.
*Pucknat AW, ed. 1981. Characteristics of PNA in the environment: Health impacts of polynuclear aromatic hydrocarbons. Park Ridge, NJ: Noyes Data Corporation, 78–122.
*Purde M, Etlin S. 1980. Cancer cases among workers in the Estonia oil shale processing industry: Health implications of new energy technologies. Ann Arbor, MI: Ann Arbor Science, 527–528.
Quarles JM, Sega MW, Schenley CK, . 1979. Transformation of hamster fetal cells by nitrosated pesticides in a transplacental assay. Cancer Res 39:4525–4533.498084
*Quilliam MA, Sim PG. 1988. Determination of polycyclic aromatic compounds by high-performance liquid chromatography with simultaneous mass spectrometry and ultraviolet diode array detection. J Chromatogr Sci 26:160–167.3379121
*Radding SB, Mill T, Gould CW, . 1976. The environmental fate of selected polynuclear aromatic hydrocarbons. Washington, D.C: US Environmental Protection Agency, Office of Toxic Substances. EPA 560/5-75-009.
*Rahimtula AD. 1977. The effects of antioxidants of the metabolism and mutagenicity of benzo[a]pyrene in vitro. Biochem J 164:473–475.328015
*Rahman A, Barrowman JA, Rahimtula A. 1986. The influence of bile on the bioavailability of polynuclear aromatic hydrocarbons from the rat intestine. Can J Physiol Pharmacol 64:1214–1218.3096546
*Ramdahl T, Alfheim I, Bjorseth A. 1982. Nitrated polycyclic aromatic-hydrocarbons in urban air particles. Environ Sci Technol 16:861–865.22236263
Ranadine KJ, Karande KA. 1963. Studies on 1,2,5,6-dibenzanthracene-induced mammary carcinogenesis in mice. Br J Cancer 17:272.14042729
*Rao KP, Nandan BD. 1990. Modification of benzo(a)pyrene induced chromosomal damage in mouse bone marrow by vitamin A. Bull Environ Contam Toxicol 45(6):829–832.2279131
*Rao KP, Ramadevi G, Das UN. 1986. Vitamin A can prevent genetic damage induced by benzo(a)pyrene to the bone marrow cells of mice. Int J Tissue React 8:219–223.3781761
Rastetter WH, Nachbar RBJ, Russo-Rodriguez S, . 1982. Fluoranthene: Synthesis and mutagenicity of 4 diol epoxides. J Org Chem 47:4873–4878.
*Readman JW, Mantourar RFC, Rhead MM, . 1982. Aquatic distribution and heterotrophic degradation and polycyclic aromatic hydrocarbons in the Tamar Estuary, England, UK. Estuarine Coastal Shelf Sci 14:369–389.
*Redmond E, Strobino B, Cypress R. 1976. Cancer experience among coke by-product workers. Ann NY Acad Sci 2–7:102–115.
Rees ED, Mandelstan P, Lowry JQ, . 1971. A study of the mechanism of intestinal absorption of benzo[a]pyrene. Biochim Biophys Acta 225:96–107.5543579
Reynders JBJ, Immel HR, Scherrenberg PM, . 1985. Respiratory tract tumors in hamsters after severe focal injury to the trachea and intratracheal instillation of benzo(a)pyrene. Cancer Lett 29:93–99.4063958
Rhodes G, Opsal RB, Meek JT, . 1983. Analysis of polycyclic aromatic hydrocarbon mixtures with laser ionization gas chromatography/mass spectrometry. Anal Chem 55:280–286.
*Rice JE, Hosted TJJ, Lavoie EJ. 1984. Fluoranthene and pyrene enhance benzo(a)pyrene-DNA adduct formation in vivo in mouse skin. Cancer Lett 24:327–333.6437667
*Rice JE, Coleman DT, Hosted TJJ, . 1985a. Identification of mutagenic metabolites of indeno[1,2,3-cd] pyrene formed in vitro with rat liver enzymes. Cancer Res 45:5421–5425.4053016
*Rice JE, Coleman DT, Hosted TJJ, . 1985b. On the metabolism, mutagenicity, and tumor-initiating activity of indeno(1,2,3-cd)pyrene. In: Cooke M, Dennis AJ, eds. Polynuclear aromatic hydrocarbons: Metabolisms, methods and metabolism. Proceedings of the Eighth International Symposium. Columbus, OH: Battelle Press, 1097–1109.
*Rice JE, Hosted TJ, DeFloria MC, . 1986. Tumor-initiating activity of major in-vivo metabolites of indeno-1 2 3 -cd-pyrene on mouse skin. Carcinogenesis 7(10):1761–1764.3757177
*Rice JE, Geddie NG, Lavoie EJ. 1987a. Identification of metabolites of benzo[j]fluoranthene formed in vitro in rat liver homogenate. Chem Biol Interact 1987 63(3):227–237.
*Rice JE, Weyand EH, Geddie NG, . 1987b. Identification of tumorigenic metabolites of benzo[j]fluoranthene formed in vivo in mouse skin. Cancer Res 47(23):6166–6170.3677067
*Rice JE, Defloria MC, Sensenhauser C, . 1988. The influence of fluoranthene on the metabolism and DNA binding of benzo[a]pyrene in vivo in mouse skin. Chem Biol Interact 1988 68(1–2):127–136.3203403
Rice JW, Weyand EH, Burrill C, . 1990. Fluorine probes for investigating the mechanism of activation of indeno(1,2,3-cd)pyrene to a tumorigenic agent. Carcinogenesis 11(11):1971–1974.2225328
*Rice DW, Seltenrich CP, Spies RB, . 1993. Seasonal and annual distribution of organic contaminants in marine sediments from Elkhom Slough, Moss Landing Harbor and Nearshore Monteray Bay, California. Environ Poll 82:79–94.
*Richardson JH, Ando ME. 1977. Sub-part-per-trillion detection of polycyclic aromatic hydrocarbons by laser induced molecular fluorescence. Anal Chem 49:955–959.860839
Richter-Reichhelm HB, Emura M, Althoff J. 1985. Scanning electron microscopical investigations on the respiratory epithelium of the Syrian golden hamster: VI. In vitro effects of different polycyclic aromatic hydrocarbons. Zentralbl Bakteriol Mikrobiol Hyg [B] 181(3–5):272–280.
Riegel B, Watman WB, Hill WT. 1951. Delay of methylcholanthrene skin carcinogenesis in mice by 1,2,5,6- dibenzofluorene. Cancer Res 11:301–306.14831069
*Rigdon RH, Giannukos NJ. 1964. Effect of carcinogenic hydrocarbons on growth of mice. Arch Pathol 77: 198–204.14088764
*Rigdon RH, Neal J. 1965. Effects of feeding benzo[a]pyrene on fertility, embryos, and young mice. J Natl Cancer Inst 34:297–305.14293795
*Rigdon RH, Neal J. 1966. Gastric carcinomas and pulmonary adenomas in mice fed benzo[a]pyrene. Tex Rep Biol Med 24:195–207.5962243
*Rigdon RH, Neal J. 1969. Relationship of leukemia to lung and stomach tumors in mice fed benzo[a]pyrene. Proc Sot Exp Biol Med 130:146–148.
*Rigdon RH, Rennels EG. 1964. Effect of feeding benzpyrene on reproduction in the rat. Experimentia 20:224–226.
*Risner CH. 1988. The determination of benzo(a)pyrene in the total particulate matter of cigarette smoke. J Chromatogr Sci 26: 113–125.3360893
Robinson DE, Mitchell AD. 1981. Unscheduled DNA synthesis response of human fibroblasts, WI-38 cells, to 20 coded chemicals: Evaluation of short-term tests for carcinogenesis: Report of the International Collaborative Program. Prog Mutat Res 1:517–527.
*Robinson JR, Felton JS, Levitt RC, . 1975. Relationship between “aromatic hydrocarbon responsiveness” and the survival times in mice treated with various drugs and environmental compounds. Mol Pharmacol 11:850–865.54870
Rocchi P, Ferreri AM, Borgia R, . 1980. Polycyclic hydrocarbons induction of diptheria toxin-resistant mutants in human cells. Carcinogenesis 1:765–767.11219867
Roe FJC. 1962. Effect of phenanthrene on tumour-initiation by 3,4-benzpyrene. Br J Cancer 16:503–506.13982333
*Rogan EG, RamaKrishna NVS, Higginbotham S, . 1990. Identification and quantitation of 7-(benzo(a)pyren-6-yl)guanine in the urine and feces of rats treated with benzo(a)pyrene. Chem Res Toxicol 3(5):441–444.2133095
*Rogge WF, Hildemann LM, Mazurek MA, . 1993a. Sources of fine organic aerosol. 2. Noncatalyst and catalyst-equipped automobiles and heavy-duty diesel trucks. Environ Sci Technol 27:636–651.
*Rogge WF, Hildemann LM, Mazurek MA, . 1993b. Sources of fine organic aerosol. 5. Natural gas home appliances. Environ Sci Technol 27:2736–2744.
*Rogge WF, Hildemann LM, Mazurek MA, . 1993c. Sources of fine organic aerosol. 3. Road dust, tire debris, and organometallic brake lining dust: roads as sources and sinks. Environ Sci Technol 27: 1892–1904.
*Rogge WF, Hildemann LM, Mazurek MA, . 1993d. Sources of fine organic aerosol. 4. Particulate abrasion products from leaf surfaces of urban plants. Environ Sci Technol 27:2700–2710.
*Roggeband R, Wolterbeek APM, Melis OWM, . 1994. DNA adduct formation and repair in hamster and rat tracheas exposed to benzo[a]pyrene in organ culture. Carcinogenesis 15(4):661–665.8149477
*Rosenfeld JK, Plumb RH. 1991. Ground water contamination at wood treatment facilities. Ground Water Monit Rev 11(1):133–140.
Rosenkranz HS, Poirier LA. 1979. Evaluation of the mutagenicity and DNA-modifying activity of carcinogens and noncarcinogens in microbial systems. J Natl Cancer Inst 62:873–892.372656
*Ross J, Nelson G, Erexson G, . 1991. DNA adducts in rat lung, liver and peripheral blood lymphocytes produced by i.p. administration of benzo[a]pyrene metabolites and derivatives. Carcinogenesis 12(10):1953–1955.1934277
*Ross J, Nelson G, Kligerman A, . 1990. Formation and persistence of novel benzo(a)pyrene adducts in rat lung, liver, and peripheral blood lymphocyte DNA. Cancer Res 50(16):5088–5094.2199033
*Ross JA, Nelson GB, Holden KL, . 1992. DNA adducts and induction of sister chromatid exchanges in the rat following benzo[b]fluoranthene administration. Carcinogenesis 13: 1731–1734.1423831
*Rossi L, Barbieri O, Sanguineti M, . 1983. Carcinogenic activity of benzo(a)pyrene and some of its synthetic derivatives by direct injection into the mouse fetus. Carcinogenesis 4:153–156.6297822
*Roszinsky-Kocher G, Basler A, Rohrbom G. 1979. Mutagenicity of polycyclic hydrocarbons: V. Induction of sister-chromatid exchanges in vivo. Mutat Res 66(1):65–67.423906
*Ruby JC, Halliday GM, Muller HK. 1989. Differential effects of benzo[a]pyrene and dimethylbenz[a]-anthracene on Langerhans cell distribution and contact sensitization in murine epidermis. J Invest Dermatol 92(2):150–155.2493054
Rudo KM, Dauterman WC, Langenbach R. 1989. Human and rat kidney cell metabolism of 2-acetylaminofluorene and benzo(a)pyrene. Cancer Res 49(5): 1187–1192.2917350
Rugen PJ, Stem CD, Lamm SH. 1989. Comparative carcinogenicity of the pahs as a basis for acceptable exposure levels aels in drinking water. Regul Toxicol Pharmacol 9(3):273–283.2756174
Russell LB. 1977. Validation of the in vivo somatic mutation method in the mouse as a prescreen for germinal point mutations. Arch Toxicol 38:75–85.578717
*Saber A, Morel G, Paturel L, . 1991. Application of the high-resolution low temperature spectrofluorometry to analysis of PAHs in lake sediments marine intertidal sediments and organisms. Fresenius’ J Anal Chem 339(10):716–721.
*Saboori AM, Newcombe DS. 1992. Environmental chemicals with immunotoxic properties. In: Newcombe DS, Rose NR, Bloom JC, eds. Clinical immunotoxicology. New York, NY: Raven Press, 36.5400.
*Sadhana AS, Rao AR, Kucheria K, . 1988. Inhibitory action of garlic oil on the initiation of benzo(a)pyrene-induced skin carcinogenesis in mice. Cancer Lett 40:193–197.3383177
*Saffiotti U, Montesane R, Sellakumar AR, . 1972. Respiratory tract carcinogenesis induced in hamsters by different dose levels of benzo[a]pyrene and ferric oxide. J Natl Cancer Inst 49:1199–1204.5084126
Sajewicz M, Rzepa J, Sliwiok J. 1988. Determination of benzo(a)pyrene in coke tars. J Chromatogr 456(1):227–231.3243867
Sakai M, Yoshida D, Mizusaki S. 1985. Mutagenicity of polycyclic aromatic hydrocarbons and quinones on Salmonella typhimurium TA97. Mutat Res 156:61–67.3889628
*Salaman MH, Roe FJC. 1956. Further tests for tumour-initiating activity: N,N-di(2-chloroethyl)-paminophenylbutic acid (CB1348) as an initiator of skin tumour formation in the mouse. Br J Cancer 10:363–378 (Retrieval in progress).13364128
*Salamone MF 1981. Toxicity of 41 carcinogens and noncarcinogenic analogs. Prog Mutat Res. 1:682–685.
*Salamone MF, Chiu S, Logan DM. 1988. Abnormal sperm test results for benzo(a)pyrene, pyrene, 2-acetylaminofluorene, and 4-acetylaminofluorene using both hybrid and outbred mice: Part 2. Gavage treatment: Evaluation of short-term tests for carcinogenicity. Report of the International Program for Chemical Safety’s Collaborative Study 2:243–250.
*Salhab AS, James MO, Wang SL, . 1987. Formation of benzo(a)pyrene-DNA adducts by microsomal enzymes: Comparison of maternal and fetal liver, fetal hematopoietic cells and placenta. Chem Biol Interact (Ireland) 61:203–214.
*Sanders CL, Skinner C, Gelman RA. 1986. Percutaneous absorption of 7,10 ^14^C-benzo[a]pyrene and 7,12 ^14^C- dimethylbenz[a]anthracene in mice. J Environ Pathol Toxicol Oncol 7:25–34.3098955
*Santella RM, Hemminki K, Tang D-L, . 1993. Polycyclic aromatic hydrocarbon-DNA adducts in white blood cells and urinary 1-hydroxypyrene in foundry workers. Cancer Epidemiology, Biomarkers & Prevention 2:59–62.
*Santodonato J. 1981. Polycyclic organic matter. J Environ Pathol Toxicol 5:1–364.7310260
*Sanyal MK, Li Y-L, Biggers WJ, . 1993. Augmentation of polynuclear aromatic hydrocarbon metabolism of human placental tissues of first-trimester pregnancy by cigarette smoke exposure. Am J Obstet Gynecol 168(5):1587–1597.8498447
*Sawicki E. 1962. Analysis for airborne particulate hydrocarbons: Their relative proportions as affected by different types of pollution. Bethesda, MD: National Cancer Institute Monograph No. 9, 201–220.
*Sax NI, Lewis RS. 1989. Dangerous properties of industrial materials. 7th ed. New York, NY: Van Nostrand Reinhold.
Schimberg RW. 1981. Polycyclic aromatic hydrocarbons (PAH) in the work environment. Kern - Kemi 8 537–541.
*Schmahl D, Schmidt KG, Habs M. 1977. Syncarcinogenic action of polycyclic aromatic hydrocarbons in automobile exhaust gas condensates. In: Mohr U, Schmahl D, Tomatis L, eds. Air pollution and cancer in man. IARC publication 16. Lyon, France: World Health Organization.
*Schnizlein CT, Munson AE, Rhoades RA. 1987. Immunomodulation of local and systemic immunity after subchronic pulmonary exposure of mice to benzo(a)pyrene. Int J Immunopharmacol 9:99–106.3583505
*Schoket B, Doty WA, Vincze I, . 1993. Increased sensitivity for determination of polycyclic aromatic hydrocarbon-DNA adducts in human DNA samples by dissociation-enhanced lanthanide fluoroimmunoassay (DELFIA). Cancer Epidemiology, Biomarkers & Prevention 2:349–353.
*Schulte A, Ernst H, Peters L, . 1993. Induction of squamous cell carcinomas in the mouse lung after long-term inhalation of polycyclic aromatic hydrocarbon-rich exhausts. Exp Toxicol Pathol 45:415–421.
Sega GA. 1979. Unscheduled DNA synthesis (DNA repair) in the germ cells of male mice - its role in the study of mammalian mutagenesis. Genetics 92:49–58.17248926
Selkirk JK, Huberman E, Heidelberger C. 1971. An epoxide is an intermediate in the microsomal metabolism of the chemical carcinogen, dibenz(a,h)anthracene. Biochem Biophys Res Commun 43(5):1010–1016.4398130
Sellakumar A, Shubik P. 1974. Carcinogenicity of different polycyclic hydrocarbons in the respiratory tract of hamsters. J Natl Cancer Inst 53:1713–1719.4436869
Sellakumar A, Stenback F, Rowland J. 1976. Effects of different dusts on respiratory carcinogenesis in hamsters induced by benzo[a]pyrene and diethylnitrosamine. Europ J Cancer 12:313–319.
*Seto H, Ohkubo T, Kanoh T, . 1993. Determination of polycyclic aromatic hydrocarbons in the lung. Arch Environ Contam Toxicol 24:498–503.8507106
*Severson RF, Snook ME, Arrendale RF, . 1976. Gas chromatographic quantitation of polynuclear aromatic hydrocarbons in tobacco smoke: Analytic laboratory methods. Anal Chem 48:1866–1872.970639
Shah GM, Bhattacharya RK. 1989. Alteration in hepatic nuclear RNA polymerase activity following benzo[a]pyrene administration in rat. In vivo 3(2):125–127.2519839
*Shamsuddin AK, Gan R. 1988. Immunocytochemical localization of benzo(a)pyrene-DNA adducts in human tissue. Human Pathology 19(3):309–315.3126127
*Shamsuddin AKM, Sinopoli NT, Hemminki K, . 1985. Detection of benzo(a)pyrene DNA adducts in human white blood cells. Cancer Res 45:66–68.3965153
*Shane BS, Henry CB, Hotchkiss JH, . 1990. Organic toxicants and mutagens in ashes from eighteen municipal refuse incinerators. Arch Environ Contam Toxicol 19(5):665–673.21318496
Shear MJ, Luter J. 1941. Studies in carcinogenesis: XVI. Production of subcutaneous tumors in mice by miscellaneous polycyclic compounds. J Natl Cancer Inst 2:241–258.
*Shendrikova IA, Aleksandrov VA. 1974. Comparative penetration of polycyclic hydrocarbons through the rat placenta into the fetus. Bull Exp Biol Med 77: 169–171.4433923
*Sherson D, Sabro P, Sigsgaard T, . 1990. Biological monitoring of foundry workers exposed to polycyclic aromatic hydrocarbons. Br J Ind Med 47(7):448–453.2383513
Shiba M, Marchok AC, Klein-Szanto AJ, . 1987. Pathological changes induced by formaldehyde in open-ended rat tracheal implants preexposed to benzo(a)pyrene. Toxicol Pathol 15:401–408.3432939
*Shimada H, Satake S, Itoh S, . 1990. Multiple-dosing effects of benzo[a]pyrene in the mouse bone marrow micronucleus test. Mutat Res 234(3–4): 179–181.2366787
*Shimada H, Suzuki H, Itoh S, . 1992. The micronucleus test of benzo[a]pyrene with mouse and rat peripheral blood reticulocytes. Mutat Res 278(2–3):165–168.1372700
Shimkin MB, Stoner GD. 1975. Lung tumors in mice: Application to carcinogenesis bioassay. In: Klein G, Weinhouse S, eds. Advances in cancer research. Vol. 12. New York, NY: Raven Press, 1.
*Shiraishi H, Pilkington NH, Otsuki A, . 1985. Occurrence of chlorinated polynuclear aromatic hydrocarbons in tap water. Environ Sci Technol 19:585–590.22148299
*Shmahl D, Schmidt KG, Habs MK. 1977. Syncarcinogenic action of polycyclic aromatic hydrocarbons in automobile exhause gas condensates. In: Air Pollution and Cancer in Man. IARC Publication 16. (U. Mohr, D. Schmahl, and L. Tomatis, eds.). World Health Organization. Lyon France, 53–59.
Shubik P, Hartwell JL. 1957. Survey of compounds which have been tested for carcinogenic activity. Washington, D.C: Government Printing Office, Public Health Service publication no. 149, supplement 1.
Shubik P, Hartwell JL. 1969. Survey of compounds which have been tested for carcinogenic activity. Washington, D.C: Government Printing Office, Public Health Service publication no. 149, supplement 1.
*Shubik P, Porta GD. 1957. Carcinogenesis and acute intoxication with large doses of polycyclic hydrocarbons. Am Med Assoc Arch Pathol 64:691–703.
Shubik P, Pietra G, Della Porta G. 1960. Studies of skin carcinogenesis in the Syrian golden hamster. Cancer Res 20:100.14446270
*Shugart L. 1986. Quantifying adductive modification of hemoglobin from mice exposed to benzo(a)pyrene. Anal Biochem 152:365–369.3963369
*Shugart L, Holland JM, Rahn RO. 1983. Dosimetry of polycyclic aromatic hydrocarbon skin carcinogenesis: Covalent binding of benzo(a)pyrene to mouse epidermal DNA. Carcinogenesis 4:195–198.6297825
*Shum S, Jensen NM, Nebert DW. 1979. The murine HA Hh locus: In utero toxicity and teratogenesis associated with genetic differences in benzo[a]pyrene metabolism. Teratology 20:365–376.542892
Siebert D, Marquardt H, Friesel H, . 1981. Polycyclic aromatic hydrocarbons and possible metabolites: Convertogenic activity in yeast and tumor initiating activity in mouse skin. J Cancer Res Clin Oncol 102:127–139.7338531
Simmon VF. 1979a. In vitro assays for recombinogenic activity of chemical carcinogens and related compounds with Saccharomyces cerevisiae D3. J Natl Cancer Inst 62:901–910.372658
Simmon VF. 1979b. In vitro mutagenicity assays of chemical carcinogens and related compounds with Salmonella typhimurium. J Natl Cancer Inst 62 893–900.372657
*Simmon VF, Rosenkranz HS, Zeiger E, . 1979. Mutagenic activity of chemical carcinogens and related compounds in the intraperitoneal host-mediated assay. J Natl Cancer Inst 62:911–918.372659
*Simonich SL, Hites RA. 1994b. Importance of vegetation in removing polycyclic aromatic hydrocarbons from the atmosphere. Nature 370:49–51.
*Simonsick WJJ, Hites RA. 1985. Charge exchange chemical ionization mass spectrometry: A tool for PAH isomer differentiation. In: Cooke M, Dennis AJ, eds. Polynuclear aromatic hydrocarbons: Mechanisms, methods and metabolism. Columbus, OH: Battelle Press, 1227–1237.
Sims P. 1982. The metabolic activation of some polycyclic hydrocarbons: The role of dihydrodiols and diol-epoxides. Adv Exp Med Biol 136:487–500.
*Sims RC. 1990. Soil remediation techniques at uncontrolled hazardous waste sites, a critical review. J Air Waste Man Assoc 40(5):704–732.
*Sims RC, Overcash MR. 1983. Fate of polynuclear aromatic compounds (PNAs) in soil-plant systems. Res Rev 88:1–68.
*Sims RC, Doucette WJ, McLean JE, . 1988. Treatment potential for 56 EPA-listed hazardous shemicals in soil. Robert Kerr Environmental Research Laboratory, Ada, OK. Epa dot. no. EPA/600/6-88/001.
*Singer B, Grunberger. 1983. Metabolic activation of carcinogens and mutagens. In: Molecular biology of mutagens and carcinogens. New York, NY: Plenum Press, 97–141.
*Singh R and Weyand EH. 1994. Studies on the binding of various polycyclic aromatic hydrocarbons to mouse hemoglobin and serum proteins. Polycyclic Aromatic Hydrocarbons 6:135–142.
Sinsheimer JE, Giri AK, Hooberman BH, . 1991. Mutagenicity in Salmonella and sister chromatid exchange in mice for 1,4-dimethylphenanthrenes 1,3-,2,4-dimethylphenanthrenes and 3,4-dimethylphenanthrenes. Environ Mol Mutagen 17(2):93–97.2009871
Sirianni SR, Huang CC. 1978. Sister chromatid exchange induced by promutagens/carcinogens in Chinese hamster cells cultured in diffusion chambers in mice. Proceedings of the Society for Experimental Biology and Medicine 158:269–274.
Sisovic A, Fugas M. 1991. Comparative evaluation of procedures for the determination of PAH in low-volume samples. Environ Monit Assess 18(3):235–241.24233854
*Slaga TJ, diGiovanni J. 1984. Inhibition of chemical carcinogenesis. In: Searle CE, ed. Chemical carcinogens. ACS Monograph #182. Vol. 2, 2nd ed. Washington, D.C: American Chemical Society.
*Slaga TJ, Jecker L, Bracken WM, . 1979. The effects of weak or non-carcinogenic polycyclic hydrocarbons on 7,12- dimethylbenz(a)anthracene and benzo(a)pyrene skin tumor-initiation. Cancer Lett 7 51–59.110441
*Slaga TJ, Gleason GL, Wells G. 1980a. Comparison of the skin tumor-initiating activities of dihydrodiols and diol-epoxides of various polycyclic aromatic hydrocarbons. Cancer Res 40:1981–1984.7371034
*Slaga TJ, Triplett LL, Nesnow S. 1980b. Mutagenic and carcinogenic potency of extracts of diesel and related environmental emissions: Two-stage carcinogenesis in skin tumor sensitive mice (SENCAR): Health effects of diesel engine emissions. Proceedings of An International Symposium. Cincinnati, OH: US Environmental Protection Agency. EPA 600/9-80-057b., 874–897.
Smolarek TA, Baird WM. 1984. Benzo[e]pyrene-induced alterations in the binding of benzo[a]pyrene to DNA in hamster embryo cell cultures. Carcinogenesis 5(8):1065–1069.6086168
*Smolarek TA, Moynihan C, Salmon CP, . 1986. Benz(a)anthracene-induced alterations in the metabolic activation of benzo[a]pyrene by hamster embryo cell cultures. Cancer Lett 30:243–249.3754483
*Smolarek TA, Baird WM, Fisher EP, . 1987. Benzo(e)pyrene-induced alterations in the binding of benzo(a)pyrene and 7,12-dimethylbenz(a)anthracene to DNA in Sencar mouse epidermis. Cancer Res 47(14):3701–3706.3109730
Snell KC, Stewart HL. 1962. Pulmonary adenomatosis induced in DBA/2 mice by oral administration of dibenz[a,h]anthracene. J Natl Cancer Inst 28:1043.14039387
*Snell KC, Stewart HL. 1963. Induction of pulmonary adenomatoses in DBA/2 mice by the oral administration of dibenz[a,h]anthracene. Acta Un Int Cancer 19:692–694.
*Snider EH, Manning FS. 1982. A survey of pollutant emission levels in waste waters and residuals from the petroleum refining industry. Environment International 7:237–258.
Solt DB, Polverini PJ, Calderon L. 1987. Carcinogenic response of hamster buccal pouch epithelium to 4 polycyclic aromatic hydrocarbons. J Oral Pathol 16:294–302.2445943
*Sorrel RK, Brass HJ, Reding R. 1980. A review of occurrences and treatment of polynuclear aromatic hydrocarbons. EPA-600/D-81-066.
*Southworth GR. 1979. The role of volatilization on removing polycyclic aromatic hydrocarbons from aquatic environments. Bull Environ Contam Toxicol 21:507–514.444744
*Southworth GR, Beauchamp JJ, Schmeider PK. 1978. Bioaccumulation potential of polycyclic aromatic hydrocarbons in Daphnia pulex. Water Res 12:973–977.
*Soyka LF. 1980. Hepatic drug metabolizing enzyme activity and tumorigenesis in mice following perinatal exposure to benzo(a)pyrene. Pediatr Pharmacol 1:85–96.
*Spacie A, Landruff PF, Leversee GJ. 1983. Uptake, depuration and biotransformation of anthracene and benzo[a]pyrene. Ecotoxicol Environ Safety 7:330.6307636
*Sparnins VL, Mott AW, Baraney G, . 1986. Effects of ally1 methyl trisulfide on glutathione-S-transferase activity. Nutr Cancer 8:211–215.3737423
*SRI. 1992. SRI International. Directory of chemical producers. United States of America. Menlo Park, CA.
*SRI. 1994. Directory of chemical producers: United States of America. Menlo Park, Ca: SRI International.
*Srivastava V, Chauhan W, Srivastava P, . 1986. Fetal translocation and metabolism of PAH obtained form coal fly ash given intratracheally to pregnant rats. J Toxicol Environ Health 18:459–469.3712502
*Stahl RG, Liehr JG, Davis EM. 1984. Characterization of organic compounds in simulated rainfall runoffs from model coal piles. Arch Environ Contam Toxicol 13:179–190.
Stanton MF, Miller E, Wrench C, . 1972. Experimental induction of epidermoid carcinoma in the lungs of rats by cigarette smoke condensate. J Natl Cancer Inst 49:867–877.4647499
*Staples CA, Werner AF, Hoogheem TJ, . 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4:131–142.
*Stavenow L, Pessah-Rasmussen H. 1988. Effects of polycyclic aromatic hydrocarbons on proliferation, collagen secretion and viability of arterial smooth muscle cells in culture. Artery 15:94–108.3128250
Steiner PE. 1955. Carcinogenicity of multiple chemicals simultaneously administered. Cancer Res 15:632–635.13261089
Steiner PE, Edgecomb JH. 1952. Carcinogenicity of 1,2-benzanthracene. Cancer Res 12:657–659.12978996
Steiner PE, Falk HL. 1951. Summation and inhibition effects of weak and strong carcinogenic hydrocarbons: 1,2-Benzanthracene, chrysene, 1,2,5,6-dibenzanthracene and 20-methylcholanthrene. Cancer Res 11: 56–63.14792556
*Stenback F, Rowland J. 1979. Experimental respiratory carcinogenesis in hamsters: Environmental, physiochemical and biological aspects. Oncol 36:63–71.
Stenback F, Sellakumar A, Shubik P. 1975. Magnesium oxide as carrier dust in benzo[a]pyrene-induced lung carcinogenesis in Syrian hamsters. J Natl Cancer Inst 54:861–867.1127716
*Stenback F, Rowland J, Sellakumar A. 1976. Carcinogenicity of benzo[a]pyrene and dusts in the hamster lung (instilled intratracheally with titanium oxide, aluminum oxide, carbon and ferric oxide). Oncol 33:29–34.
Stora C. 1980. Comparative study of the cellular localization of three polycyclic hydrocarbons differing in their carcinogenicity. Oncology 37(1):23–26.7350550
*Storer JS, DeLeon I, Millikan LE, . 1984. Human absorption of crude coal tar products. Arch Dermatol 120:874–877.6732260
*Strickland A, Szczeklik J, Galuszka Z, . 1994a. Humoral immunosuppression in men exposed to polycyclic aromatic hydrocarbons and related carcinogens in polluted environments. Environ Health Perspect 102(3):302–304.8033871
*Strickland PT, Kang D, Bowman ED, . 1994b. Identification of 1-hydroxypyrene glucuronide as a major pyrene metabolite in human urine by synchronous fluorescence spectroscopy and gas chromatography-mass spectrometry. Carcinogenesis 15(3):483–487.8118933
*Stutz DR, Janusz SJ. 1988. Hazardous materials injuries: A handbook for pre-hospital care. 2nd ed. Beltsville, MD: Bradfor Communications Corporation, 298–299.
Su SY, Lai EPC, Winefordner JD. 1982. Determination of polynuclear aromatic hydrocarbons by a spiked mobile fluorescence HPLC detector. Anal Lett 15:439–450.
*Sullivan PD, Calle LM, Shafer K, . 1978. Effects of antioxidants of benzo[a]pyrene free radicals. In: Freudenthal RI, Jones PW, eds. Polynuclear aromatic hydrocarbons: 2nd International Symposium on Analysis, Chemistry, and Biology (Carcinogenesis - a comprehensive survey). Vol. 3. New York, NY: Raven Press, 1–3.
*Sullivan TJ, Mix MC. 1985. Persistence and fate of polynuclear aromatic hydrocarbons deposited on slash bum sites in the Cascade Mountains and Coast Range of Oregon (USA). Arch Environ Contam Toxicol 14:187–192.3985679
*Sun JD, Wolff RK, Kanapilly GM. 1982. Deposition, retention, and biological fate of inhaled benzo[a]pyrene adsorbed onto ultrafine particles as a pure aerosol. Toxicol Appl Pharmacol 65:231–244.6294918
*Swartz WJ, Mattison DR. 1985. Benzo[a]pyrene inhibits ovulation in C57BL/6N mice. Anatomical Record 212:268–276.4061880
*Symons RK, Crick I. 1983. Determination of polynuclear aromatic hydrocarbons in refinery effluent by high-performance liquid chromatography. Anal Chim Acta 151:237–243.
*Szczeklik A, Szczeklik J, Galuszka Z, . 1994. Humoral immunosuppression in men exposed to polycyclic aromatic hydrocarbons and related carcinogens in polluted environments. Environ Health Perspect 102(3):302–304.8033871
*Szepesy L, Lakszner K, Akermann L, . 1981. Rapid method for the determination of polycyclic aromatic hydrocarbons in environmental samples by combined liquid chromatography and gas chromatography. J Chromatogr 206:611–616.
*Tan YL. 1988. Analysis of polynuclear aromatic hydrocarbons in shale oil and diesel particulates. Anal Lett 21:553–562.
*Tan YL, Quanci JF, Borys RD, . 1992. Polycyclic aromatic hydrocarbons in smoke particles from wood and duff burning. Atmos Environ 26(6):1177–1181.
*Tanaka K, Saito M. 1988. High-performance liquid chromatographic separation and synchronous fluorimetric determination of polycyclic aromatic hydrocarbons in soils. The Analyst 113:509–510.3377186
*Teranishi K, Hamada K, Watanabe H. 1975. Quantitative relationship between carcinogenicity and mutagenicity of polyaromatic hydrocarbons in Salmonellu typhimurium mutants. Mutat Res 31(2):97–102.1090818
*Thomas W. 1986. Accumulation of airborne trace pollutants by arctic plants and soil. Water Sci Technol 18:47–57.
*Thomas AO, Lester JN. 1993. The microbial remediation of former gasworks sites: a review. Environ Technol 14(1): 1–24.
*Thomas DH, Delfino JJ. 1991. A gas chromatographic/chemical indicator approach to assessing ground water contamination by petroleum products. Ground Water Monit Rev 11(4):90–100.
*Thomas JF, Mukai M, Tebbens, . 1968. Fate of airborne benzo[a]pyrene. Env Sci Technol 2:33–39.
*Thomas W, Ruehling A, Simon H. 1984. Accumulation of airborne pollutants (polycyclic aromatic hydrocarbons, chlorinated hydrocarbons, heavy metals) in various plant species and humus. Environ Poll (Series A) 36:295–310.
Thompson JI. 1971. Survey of compounds which have been tested for carcinogenic activity. Washington, D.C: Government Printing Office, Public Health Service publication no. 149, 1968–1969.
*Thony C, Thony J, LaFontaine M, . 1976. Hydrcarbeures polycycliques aromatique cancerogens dans les produits petroliers prevention possibles du cancer des huiles minerales. Inserm Symp Ser 52:165. (French)
Thrane KE, Makalsen A, Stray H. 1985. Monitoring method for airborne polycyclic aromatic hydrocarbons. Int J Environ Anal Chem 23:111–134.
*Thruston ADJ. 1978. High pressure liquid chromatography techniques for the isolation and identification of organics in drinking water extracts. J Chromatogr Sci 16:254–259.
*Thyssen J, Althoff JKG, Mohr U. 1981. Inhalation studies with benzo[a]pyrene in Syrian golden hamsters. J Natl Cancer Inst 66:575–577.6937711
*Tokiwa H, Sera N, Horikawa K, . 1993. The presence of mutagens/carcinogens in the excised lung and analysis of lung cancer induction. Carcinogenesis 14(9):1933–1938.8403221
*Tolos WP, Shaw PB, Lowry LK, . 1990. 1-Pyrenol: A biomarker for occupational exposure to polycyclic aromatic hydrocarbons. Appl Occup Environ Hyg 5(5):303–309.
*Tolos WP, Lowry LK, MacKenzie BA. 1991. 1-pyrenol in urine: A biological monitoring method to assess exposure to polynuclear aromatic hydrocarbons containing pyrene. In: Cooke M, Dennis AJ, Fisher GL, eds. Polynuclear aromatic hydrocarbons: physical and biological chemistry. New York, NY: Springer-Verlag, 913–926.
*Tomingas R, Pott F, Dehnen W. 1976. Polycyclic aromatic hydrocarbons in human bronchial carcinoma. Cancer Lett 1:189–195.1016943
*Tomkins BA, Griest WH. 1987. Liquid chromatographic determination of benzo(a)pyrene at part-per-billion concentrations in highly refined coal- and petroleum-derived fuels. J Chromatogr (Netherlands) 386: 103–110.
*Tomkins BA, Griest WH, Caton JE, . 1982. Multicomponent isolation and analysis of polynuclear aromatics. In: Cooke M, Dennis AJ, Fisher GL, eds. Polynuclear aromatic hydrocarbons: Physical and biological chemistry. New York, NY: Springer-Verlag, 813–824.
*Tomkins BA, Buchanan MV, Reagan RR, . 1986. The isolation, identification, and quantitation of the four- and five-ring dermal tumorigen PAH in petroleum crude oils and distillate fractions using normal-phase isolation HPLC and GC/MS in the single-ion monitoring mode. In: Cooke M, Dennis AJ, eds. Polynuclear aromatic hydrocarbons: Chemistry, Characterization, and carcinogenesis. Proceedings of the Ninth International Symposium. Columbus, OH: Battelle Press, 917–932.
*Tomkins BA, Greist WH, Caton JE, . 1991. Multicomponent isolation and analysis of polynuclear aromatics. In: Cooke M, Dennis AJ, Fisher GL, eds. Polynuclear aromatic hydrocarbons: physical and biological chemistry. New York, NY: Springer-Verlag, 813–824.
Tong C, Brat SV, Williams GM. 1981. Sister-chromatid exchange induction by polycyclic aromatic hydrocarbons in an intact cell system of adult rat-liver epithelial cells. Mutat Res 91:467–473.7290101
Topham JC. 1980. Do induced sperm-head abnormalities in mice specifically identify mammalian mutagens rather than carcinogens? Mutat Res 74:379–387.7207475
*Topping DC, Martin DH, Nettesheim P. 1981. Determination of cocarcinogenic activity of benzo[e]pyrene for respiratory tract mucosa. Cancer Lett 11(4):315–321.7296525
*Topping DC, Pal BC, Martin DH, . 1978. Pathologic changes induced in respiratory tract mucosa by polycyclic hydrocarbons of differing carcinogenic activity. Am J Pathol 93(2):311–324.102204
*Torronen R, Nousiainen U, Hanninen O. 1981. Induction of aldehyde dehydrogenase by polycyclic aromatic hydrocarbons in rats. Chem-Biol Interact 36:33–44.6265106
*Toussaint G, Walker EA. 1979. Use of high-performance liquid chromatography as a clean-up procedure in analysis of polycyclic aromatic hydrocarbons in alcoholic beverages. J Chromatogr 171:448–452.546859
Tracer-Jitco. 1973a. Survey of compounds which have been tested for carcinogenic activity. Washington, D.C: Government Printing Office. Public Health Service publication no. 149, 1961–1967.
Tracer-Jitco. 1973b. Survey of compounds which have been tested for carcinogenic activity. Washington, D.C: Government Printing Office. Public Health Service publication no. 149, 1970–1971.
*Traynor GW, Apte MG, Sokol HA, . 1990. Selected organic pollutant emissions from unvented kerosene space heaters. Environ Sci Technol 24(8):1265–1270.
*TRI90. 1992. Toxic Chemical Release Inventory. U.S. Environmental Protection Agency, Office of Toxic Substances, Washington, DC.
*TRI92. 1994. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*Tromberg BJ, Sepaniak MJ, Alarie JP, . 1988. Development of antibody-based fibre-optic sensors for detection of a benzo(a)pyrene metabolite. Anal Chem 60(18):1901–1908.3228195
*Tsuda H, Farber E. 1980. Resistant hepatocytes as early changes in liver induced by polycyclic aromatic hydrocarbons. Int J Cancer 25:137–139.6105134
Tsuge S, Nishimura K, Suzuki M, . 1988. Determination of benzo(a)pyrene in airborne particulates by automated thermal-desorption gas chromatography. Anal Sci 4(1):115–116.
Tuominen J, Pyysalo H, Laurikko J, . 1987. Application of GLC-selected ion monitoring (SIM)-technique in analyzing polycyclic organic compounds in vehicle emissions. Sci Total Environ 59:207–210.
*Tuominen JP, Pyysalo HS, Sauri M. 1988. Cereal products as a source of polycyclic aromatic hydrocarbons. J Agric Food Chem 36(1):118–120.
*Tumey GL, Goerlitz DF. 1990. Organic contamination of ground water at Gas Works Park, Seattle, Washington. Ground Water Monit Rev 19(3):187–198.
Turusov VS, Nikonova TV, Parfenov YuD. 1990. Increased multiplicity of lung adenomas in five generations of mice treated with benz(a)pyrene when pregnant. Cancer Lett 55(3):227–231.2257541
Tweats DJ. 1981. Activity of 42 coded compounds in a differential killing test using Escherichia coli strains WP2, WP67 (uvrA polA), and CM871 (uvrA 1exA recA): Evaluation of shot-term tests for carcinogens: Report of the International Collaboratorive Program. Prog Mutat Res 1:199–209.
*Ueng T-H, Alvares AP. 1993. Metabolism of benzo(a)pyrene by lung microsomes from rabbits pretreated with polychlorinated biphenyls and 2,3,4,7,8-pentachlorodibenzofuran. Life Sci 52:163–169.8355556
*United Nations. 1985. Traetment and disposal methods for waste chemicals (IRPTC file). Data profile series no. 5. Geneva, Switzerland: United Nations Environmental Programme.
*Ursa P, Gengozian N. 1980. Depressed humoral immunity and increased tumor incidence in mice following in utero exposure to benzo[a]pyrene. J Toxicol Environ Health 6:569–576.7420464
*Ursa P, Johnson RA. 1987. Early changes in T lymphocytes and subsets of mouse progeny defective as adults in controlling growth of a syngeneic tumor after in utero insult with benzo(a)pyrene. Immunopharmacology 14:1–10.3500149
Urso P, Johnson RA. 1988. Quantitative and functional change in T cells of primiparous mice following injection of benzo(a)pyrene at the second trimester of pregnancy. Immunopharmacol Immunotoxicol 10:195–217.2971711
*Ursa P, Gengozian N, Rossi RM, . 1986. Suppression of humoral and cell-mediated immune responses in vitro by benzo(a)pyrene. J Immunophatmacol 1986, 8(2):223–241.
Urso P, Ryan MC, Bennett JS. 1988. Changes in peripheral blood cells in mice after injection with benzo[a]pyrene during pregnancy. Immunopharmacol Immunotoxicol 10:179–193.3171106
*Ursa P, Zhang W, Cobb JR. 1992. Immunological consequences from exposure to benzo(a)pyrene during pregnancy. Stand J Immunol 36(Suppl 11):203–206.
*USDA. 1980. The biologic and economic assessment of pentachlorophenol, inorganic arsenicals, creosote. Volume 1: Wood preservatives. US Department of Agriculture, Washington, D.C. Technical bulletin no. 1658-1, 193–227.
*USDOC. 1985. U.S. Imports for Consumption and General Imports. TSUSA Commodity by Country of Origin. FT246/Annual 1985. Washington, D.C.: US Department of Commerce.
*Uziel M, Ward RJ, Vo-Dinh T. 1987. Synchronous fluorescence measurement of benzo(a)pyrene metabolites in human and animal urine. Anal Lett 20:761–776.
*Vahakangas K, Trivers G, Rowe M, . 1985. Benzo[a]pyrene diolepoxide-DNA adducts detected by synchronous fluorescence spectrophotometry. Environ Health Perspect 62:101–104.3936704
*Vainiotalo S, Matveinen K. 1993. Cooking fumes as a hygienic problem in the food and catering industries. Am Ind Hyg Assoc J 54(7):376–382.
Valencia R, Houtchens K. 1981. Mutagenic activity of 10 coded compounds in the Drosophila sex-linked recessive lethal test. Evaluation of short-term tests for carcinogens: Report of the Intemation Collaborative program. Prog Mutat Res 1:652–659.
*van de Wiel JAG, Fijneman PHS, Duijf CMP, . 1993. Excretion of benzo[a]pyrene and metabolites in urine and feces of rats: influence of route of administration, sex, and long-term ethanol treatment. Toxicology 80: 103–115.8327994
Van Duuren BL, Sivak A, Segal A, . 1966. The tumor producing agents of tobacco leaf and tobacco smoke condensate. J Natl Cancer Inst 37 519.5923502
*Van Duuren BL, Langseth L, Goldschmidt BM. 1967. Carcinogenicity of epoxides, lactones and peroxy compounds: VI. Structure and carcinogenic activity. J Natl Cancer Inst 39:1217–1227.6079867
*Van Duuren BL, Katz C, Goldschmidt BM, . 1973. Brief communication: cocarcinogenic agents in tobacco carcinogenesis. J Natl Cancer Inst 51:703–705.4765384
*Van Heddeghem A, Huyghebaert A, De Moor H. 1980. Determination of polycyclic aromatic hydrocarbons in fat products by high pressure liquid chromatography. Z Lebensm Unter Forsch 171(1):9–13.
*Van Hummelen P, Gennart JP, Buchet JP, . 1993. Biological markers in PAH exposed workers and controls. Mutat Res 300:231–239.7687023
*Van Rooij JGM, Bodelier-Bade MM, Jongeneelen FJ. 1993a. Estimation of individual dermal and respiratory uptake of polycyclic aromatic hydrocarbons in 12 coke oven workers. Br J Ind Med 50:623–632.8343423
*Van Rooij JGM, Van Lieshout EMA, Bodelier-Bade MM, . 1993b. Effect of the reduction of skin contamination on the internal dose of creosote workers exposed to polycyclic aromatic hydrocarbons. Stand J Work Environ Health 19:200–207.
*Van Rooij JGM, De Roos JHC, Bodelier-Bade MM, . 1993c. Absorption of polycyclic aromatic hydrocarbons through human skin: differences between anatomical sites and individuals. J Toxicol Environ Health 38:355–368.8478978
*Van Rooij JGM, Veeger MMS, Bondelier-Bade MM, . 1994. Smoking and dietary intake of polycyclic aromatic hydrocarbons as sources of inter-individual variability in the baseline excretion of 1 -hydroxypyrene in urine. Int Arch Occup Environ Health 66(1):55–65.7927844
*Van Schooten FJ, Hillebrand MJX, Scherer E, . 1991. Immunocytochemical visualization of DNA adducts in mouse tissues and human white blood cells following treatment with benzo(a)pyrene or its diol epoxide: A quantitative approach. Carcinogenesis 12(3):427–434.1901249
*Van Schooten FJ, Hillebrand MJX, Van Leeuwen FF, . 1992. Polycyclic aromatic hydrocarbon-DNA adducts in white blood cells from lung cancer patients: No correlation with adduct levels in lung. Carcinogenesis 13(6):987–993.1600621
Vanio RS. 1976. The fate of intratracheally installed benzo[a]pyrene in the isolated perfused rat lung of both control and 20-methylcholanthrene pretreated rats. Res Commun Chem Pathol Pharmacol 13:259–272.1257613
*Varanasi U, Gmur DJ. 1980. Metabolic activation and covalent binding of benzo[a]pyrene to deoxyribonucleic acid catalyzed by liver enzymes of marine fish. Biochem Pharmacol 29:753–762.20227952
*Varanasi U, Gmur DJ. 1981. In vivo metabolism of naphthalene and benzo[a]pyrene of flatfish. In: Cooke M, Dennis AJ, eds. Chemical analysis and biological fate: Polynuclear aromatic hydrocarbons. Fifth International Symposium. Columbus, OH: Battelle Press, 367–376.
*Varanasi U, Reichert WL, Stein JE, . 1985. Bioavailability and biotransformation of aromatic hydrocarbons in benthic organisms exposed to sediment from an urban estuary. Environ Sci Technol 19:836–841.22196609
*Vassilaros DL, Stoker PW, Booth GM, . 1982. Capillary gas chromatographic determination of polycyclic aromatic compounds in vertebrate fish tissue. Anal Chem 54: 106–112.6175248
*Vaughan BE. 1984. State of research: Environmental pathways and food chain transfer. Environ Health Perspect., 353–371.6428875
Veith GD, Kuehl DW, Leonard EN, . 1981. Polychlorinated biphenyls and other organic chemical residues in fish from major United States watersheds near the great lakes, 1978. Pestic Monit J 15:1–8.6792589
*Verschueren K. 1983. Handbook of data on organic chemicals. 2nd ed. New York, NY: Van Nostrand Reinhold Co.
*Viau C, Vyskocil A, Tremblay C, . 1993. Urinary excretion of 1-hydroxypyrene in workers exposed to polycyclic aromatic hydrocarbon mixtures. J Occup Med Technol 2(3):267–276.
VIEW. 1989. Agency of Toxic Substances and Disease Registry (ATSDR), Office of External Affairs, Exposure and Disease Registry Branch, Atlanta, GA. June 20, 1989.
*Vo-Dinh T. 1981. A new passive dosimeter for monitoring personnel exposure to polycyclic aromatic vapors. 182nd American Chemical Society National Meeting, New York, NY, August 23-28.
*Vo-Dinh T, Abbott DW. 1984. A ranking index to characterize polynuclear aromatic pollutants in environmental samples. Environ Int 10:299–304.
*Vo-Dinh T, Bruewer TJ, Colovos GC, . 1984. Field evaluation of a cost-effective screening procedure for polynuclear aromatic pollutants in ambient air samples. Environ Sci Technol 18:477–482.22247952
*Vo-Dinh T, Alarie JP, Johnson RW. 1991. Evaluation on the fiber-optic antibody-based fluoroimmunosensor for DNA adducts in human placenta samples. Clin Chem 37(4):532–535.2015666
Vogel EW, Zijlstra JS, Blijleven WGH. 1983. Mutagenic activity of selected aromatic amines and polycyclic hydrocarbons in Drosophila melanogaster. Mutat Res 107(1):53–78.6402690
Vogt NB, Brakstad F, Thrane K, . 1987. Polycyclic aromatic hydrocarbons in soil and air: Statistical analysis and classification by the SIMCA method. Environ Sci Technol 21:35–44.
*Vreuls JJ, De Jong GG, Brinkman U. 1991. On-line coupling of liquid chromatography capillary gas chromatography and mass spectrometry for the determination and identification of polycyclic aromatic hydrocarbons in vegetable oils. Chromatographia 31(3–4)113–122.
*Wachter RA, Blackwood TR. 1979. Water pollutants from coal storage areas. Coal Technology (Houston) 2:234–239.
*Wadler S, Fuks JZ, Wiemik PH. 1986. Phase I and II agents in cancer therapy: Part I. Anthracyclines and related compounds. J Clin Pharmacol 26:491–509.2944917
*Waldeman JM, Lioy PJ, Greenberg A, . 1991. Analysis of human exposure to benzo(a)pyrene via inhalation and food ingestion in the total human environmental exposure study (THEES). J Expos Anal Environ Epidemiol 1(2):193–225.
*Wallace WE, Keane MJ, Hill CA, . 1987. Mutagenicity of diesel exhaust particles and oil shale particles dispersed. J Toxicol Environ Health 21:163–171.2437315
*Wang DT, Meresz O. 1982. Occurrence and potential uptake of polynuclear aromatic hydrocarbons of highway traffic origin by proximally grown food crops. In: Cooke M, Dennis AJ, eds. Polynuclear aromatic hydrocarbons: Physical and biological chemistry. Columbus, OH: Battelle Press. 885–896.
*Wang J-S, Busby WF, Jr. 1993. Induction of lung and liver tumors by fluoranthene in a preweanling CD-l mouse bioassay. Carcinogenesis 14(9):1871–1874.8403212
*Warshawsky D, Barkley W. 1987. Comparative carcinogenic potencies of 7H-dibenzo[c,g]carbazole, dibenz[a,j]acridine and benzo(a)pyrene in mouse skin. Cancer Lett 37:337–344.3677065
*Warshawsky DT, Cody M, Raidke BA, . 1983. Toxicity and metabolism of benzo[a]pyrene in the green alga Selenastrum capricontum. In: Cooke M, Dennis AJ, eds. Polynuclear aromatic hydrocarbons: Formation, metabolism and measurement. Columbus, OH: Battelle Press, 1235–1245.
*Warshawsky D, Barkley W, Bingham E. 1993. Factors affecting carcinogenic potential of mixtures. Fundam Appl Toxicol 20:376–382.8504912
Wattenberg LW, Bueding E. 1986. Inhibitory effects of 5-(2-pyrazinyl)-4-methyl-1,2-dithiol-3-thione (Oltipraz) on carcinogenesis induced by benzo[a]pyrene, diethylnitrosamine and uracil mustard. Carcinogenesis 7:1379–1381.3731391
*Wattenberg LW, Leong JL. 1970. Inhibition of the carcinogenic action of benzo[a]pyrene by flavones. Cancer Res 30:1922–1925.5456076
*Weast RC, ed. 1987. CRC handbook of chemistry and physics. 68th ed. Boca Raton, FL: CRC Press.
*Weast RC, Astle MJ, Beyer WH, eds. 1988. Handbook of chemistry and physics. Boca Raton, FL: CRC Press, Inc.
*Weibel FJ. 1980. Activation and inactivation of carcinogens by microsomal nonoxooxygenases: Modification by benzoflavones and polycyclic aromatic hydrocarbons. Carcinogenesis 5.: Modifiers of chemical carcinogenesis.
*Weinberg CR, Wilcox AJ, Baird DD. 1989. Reduced fecundability in women with prenatal exposure to cigarette smoking. Am J Epidemiol 129:1072–1078.2705427
*Weinstein D, Katz ML, Kazmer S. 1977. Chromosomal effects of carcinogens and non-carcinogens on WI-38 after short term exposures with and without metabolic activation. Mutat Res 46:297–304.408680
*Weissenfels WD, Beyer M, Klein J. 1990. Rapid testing system for assessing the suitability of the biological reclamation for PAH-contaminated soil. In: Christiansen C, Munck L, Villadsen J, eds. 5th European Congress on Biotechnology, proceedings volume 2. Copanhagen, Denmark: Munksgaard, 931–934.
*Weissenfels WD, Klewer HL, Langhoff J. 1992. Adsorption of polycyclic aromatic hydrocarbons (PAHs) by soil particles: Influence on biodegradability and biotoxicity. Appl Microbial Biotechnol 36(5):689–696.
Wenzel-Hartung R, Brune H, Grimmer G, . 1990. Evaluation of the carcinogenic potency of 4 environmental polycyclic aromatic compounds following intrapulmonary application in rats. Exp Pathol 40(4):221–227.1711479
*Werner P, Brauch H-J. 1988. Aspects on the in-situ and on-site removal of hydrocarbons from contaminated sites by biodegradation. In: Wolf K, van den Brink WJ, Colon FJ, eds. Contaminated Soil ‘88. Boston, MA: Kluwer Academic Publishers, 69.5704.
*Wester RC, Maibach HI, Bucks DAW, . 1990. Percutaneous absorption of carbon-14 labelled DDT and carbon-14 labelled benzo(a)pyrene from soil. Fundam Appl Toxicol 15(3):510–516.2258015
*Westerholm R, Li H. 1994. A multivariant statistical analysis of fuel-related polycyclic aromatic hydrocarbon emissions from heavy-duty diesel vehicles. Environ Sci Technol 28(5):965–972.22191842
Weston. 1985. Comparative studies of the metabolic activation of chrysene in rodent and human skin. Chem Biol Interact 54:223–242.4028289
*Weston A, Bowman ED. 1991. Fluorescence detection of benzo(a)pyrene-DNA adducts in human lung. Carcinogenesis 12(8):1445–1450.1860165
*Weston A, Bowman ED, Shields PG, . 1993a. Detection of polycyclic aromatic hydrocarbon-DNA adducts in human lung. Environ Health Perspect 99:257–259.8319638
*Weston A, Bowman ED, Carr P, . 1993b. Detection of metabolites of polycyclic aromatic hydrocarbons in human urine. Carcinogenesis 14(5):1053–1055.8504465
*Weston A, Rowe M, Poirier M, . 1988. The application of immunoassays and fluorometry to the detection of polycyclic hydrocarbon-macromolecular adducts and anti-adduct antibodies in humans. Int Arch Occup Environ Health 60(3): 157–162.3384480
*Weston A, Santella RM, Bowman ED. 1994. Detection of polycyclic aromatic hydrocarbon metabolites in urine from coal tar treated psoriasis patients and controls. Polycyclic Aromatic Compounds 5:241–247.
*Weyand EH, Bevan DR. 1986. Benzo(a)pyrene disposition and metabolism in rats following intratracheal instillation. Cancer Res 46:5655–5661.3756912
*Weyand EH, Bevan DR. 1987a. Covalent binding of benzo(a)pyrene to macromolecules in lung and liver of rats following intratracheal instillation. Cancer Lett 36:149–159.2441851
*Weyand EH, Bevan DR. 1987b. Species differences in disposition of benzo(a)pyrene. Drug Metab Dispos 15:442–448.2888614
*Weyand EH, Bevan DR. 1988. Benzo(a)pyrene metabolism in vivo following intratracheal administration. In: Cooke M, Dennis AJ, eds., Polynuclear aromatic hydrocarbons: A decade of progress. Columbus, OH: Battelle Press, 913–923.
*Weyand EH, LaVoie EJ. 1988. Comparison of PAH: DNA adduct formation and tumor initiating activity in newborn mice (meeting abstract). Proceeding of the Annual Meeting of the American Association for Cancer Res 29:A390.
*Weyand EH, Wu Y. 1994. Genotoxicity of manufactured gas plant residue (MGP) in skin and lung of mice following MGP ingestion or topical administration. Polycyclic Aromatic Compounds 6:35–42.
*Weyand EH, Rice JE, LaVoie EJ. 1987. 32P-postlabeling analysis of DNA adducts from non-altemant PAH using thin-layer and high performance liquid chromatography. Cancer Lett 37:257–266.3677058
*Weyand EH, Geddie N, Rice JE, . 1988. Metabolism and mutagenic activity of benzo[k]fluoranthene and 3-, 8- and 9-fluorobenzo[k]fluoranthene. Carcinogenesis 9(7):1277–1281.3383345
*Weyand EH, Pate1 S, LaVoie EJ, . 1990. Relative tumor initiating activity of benzo(a)fluoranthene, benzo(b)fluoranthene, naphthol(1,2-b)fluoranthene and naphtho(2,1-a)fluoranthene on mouse skin. Cancer Lett 52(3):229–234.2379145
*Weyand EH, Wu Y, Pate1 S. 1991a. Urinary excretion and DNA binding of coal tar components on B6C3F_1_ mice following ingestion. Chem Res Toxicol 4:93–100.
*Weyand EH, Wu Y, Pate1 S, . 1991b. Biochemical effects of coal tar in mice following ingestion. In: Garriques P, Lamotte M, eds. Polycyclic aromatic compounds. Synthesis, properties, analytical measurements, occurrence, and biological effects. Proceedings of the thirteenth international symposium on polynuclear aromatic hydrocarbons. Philadelphia, PA: Gordon and Breach.
*Weyand EH, Amin S, Sodhi R, . 1991~. Effects of methyl substitution on the metabolism and binding of benz[e]acephenanthrylene. In: Garriques P, Lamotte M, eds. Polycyclic aromatic compounds. Synthesis, properties, analytical measurements, occurrence, and biological effects. Proceedings of the thirteenth international symposium on polynuclear aromatic hydrocarbons. Philadelphia, PA: Gordon and Breach.
*Weyand EH, Amin S, Huie K, . 1992a. Effects of fluorine substitution on the DNA binding and tumorigenicity of benzo[b]fluoranthene in mouse epidermis. Chem Biol Interactions 71:279–290.
*Weyand EH, He Z-H, Ghodrati Y, . 1992b. Effect of fluorine substitution on benzo(j)fluoranthene genotoxicity. Chem Biol Interact 84:37–53.1394615
*Weyand EH, Bryla P, Wu Y, . 1993a. Detection of the major DNA adducts of benzo(j)fluoranthene in mouse skin: Nonclassical dihydrodiol epoxides. Chem Res Toxicol 6:117–124.8448341
*Weyand EH, Cai Z-W, Wy Y, . 1993b. Detection of the major DNA adducts of benzo(b)fluoranthene on mouse skin: Role of phenolic dihydrodiols. Accepted for publication by Chem Res Toxicol.
*Weyand EH, Wu Y, Pate1 S. 1994. Biochemical effects of manufactured gas plant residue following ingestion by B6C3F_1_ mice. J Toxicol Environ Health 42 89–107.8169998
*White CM, Lee ML. 1980. Identification and geochemical significance of some aromatic components of coal. Geochim Cosmochim Acta. 44: 1825–1832.
White J, White A. 1939. Inhibition of growth of the rat by oral administration of methylcholanthrene, benzpyrene, or pyrene and the effects of various dietary supplements. J Biol Chem 131:149–161.
White JB, Vanderslice RR. 1980. POM source and ambient concentration data: Review and analysis. Washington, D.C. U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/7-80-044.
*White KJ, Holsapple MP. 1984. Direct suppression of in vitro antibody production by mouse spleen cells by the carcinogen benzo[a]pyrene but not by the congener benzo[e]pyrene. Cancer Res 44:3388–3393.6331644
*White KJ, Lysy HH, Holsapple MP. 1985. Immunosuppression by polycyclic aromatic hydrocarbons: A structure-activity relationship in B6C3F_l_ and DBA/2 mice. Immunopharmacology 9:155–164.4040508
*WHO. 1971. International standards for drinking-water. Third Edition. Geneva, Switzerland: World Health Organization, 37.
*Wielgosz SM, Brauze D, Pawlak AL. 1991. Ah locus-associated differences in induction of sister-chromatid exchanges and in DNA adducts by benzo[a]pyrene in mice. Mutat Res 246(1):129–137.1846026
*Wiencke JK, McDowell ML, Bode11 WJ. 1990. Molecular dosimetry of DNA adducts and sister chromatid exchanges in human lymphocytes treated with benzo(a)pyrene. Carcinogenesis 11(9):1497–1502 2401041
*Wilcox AJ, Baird DD, Weinberg CR. 1989. Do women with childhood exposure to cigarette smoking have increased fecundability? Am J Epidemiol 129: 1079–1083.2705428
Wild SR, Berrow ML, McGrath SP, . 1992. Polynuclear aromatic hydrocarbons in crops from long-term field experiments amended with sewage sludge. Environ Poll 76(1):25–32.
*Wild SR, Jones KC. 1993. Biological and abiotic losses of polynuclear aromatic hydrocarbons (PAHs) from soils freshly amended with sewage sludge. EnvironToxicol Chem 12:5–12
*Wild SR, Mitchell DJ, Yelland CM, . 1992. Wasted municipal solid waste incinerator fly ash as a source of polynuclear aromatic hydrocarbons (PAHs) to the environment. Waste Manag Res 10(1):99–111.
*Willems MI, Roggeband R, Baan RA, . 1991. Monitoring the exposure of rats to benzo(a)pyrene by the determination of mutagenic activity in excreta, chromosome aberrations and sister chromatid exchanges in peripheral blood cells, and DNA adducts in peripheral blood lymphocytes and liver. Mutagenesis 6(2):151–158.2056917
*Williams PT, Taylor DT. 1993. Aromatization of tire pyrolysis oil to yield polycyclic aromatic hydrocarbons. Fuel 72(11): 1469–1474.
Williams GM, Laspia MF, Dunkel VC. 1982. Reliability of the hepatocyte primary culture/DNA repair test in testing of coded carcinogens and noncarcinogens. Mutat Res 97:359–370.7144803
*Williams R, Meares J, Brooks L, . 1994. Priority pollutant PAH analysis of incinerator emission particles using HPLC and optimized fluorescence. Int J Environ Anal Chem 54(4):299–314.
*Wilson JS, Holland LM. 1988. Periodic response difference in mouse epidermis chronically exposed to crude-oils or b(a)p males vs. females. Toxicology 50(1):83–94.3388432
*Wilson SC, Jones KC. 1993. Bioremediation of soil contaminated with polynuclear aromatic hydrocarbons (PAHs): a review. Environ Pollut 81(3):229–249.15091809
*Wilson RH, DeEds F, Cox AJ. 1947. The carcinogenic activity of 2-acetaminofluorene: IV. Action of related compounds. Cancer Res 7:453–458.
*Wilson JT, McNabb JF, Cochran JW, . 1986. Influence of microbial adaptation on the fate of organic pollutants in ground water. Environ Toxicol Chem 721–726.
*Windholz M. 1983. The Merck index. 10th ed. Rahway, NJ: Merck and Co.
Windsor JG, Hites RA. 1979. Polycyclic aromatic hydrocarbons in Gulf of Maine sediments and Nova Scotia sils. Geochim Cosmochim Acta 43:27–33.
Wise SA, Chesler SN, Hilpert LR, . 1985. Characterization of polycyclic aromatic hydrocarbon mixtures from air particulate samples using liquid chromatography, gas chromatography, and mass spectrometry. In: Cooke M, Dennis AJ, eds. Polynuclear aromatic hydrocarbons: Mechanisms, methods and metabolism. Columbus, OH: Battelle Press, 1413–1427.
*Withey JR, Law FCP, Endrenyi L. 1991. Pharmacokinetics and bioavailability of pyrene in the rat. J Toxicol Environ Health 32(4):429–447.1826747
*Withey JR, Shedden J, Law FCP, . 1992. Distribution to the fetus and major organs of the rat following inhalation exposure to pyrene. J Appl Toxicol 12(3):223–231.1629519
*Withey JR, Law FCP, Endrenyi L. 1993a. Percutaneous uptake, distribution, and excretion of pyrene in rats. J Toxicol Environ Health 40:601–612.8277521
*Withey JR, Shedden J, Law FCP, . 1993b. Distribution of benzo[a]pyrene in pregnant rats following inhalation exposure and a comparison with similar data obtained with pyrene. J Appl Toxicol 13(3):193–202.8326089
Wojciechowski JP, Kaur P, Sabharwal PS. 1981. Comparison of metabolic systems required to activate pro-mutagens/carcinogens in vitro for sister-chromatid exchange studies. Mutat Res 88:89–97.6782474
*Wojdani A, Alfred LJ. 1984. Alterations in cell-mediated immune functions induced in mouse splenic lymphocytes by polycyclic aromatic hydrocarbons. Cancer Res Mar 44(3):942–945.
Wojdani AM, Attarzadeh G, Wolde-Tsadik, . 1984. Immunocytotoxicity effects of polycyclic aromatic hydrocarbons on mouse lymphocytes. Toxicology 31:181–189.6330935
*Wolfe JM, Bryan WR. 1939. Effects induced in pregnant rats by injection of chemically pure carcinogenic agents. Am J Cancer 36:359–368.
*Wolff RK, Griffith WC, Henderson RF, . 1989a. Effects of repeated inhalation exposures to 1-nitropyrene, benzo(a)pyrene, Ga_2_O_3_, particles, and SO, alone and in combinations on particle clearance, bronchoalveolar lavage fluid composition, and histopathology. J Toxicol Environ Health 27(1):123–138.2724363
*Wolff RK, Sun JD, Bond JA, . 1989b. Repeated inhalation exposures to 1-nitropyrene (NP) or benzo(a)pyrene (BaP) in association with Ga203 particles and S02: Tissue distribution, binding, and metabolism of (^14^C)NP and (^14^C)BaP. Inhal Toxicol 1(1):79–94.
*Wolff MS, Herbert R, Marcus M, . 1989~. Polycyclic aromatic hydrocarbon (PAH) residues on skin in relation to air levels among roofers. Arch Environ Health 44(3):157–163.2751351
*Woo CS, D’Silva AP, Fassel VA. 1980. Characterization of environmental samples for polynuclear aromatic hydrocarbons by an x-ray excited optical luminescence technique. Anal Chem 52:159–164.
Wood AW, Levin W, Ryan D, . 1977. High mutagenecity of metabolically activated chrysene 1,2-dihydrodiol: Evidence for bay region activation of chrysene. Biochem Biosphys Res Comm 78:847.
Wood AW, Levin W, Thomas PE, . 1978. Metabolic activation of dibenz(a,h)anthracene and its dihydrodiols to bacterial mutagens. Cancer Res 38:1967–1973.350381
*Wood AW, Chang RL, Levin W, . 1979a. Mutagenicity and tumorigenicity of phenanthrene and chrysene epoxides and diol epoxides. Cancer Res 39:4069–4077.383279
*Wood AW, Levin W, Thakker DR, . 1979b. Biological activity of benzo[e]pyrene: An assessment based on mutagenic activities and metabolic profiles of the polycyclic hydrocarbon and its derivatives. J Biol Chem 254(11):4408–4415.374411
*Wood AW, Chang RL, Huang MT, . 1980. Mutagenicity of benzo(e)pyrene and triphenylene tetrahydroepoxides and diol-epoxides in bacterial and mammalian cells. Cancer Res 40:1985–1989.6989494
Wu RM, Jiang Y-M, Ge N-C, . 1985. Determination of trace amounts of organic pollutants in the Yellow River by capillary column gas chromatography-mass spectrometry. Int J Environ Anal Chem 22:115–126.
*Wu Y, Kim SJ, Weyand EH. 1994. Bioavailability of manufactured gas plant residue (MPG) components in mice following ingestion: comparison of adulterated powder and gel diets. Polycyclic Aromatic Hydrocarbons 7: 175–182.
*Wynder EL, Hoffmann D. 1959a. A study of tobacco carcinogenesis: VII. The role of higher polycyclic hydrocarbons. Cancer 12:1079–1086.13846285
*Wynder EL, Hoffmann D. 1959b. The carcinogenicity of benzofluoranthene. Cancer 12:1194.13846287
*Wynder EL, Hoffmann D. 1967. Tobacco and tobacco smoke. New York, NY: Academic Press.
Wynder EL, Ritz LFN. 1957. Effect of concentrations of benzopyrene in skin carcinogenesis. J Natl Cancer Inst 19:361–370.13502721
Wynder EL, Spranger JW, Fark MM. 1960. Dose-response studies with benzo[a]pyrene. J Natl Cancer Inst 13:106–110.
*Xiao Y, Von Tungein LS, Chou MW, . 1993. Effect of caloric restriction on the metabolism of 7-bromobenz[a]anthrecene and 7-fluorobenz[a]anthracene by male B6C3F_1_ mouse liver microsomes: reduction of metabolic activation pathway. Age 17:160–165.
*Xu B-X, Fang Y-Z. 1988. Determination of polynuclear aromatic hydrocarbons in water by flotation enrichment and HPLC. Talanta 35(11):891–894.18964638
Ya Khesina A, Shcherback NP, Shabad LM, . 1969. Benzpyrene breakdown by the soil microflora. Bull Exp Biol Med 68:70.
*Yabiku HY, Martins MS, Takahashi MY. 1993. Levels of benzo[a]pyrene and other polycyclic aromatic hydrocarbons in liquid smoke flavour and some smoked foods. Food Addit Contam 10(4):399–405.8405579
*Yamagiwa K, Ichikawa K. 1918. Experimental study of the pathogenesis of carcinoma. J Cancer Res 3:1–29.
*Yamazaki H, Kakiuchi Y. 1989. The uptake and distribution of benzo(a)pyrene in rat after continuous oral administration. Toxicol Environ Chem 24(1/2):95–104.
*Yamazaki H, Terada M, Tsuboi A, . 1987. Distribution and binding pattern of benzo(a)pyrene in rat liver, lung and kidney constituents after oral administration. Toxicol Environ Chem 15:71–81.
*Yamazaki H, Imamura E, Kamei S, . 1990. Polycyclic aromatic hydrocarbons affect the calcium ionophore induced activation of rabbit platelet. Chemosphere 21(1/2):21–28.
Yang SK. 1988. Stereoselectivity of cytochrome P-450 isozymes and epoxide hydrolase in the metabolism of polycyclic aromatic hydrocarbons. Biochem Pharmacol 37(1):61–70.3276319
*Yang JJ, Roy TA, Mackerer CR. 1986. Percutaneous absorption of anthracene in the rat: Comparison of in vivo and in vitro results. Toxicol Ind Health 2:79–84.
*Yang JJ, Roy TA, Krueger AJ, . 1989. In-vitro and in-vivo percutaneous absorption of benzo-a-pyrene from petroleum crude-fortified soil in the rat. Bull Environ Contam Toxicol 43(2):207–214.2775887
*Yang SYN, Connell DW, Hawker DW, . 1991. Polycyclic aromatic hydrocarbons in air soil and vegetation in the vicinity of an urban roadway. Sci Total Environ 102:229–240.
*Yang Y, Sjovall J, Rafter J, . 1994. Characterization of neutral metabolites of benzo[a]pyrene in urine from germfree rats. Carcinogenesis 15(4):681–687.8149480
*Yanysheva NY, Balenko NV, Chemichenko IA, . 1993. Peculiarities of carcinogenesis under simultaneous oral administration of benzo[a]pyrene and o-cresol in mice. Environ Health Perspect 101(Supp 3):341–344.8143642
*Yoshikawa T, Ruhr LP, Flory W, . 1987. Toxicity of polycyclic aromatic hydrocarbons: III. Effects of beta-naphtoflavone pretreatment on hepatotoxicity of compounds produced in the ozonation or NOZnitration of phenanthrene and pyrene in rats. Vet Hum Toxicol 29: 113–117.3576942
*Zaleski J, Kwei GY, Thurman RG, . 1991. Suppression of benzo[a]pyrene metabolism by accumulation of triacylglycerols in rat hepatocytes: Effects of high-fat and food-restricted diets. Carcinogenesis (Eynsham) 12(11):2073–2080.
*Zepp RG, Schlotzhauer PF. 1979. In: Jones PW, Leber P, eds. Polynuclear aromatic hydrocarbons. Ann Arbor MI: Ann Arbor Science, 141.
*Zhao XL, Ho W, Shiu J-H, . 1990a. Effects of benzo(a)pyrene on the humoral immunity of mice exposed by single intraperitoneal injection. Chinese J Prevent Med 24(4):220–222.
*Zhao ZH, Quan WY, Tian DH. 1990b. Urinary 1-hydroxypyrene as an indicator of human exposure to ambient polycyclic aromatic hydrocarbons in a coal-burning environment. Sci Total Environ 92:145–154.2326620
*Zheng G-Q, Kenney PM, Zhang J, . 1993. Chemoprevention of benzo[a]pyrene-induced forestomach cancer in mice by natural phthalides from celery seed oil. Nutr Cancer 19:77–86.8446516
Zijlstra JA, Vogel EW. 1984. Mutagenecity of 7,12-dimethylbenz[a]anthracene and some other aromatic mutagens in Drosophila melanogaster. Mutat Res 125:243–261.6422284