# 7 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding polycyclic aromatic hydrocarbons (PAHs) in air, water, and other media are summarized in Table 7-1.

An MRL of 0.6 mg/kg/day has been derived for intermediate-duration oral exposure (15-364 days) to acenaphthene, based on a minimal LOAEL of 175 mg/kg/day for liver weight in mice (EPA 1989c).

An MRL of 0.4 mg/kg/day has been derived for intermediate-duration oral exposure (15-364 days) to fluoranthene, based on a minimal LOAEL of 125 mg/kg/day for increased liver weight in mice (EPA 1988e).

An MRL of 0.4 mg/kg/day has been derived for intermediate-duration oral exposure (15-364 days) to fluorene, based on a minimal LOAEL of 125 mg/kg/day for relative liver weight in mice (EPA 1989e).

Reference doses have been developed by EPA for anthracene (0.3 mg/kg/day), acenaphthene (0.06 mg/kg/day), fluoranthene (0.04 mg/kg/day), fluorene (0.04 mg/kg/day), and pyrene (0.03 mg/kg/day). No reference concentrations exists for any of the PAHs.

PAHs are regulated under The Emergency Planning and Community Right-to-Know (EPCRA) standards of 40 CFR Subpart J. EPCRA requires owners and operators of certain facilities that manufacture, import, process, or otherwise use these chemicals to report annually their release of those chemicals to any environmental media.

OSHA regulates the benzene soluble fraction of coal tar pitch volatiles and mineral oil mist, which contain several of the PAH compounds. Employers of workers who are occupationally exposed must institute engineering controls and work practices to reduce and maintain employee exposure at or below permissible exposure limits (PEL). The employer must use engineering and work controls, if feasible, to reduce exposure to or below an 8-hour time-weighted average (TWA) of 0.2 mg/m^3^ for coal tar pitch volatiles and 5 mg/m^3^ for mineral oil mist.

PAHs are regulated by the Clean Water Effluent Guidelines in Title 40, Sections 400-475, of the Code of Federal Regulations. For each point source category, PAHs may be regulated as a group of chemicals controlled as Total Toxic Organics, may have a specific regulatory limitation, or may have a zero discharge limitation. The point source categories for which the PAHs are controlled as a Total Toxic Organic include electroplating, and metal molding and casting. The point source categories for which the PAHs have specific regulatory limitations include organic chemicals, plastics, and synthetic fibers; cokemaking; and nonferrous metals manufacturing.

Under the Resource Conservation and Recovery Act (RCRA), several PAHs are listed as hazardous wastes when they are discarded commercial chemical products, off-specification species, container residues, and spill residues (40 CFR 261.33).

TABLE 7-1 Regulations and Guidelines Applicable to Polycyclic Aromatic Hydrocarbons

Agency | | Description | Information | | Reference
[underlined: INTERNATIONAL]
IARC | | Carcinogenic classification^a^ | | | IARC 1987; IARC 1984; IARC 1984; IARC 1983; IARC 1973
IARC | | (B[a]A; B[a]P) | Group 2A^b^ | | IARC 1987; IARC 1984; IARC 1984; IARC 1983; IARC 1973
IARC | | (B[b]F; B[j]F; B[k]F; I[123cd]P) | Group 2B^c^ | | IARC 1987; IARC 1984; IARC 1984; IARC 1983; IARC 1973
IARC | | (Anthracene; B[ghi]P; B[e]P; Chrysene; Fluoranthene; Fluorene; Phenanthrene; Pyrene) | Group 3^d^ | | IARC 1987; IARC 1984; IARC 1984; IARC 1983; IARC 1973
IARC | | (Mineral oil mists) | Group 1
IARC | | | | | IARC 1984
IARC | | Occupational exposure limits
IARC | | Oil mists, mineral
IARC | | Australia, Belgium, German Democratic Republic, Italy, Netherlands, Switzerland | 5 mg/m^3^ (TWA
IARC | | Japan, Finland, Sweden | 3 mg/m^3^ (TWA)
IARC | | Coal-tar pitch volatiles | 0.2 mg/m^3^ (TWA)
IARC | | Australia, Belgium, Italy, Netherlands, Switzerland, Yugoslavia
WHO | | European standard for drinking water^e^ | 0.2 µg/L | | WHO 1971
[underlined: NATIONAL]
Regulations:
a. | Air: | | 0.2 mg/m^3^
a. | OSHA | PEL, TWA | | | 29 CFR 1910.1000; 29 CFR 1910.1002; OSHA 1993; ACGIH 1991
a. | OSHA | Coal tar pitch volatiles-benzene soluble fraction^f^ | | | 29 CFR 1910.1000; 29 CFR 1910.1002; OSHA 1993; ACGIH 1991
a. | OSHA | Oil mist, mineral | 5 mg/m^3^ | | 29 CFR 1910.1000
a. | EPA | Hazarouds Air Pollutants: Proposed Regulations Governing Constructed, Reconstructed or Modified Major Sources | Yes | | 59 FR 15504; April 1, 1994; (40 CFR 63.44)
b. | Non-specific media:
b. | EPA | Solid Waste | | | 40 CFR Subchapter I
b. | EPA | Criteria for municipal solid waste landfills | | | 40 CFR 258
b. | EPA | List of hazardous inorganic and organic constituents (all PAHs) | Yes | | 40 CFR App. II
b. | EPA | Identification and Listing of Hazardous Waste | Yes | | 40 CFR 261
b. | EPA | Off-specification and discarded materials, and residues (B[a]A, B[a]P, Chrysene, DB[a,h]A, DB[a,i]P, Fluoranthene, I[1,2,3-cd]P) | | | 40 CFR 261.33
b. | EPA | Basis for listing hazardous waste (Acenaphthylene; B[a]A; B[a]P; B[b]F; B[k]F; Chrysene; DB[a,h]A; Fluoranthene; I[1,2,3-cd]P) | Yes | | 40 CFR 261, App. VII
b. | EPA | Hazardous constituents of waste (B[a]A; B[b]F; B[j]F; B[k]F; B[a]P; Chrysene; DB[a,e]P; DB[a,h]P; DB[a,i]P; Fluoranthene, I[1,2,3-cd]P) | Yes | | 40 CFR 261, App. VIII
b. | EPA | Waste excluded from nonspecific sources | Yes | | 40 CFR 261, App. IX
b. | EPA | Carbamate production identification and listing of hazardous waste: oral and inhalation toxicity information for waste constituents (Notice of proposed rulemaking) | Yes | | 59 FR 9808; March 1, 1994; (40 CFR 261.32); EPA 1994
b. | EPA | Standards for Owners, and Operators of Hazardous Waste Treatment, Storage & Disposal Facilities | Yes | | 40 CFR 264
b. | EPA | Groundwater monitoring list (all PAHs) | | | 40 CFR 264, App. IX
b. | EPA | Standards for the Management of Specific Hazardous Wastes and Specific Types of Hazardous Waste Management Facilities | | | 40 CFR 266
b. | EPA | Limits for exclusion of waste-derived residues | | | 40 CFR 266, App. VII
b. | EPA | (B[a]A) | 1×10^−4^ mg/kg
b. | EPA | (DB[a,h]A) | 7×10^−6^ mg/kg
b. | EPA | Land Disposal Restrictions | | | 40 CFR 268
b. | EPA | Waste to be evaluated (B[a]A; B[a]P; Chrysene; DB[a,h]A; I[1,2,3-cd]P) | Yes | | 40 CFR 268.10
b. | EPA | List of wastes to be identified by May 8, 1990 | Yes | | 40 CFR 268.12
b. | EPA | Land disposal treatment concentrations | | | 40 CFR 268.43
b. | EPA | Waste No. F039 | Wastewaters (mg/L) | Non-wastewaters (mg/kg)
b. | EPA | Acenaphthalene | 0.059 | 3.4
b. | EPA | Acenaphthene/Anthracene/Fluorene | 0.059 | 4.0
b. | EPA | B[a]A; Chrysene | 0.059 | 8.2
b. | EPA | B[b]F; B[k]F | 0.055 | 3.4
b. | EPA | B[g,h,i]P | 0.055 | 1.5
b. | EPA | B[a]P | 0.061 | 8.2
b. | EPA | DB[a,h]A | 0.055 | 8.2
b. | EPA | DB[a,e]P | 0.061 | NA
b. | EPA | Fluoranthene | 0.068 | 8.2
b. | EPA | Phenanthrene | 0.059 | 3.1
b. | EPA | Pyrene | 0.067 | 8.2
b. | EPA | Waste No. K035
b. | EPA | Acenaphthrene; Anthracene, B[a]P; DB[a,h]A; Fluorene; I[1,2,3-cd]P | NA | 3.4
b. | EPA | B[a]A; Chrysene; Phenanthrene | 0.059 | 3.4
b. | EPA | Fluoranthene | 0.068 | 3.4
b. | EPA | Pyrene | 0.067 | 8.2
b. | EPA | Waste No. K048
b. | EPA | B[a]P | 0.047 | 12
b. | EPA | Chrysene | 0.043 | 15
b. | EPA | Fluorene | 0.011 | 14
b. | EPA | Phenanthrene | 0.033 | 42
b. | EPA | Pyrene | 0.047 | 36
b. | EPA | Waste No. K087
b. | EPA | Acenaphthalene; Chrysene; Fluoranthene; I[1,2,3-cd]P; Phenanthrene | 0.028 | 3.4
b. | EPA | Waste No. K049
b. | EPA | Anthracene | 0.039 | 28
b. | EPA | B[a]P | 0.047 | 12
b. | EPA | Chrysene | 0.043 | 15
b. | EPA | Phenanthrene | 0.033 | 42
b. | EPA | Pyrene | 0.047 | 3.6
b. | EPA | Waste No. K051
b. | EPA | Acenaphthene | 0.05 | NA
b. | EPA | Anthracene | 0.039 | 28
b. | EPA | B[a]A | 0.043 | 20
b. | EPA | Phenanthrene | 0.011 | 14
b. | EPA | Pyrene | 0.033 | 42
b. | EPA | Waste No. U018, U050 (B[a]A; Chrysene) | 0.059 | 8.2
b. | EPA | U022 (B[a]P) | 0.061 | 8.2
b. | EPA | U063 (DB[a,h]A) | 0.055 | 8.2
b. | EPA | U120 (Fluoranthene) | 0.068 | 8.2
b. | EPA | U137 (I[1,2,3-cd]P) | 0.0055 | 8.2
b. | EPA | Requirements Authorization of State Hazardous Waste Programs | | | 40 CFR 271
b. | EPA | Regulations implementing the HSWA of 1984 | Yes | | 40 CFR 271.1
b. | EPA | Proposed rule: Universal treatment standards for organics | Yes | | 58 FR 48092; Sept. 14, 1993
b. | EPA | Maximum grab sample (non-wastewaters) | | | (40 CFR 148, 260, 261, 268, 271)
b. | EPA | Acenaphthalene; acenaphthene; anthracene; B[a]A; B[a]P; chrysene; fluoranthene; fluorene; I[1,2,3-cd]P | 3.4 mg/kg
b. | EPA | B[b]F; B[k]F | 6.8 mg/kg
b. | EPA | B[g,h,i]P | 1.8 mg/kg
b. | EPA | DB[a,h]A; pyrene | 8.2 mg/kg
b. | EPA | Phenanthrene | 5.6 mg/kg
b. | EPA | Maximum grab sample (wastewaters)
b. | EPA | Acenaphthalene; acenaphthene; anthracene; B[a]A; chrysene; fluorene; phenanthrene | 0.059 mg/L
b. | EPA | B[a]P; DB[a,e]P | 0.061.mg/L
b. | EPA | B[b]F; B[k]F | 0.11 mg/L
b. | EPA | B[g,h,i]P; I[1,2,3-cd]P | 0.0055 mg/L
b. | EPA | DB[a,h]A | 0.055 mg/L
b. | EPA | Fluoranthene | 0.068 mg/L
b. | EPA | Pyrene | 0.067 mg/L
b. | EPA | Proposed rule: BDAT standard
b. | EPA | Maximum grab sample (non-wastewaters)
b. | EPA | B[a]A; B[a]P; chrysene; I[1,2,3-cd]P | 3.4 mg/kg
b. | EPA | B[b]F; B[k]F | 6.8 mg/kg
b. | EPA | DB[a,h]A | 8.2 mg/kg
b. | EPA | Maximum grab samples (wastewaters)
b. | EPA | B[a]A; chrysene | 0.059 mg/L
b. | EPA | B[a]P | 0.061 mg/L
b. | EPA | B[b]F; B[k]F | 0.11 mg/L
b. | EPA | I[1,2,3-cd]P | 0.0055 mg/L
b. | EPA | DB[a,h]A | 0.055 mg/L
b. | EPA | Superfund, Emergency Planning, and Community Right-To-Know Programs | | | 40 CFR Subchapter J
b. | EPA | Desigination, Reportable Quantities and Notification | | | 40 CFR 302
b. | EPA | Designation and Reportable Quantities of Hazardous Waste | | | 40 CFR 302.4
b. | EPA | Acenaphthene; chrysene, fluoranthene, I[1,2,3-cd]P | 100 pounds
b. | EPA | Acenaphthylene; anthracene, B[k]F; B[g,h,i]P; fluorene; phenanthrene, pyrene | 5,000 pounds
b. | EPA | B[a]A | 10 pounds
b. | EPA | B[b]F; B[a]P; DB[a,h]A | 1 pound
b. | EPA | Emergency Planning and Notification | | | 40 CFR 355
b. | EPA | List of extremely hazardous substances and threshold planning quanitties | | | 40 CFR 355, App. A
b. | EPA | Pyrene | 1,000/10,000 lbs.
b. | EPA | Toxic Chemical Release Reporting: Community Right-to-Know | | | 40 CFR 372
b. | EPA | Toxic chemical listing (anthracene) | Yes | | 40 CFR 272.65
b. | EPA | Proposed Rule: National oil and hazardous substance pollution contingency plan; QA/QC of chemical analysis of oil compositoin using GC/MS | Yes | | 58 FR 54702; October 22, 1993; 40 CFR 300
b. | EPA | Proposed Rule: Addition of certain chemicals; toxic chemical release reporting; comunity right-to-know | Yes | | 59 FR 1788; January 12, 1994; 40 CFR 372
b. | EPA | Toxic Substances Control Act | | | 40 CFR; Subchapter R
b. | EPA | Reporting and Recordkeeping Requirements | | | 40 CFR 704
b. | EPA | Chemical substance matrix for CAIR reporting (Phenanthrene, pyrene) | Yes | | 40 CFR 704.225
b. | EPA | Health and Safety Data Reporting | | | 40 CFR 716
b. | EPA | Listing of substances and mixtures (anthracene) | Yes | | 40 CFR 716.120
b. | EPA | Significant New Uses of Chemical Substances | | | 40 CFR 721
b. | EPA | Fluorene substituted aromatic amines | Yes | | 40 CFR 721.3764
b. | EPA | Provisional Test Guidelines | | | 40 CFR 795
b. | EPA | Protocol for determining anaerobic microbiological transformation rate data for chemicals in the subsurface environment | Yes | | 40 CFR 795.54
b. | DOT | Hazardous materials transport | Yes | | 49 CFR 171; DOT 1991
c. | Water
c. | EPA | Water Programs | | | 40 CFR Subchapter D
c. | EPA | National Pollution Discharge Elimination System (NPDES) | | | 40 CFR 122
c. | EPA | Testing requirements for NPDES permits
c. | EPA | B[a]P; acenaphthene; aenaphthalene | Yes | | 40 CFR 122, App. D
c. | EPA | Guidelines Establishing Test Procedures for the Analysis of Pollutants | | | 40 CFR 136
c. | EPA | Guidelines for testing pollutants under the CWA (all PAHs) | | | 40 CFR 136.3
c. | EPA | Testing procedures for PAHs base/neutrals and acids, semivolatile organic compounds (all PAHs) | Yes | | 40 CFR 136, App. A Methods 610, 625, 1625 (Revision B)
c. | EPA | National Primary Drinking Water Regulations | | | 40 CFR 141
c. | EPA | Effective dates (B[a]P) | Yes | | 40 CFR 141.6
c. | EPA | Sampling and Analytical Requirements for organic chemicals (B[a]P) | Yes | | 40 CFR 141.24
c. | EPA | Public notification under the SDWA (B[a]P) | 0.002 ppm | | 40 CFR 141.32
c. | EPA | Special monitoring for organic and inorganic compounds (B[a]P) | Yes | | 40 CFR 141.40
c. | EPA | Maximum contaminant levels for organic contaminants (B[a]P) | 0.0002 mg/L | | 40 CFR 141.61
c. | EPA | Final Rule: Water quality standards; numeric criteria for priority toxic pollutants; states’ compliance | Yes | | 57 FR 60848; Dec. 22, 1992; (40 CFR 131)
c. | EPA | Human health (10^−6^ risk for carcinogens); for consumption of (µg/L): | Water and Organism | Organism Only
c. | EPA | Anthracene | 9,600 | 110,000
c. | EPA | B[a]A; B[a]P; B[b]F; B[k]F; chrysene; DB[a,h]A; I[1,2,3-cd]P | 0.0028 | 0.031
c. | EPA | Fluoranthene | 300 | 370
c. | EPA | Fluorene | 1,300 | 14,000
c. | EPA | Pyrene | 960 | 11,000
c. | EPA | Proposed Rule: National primary and secondary drinking water regulations; analytical methods for regulated drinking water contaminants (B[a]P) | Yes | | 58 FR 5622; Dec. 15, 1993; (40 CFR 141, 143)
c. | EPA | Effluent Guidelines and Standards | | | 40 CFR Subchapter N
c. | EPA | General Provisions | | | 40 CFR 401
c. | EPA | Toxic pollutants under Sec. 307(a) of the CWA (Acenaphthene, fluoranthene) | Yes | | 40 CFR 401.15
c. | EPA | General Pretreatment Regulations for Existing and New Sources of Pollution | | | 40 CFR 403
c. | EPA | Pretreatment regulations for POTWs (acenaphthene, fluoranthene) | Yes | | 40 CFR 403, App. B
c. | EPA | Electroplating Point Source Category | | | 40 CFR 413
c. | EPA | Definition of total toxic organic (TTO) (all PAHs, excluding acenaphthene) | Yes | | 40 CFR 413.02
c. | EPA | Organic Chemicals, Plastics, and Synthetic Fiber | | | 40 CFR 414
c. | EPA | Toxic effluent standards for point sources that use end-of-pipe biological treatment | Daily maximum (µg/L) | Monthly Maximum (µg/L) | 40 CFR 414.91; (58 FR 36872); July 9, 1993
c. | EPA | Acenaphthene; acenaphthylene; anthracene; B[a]A; B[k]F; Chrysene; fluorene; phenanthrene | 59 | 22
c. | EPA | Fluoranthene | 68 | 25
c. | EPA | B[a]P | 61 | 23
c. | EPA | Pyrene | 67 | 25
c. | EPA | Toxic pollutant standards for point sources that do not use end-of-pipe biological treatment | | | 58 FR 36872; (40CFT 414.101
c. | EPA | Acenaphthene; acenaphthylene; anthracene; B[a]A; B[k]F; Chrysene; fluorene; phenanthrene | 47 | 19
c. | EPA | B[a]P; pyrene | 48 | 20
c. | EPA | Fluoranthene | 54 | 22
c. | EPA | Toxic pollutant standards for indirect discharge point sources | | | 58 FR 36872; 40 CFR 414.111
c. | EPA | Acenaphthene; anthracene; fluorene; phenanthrene | 47 | 19
c. | EPA | Fluoranthene | 54 | 22
c. | EPA | Pyrene | 48 | 20
c. | EPA | Iron and Steel Manufacturing Point Source Category | | | 40 CFR 420
c. | EPA | Definition (B[a]P) | Yes | | 40 CFR 420.02
c. | EPA | Effluent limitations attainable using BAT for cokemaking B[a]P--1 day maximum (kg/kkg of product) | | | 40 CFR 420.13
c. | EPA | cokemaking--iron and steel | 0.0000319
c. | EPA | --iron and steel with physical chemical treatment | 0.0000215
c. | EPA | --merchant | 0.0000355
c. | EPA | --merchant with physical chemical treatment | 0.0000250
c. | EPA | New source performance standards (B[a]P)--1 day maximum (kg/kkg of product) | Yes | | 40 CFR 420.14
c. | EPA | cokemaking--iron and steel | 0.0000319
c. | EPA | --merchant | 0.0000355
c. | EPA | Nonferrous Metals Manufacturing Point Source Category | | | 40 CFR 421
c. | EPA | Definition of B[a]P for primary aluminum smelting | Yes | | 40 CFR 421.21
c. | EPA | Effluent limitations attainable by application of BAT for primary aluminum smelting plants (mg/kg) | Max. 1-day limit | Max. monthly avg. | 40 CFR 421.23
c. | EPA | Anode and cathode plastic plant wet air pollution control | 0.005 | 0.002
c. | EPA | Anode contact cooling and briquette quenching | 0.007 | 0.003
c. | EPA | Anode bake plant wet air pollution control (closed top) | 0.146 | 0.067
c. | EPA | Anode bake plant wet air pollution control (open top ring furnace with spray tower only | 0.002 | 0.001
c. | EPA | Anode bake plant wet air pollution control (open top ring furnace with wet ESP and spray tower) | 0.025 | 0.011
c. | EPA | Anode bake plant wet air pollution control (tunnel kiln) | 0.038 | 0.018
c. | EPA | Cathode reprocessing (with dry potline scrubbing and not commigled) | 1.181 | 0.547
c. | EPA | Cathode reprocessing (with wet potline scrubbing) | 0.000 | na
c. | EPA | Potline wet air pollution control (w/o cathode reprocessing) | 0.028 | 0.013
c. | EPA | Potline wet air pollution control (w/cathode reprocessing and not commingled) | 0.028 | 0.013
c. | EPA | Potline wet air pollution control (w/cathode reprocessing and commingled) | 0.028 | 0.013
c. | EPA | Pot room wet air pollution control | 0.056 | 0.026
c. | EPA | Potline SO_2_ emissions wet air pollution control | 0.045 | 0.021
c. | EPA | Degreasing wet air pollution control | zero | zero
c. | EPA | Pot repair and pot soaking | 0.000 | na
c. | EPA | Direct chill casting contact cooling | zero | zero
c. | EPA | Continuous rod casting contact cooling | zero | zero
c. | EPA | Stationary casting or shot casting contact cooling | 0.000 | na
c. | EPA | New Source Performance Standards for Primary Aluminum Smelting (B[a]P) (mg/kg) | Max. 1-day limit | Max. monthly avg. | 40 CFR 421.24
c. | EPA | Anode and cathode paste plant wet air pollution control | 0.000 | na
c. | EPA | Anode contact cooling and briquette quenching | 0.007 | 0.003
c. | EPA | Anode bake plant wet air pollution control | 0.000 | na
c. | EPA | Cathode reprocessing (operating with dry potline scrubbing and commingled) | 1.181 | 0.547
c. | EPA | Potline wet air pollution control | 0.000 | na
c. | EPA | Pot room wet air pollution control | 0.000 | na
c. | EPA | Potline SO_2_ emissions wet air pollution control | 0.045 | 0.021
c. | EPA | Degassing wet air pollution control | 0.000 | na
c. | EPA | Pot repair and pot soaking | 0.000 | na
c. | EPA | Direct chill casting contact cooling | zero | zero
c. | EPA | Continuous rod casting contact cooling | zero | zero
c. | EPA | Stationary casting or shot casting contact cooling | 0.000 | na
c. | EPA | Pretreatment standards for primary aluminum smelting sources (B[a]P) (mg/kg) | Max. 1-day limit | Max. monthly avg. | 40 CFR 421.26
c. | EPA | Anode and cathode paste plant wet air pollution control | 0.000 | na
c. | EPA | Anode contact cooling and briquette quenching | 0.007 | 0.003
c. | EPA | Anode bake plant wet air pollution control | 0.000 | na
c. | EPA | Cathode reprocessing (operating with dry potline scrubbing and not commingled) | 1.181 | 0.547
c. | EPA | Cathode reprocessing (operating with dry potline scrubbing and commingled) | 1.181 | 0.547
c. | EPA | Potline wet air pollution control | 0.000 | na
c. | EPA | Pot room wet air pollution control | 0.000 | na
c. | EPA | Potline SO_2_ emissions wet air pollution control | 0.045 | 0.021
c. | EPA | Degassing wet air pollution control | 0.000 | na
c. | EPA | Pot repair and pot soaking | 0.000 | na
c. | EPA | Direct chill casting contact cooling | zero | zero
c. | EPA | Continuous rod casting contact cooling | zero | zero
c. | EPA | Stationary casting or shot casting contact cooling | 0.000 | na
c. | EPA | Steam Electric Power Generating Point Source Category | | | 40 CFR 423
c. | EPA | Priority pollutants for steam power generators (all PAHs) | Yes | | 40 CFR 423, App. A
c. | EPA | Metal Finishing Point Source Category | | | 40 CFR 433
c. | EPA | Definition of total toxic organics (TTO) for metal refinishing (all PAHs) | Yes | | 40 CFR 433.11
c. | EPA | Metal Molding and Casting Point Source Category | | | 40 CFR 464
c. | EPA | Definition of TTO for aluminum casting (Acenphthene; anthracene; B[a]A; B[a]P; chrysene; fluorene; fluoranthene; phenanthrene; pyrene) | Yes | | 40 CFR 464.11
c. | EPA | Definition of TTO for copper casting (Acenphthene; acenaphthylene; anthracene; B[a]A; B[b]F; chrysene; phenanthrene; pyrene) | Yes | | 40 CFR 464.21
c. | EPA | Definition of TTO for ferrous casting (Acenaphthene; chrysene; acenaphthylene; anthracene; fluoranthene; fluorene; phenanthrene; pyrene) | Yes | | 40 CFR 464.31
c. | EPA | Definition of TTO for zinc casting (Acenaphthene; fluoranthene) | Yes | | 40 CFR 464.41
c. | EPA | Aluminum Forming Point Source Category | | | 40 CFR 467
c. | EPA | Definition of TTO for aluminum casting (Acenaphthene; acenaphtylene; anthracene; B[k]F; B[a]P; B[g,h,i]P; chrysene; DB[a,h]A; fluoranthene; fluorene, I[1,2,3-cd]P; phenanthrene; pyrene) | Yes | | 40 CFR 467.02
c. | EPA | Copper Forming Point Source Category | | | 40 CFR 468
c. | EPA | Definition of TTO for copper forming (Anthracene; phenanthrene) | Yes | | 40 CFR 468.02
Guidelines:
a. | Air:
a. | ACGIH | TLV TWA; Confirmed human carcinogens | | | ACGIH 1991
a. | ACGIH | Coal tar pitch volatiles-benzene soluble fraction | 0.2 mg/m^3^
a. | ACGIH | Phenanthrene: cyclohexane extractable fraction | 1030 mg/m^3^
a. | ACGIH | Oil mist, mineral
a. | ACGIH | TWA | 5 mg/m^3^ | | ACGIH 1991
a. | ACGIH | STEL | 10 mg/m^3^
a. | NIOSH | REL TWA | | | NIOSH 1992
a. | NIOSH | Coal tar pitch volatiles; B[a]P; cyclohexane extractable fraction | Ca^g^; 0.1 mg/m^3^
a. | NIOSH | Chrysene | Ca^g^; lowest feasible concentration
a. | NIOSH | Oil mist, mineral
a. | NIOSH | TWA | 5 mg/m^3^
a. | NIOSH | STEL | 10 mg/m^3^
b. | Water:
b. | EPA OWRS | Ambient water quality criteria for protection of human health | | | IRIS 1994
b. | EPA OWRS | Ingestion of water and organisms^h^
b. | EPA OWRS | PAHs | 0.0028 µg/L
b. | EPA OWRS | Fluoranthene | 42 µg/L
b. | EPA OWRS | Ingestion of organisms only | 0.031 µg/L
b. | EPA OWRS | PAHs | 54 µg/L
b. | EPA OWRS | Fluoranthene
b. | EPA OWRS | Organoleptic effects (acenaphthene) | 0.02 mg/L
b. | EPA OW | Drinking water standards and health advisories | | | EPA 1994
b. | EPA OW | Maximum contaminant level goal (B[a]P) for organic chemicals | 0 mg/L | | 40 CFR 141.50
b. | EPA OW | Maximum contaminant level
b. | EPA OW | (B[a]A) | 0.0001 mg/L
b. | EPA OW | (B[a]P, B[b]F, B[k]F, chrysene) | 0.0002 mg/L
b. | EPA OW | (DB[ah]A) | 0.0003 mg/L
b. | EPA OW | (I[123cd]P) | 0.0004 mg/L
b. | EPA | Clean Water Act: Toxic pollutants subject to the effluent standards of the Clean Water Act section 301(a)(1) | | | EPA 1981b (40 CFR 401.15) EPA 1991b (40 CFR 129)
b. | EPA | Polynuclear aromatic hydrocarbons (include: acenaphthene: benzanthracene; benzopyrenes; benzofluoranthene; chrysenes; dibenzoanthracenes; indenopyrenes; fluoranthenes) | Yes
c. | Non-specific media: | Carcinogenic classification^i^ | | | IRIS 1994
c. | EPA
c. | | (Fluoranthene, anthracene, acenaphthylene) | Group D
c. | | (B[a]A, I[123cd]P, DB[ah]A, chrysene, B[k]F, B[b]F, B[a]P) | Group B
c. | EPA | RfD (Oral) | | | IRIS 1994
c. | EPA | Anthracene | 0.3 mg/kg/day (u.f. 3000)
c. | EPA | Acenaphthene | 0.06 mg/kg/day (u.f. 3000)
c. | EPA | Fluoranthene | 0.04 mg/kg/day (u.f. 3000)
c. | EPA | Fluorene | 0.04 mg/kg/day (u.f. 3000)
c. | EPA | Pyrene | 0.03 mg/kg/day (u.f. 3000)
c. | EPA | Acenaphthylene; B[a]P; B[e]P; B[a]A; B[b]F; B[ghi]P; B[k]F; B[j]F; chrysene; DB[ah]A; I[123cd]P; BP; phenanthrene | No data
c. | OSHA | NRC recommendations concerning chemical hygiene in laboratories (B[a]P) | Yes | | 29 CFR 1910.1450, App. A
[underlined: STATE]
Regulations and Guidelines:
a. | Air
a. | | Average acceptable ambient air concentrations | | | NATICH 1992
a. | Arizona
a. | (B[a]P; B[a]A; DB[ah]A) | 1-hour average | 0.79 µg/m^3^
a. | (B[a]P; B[a]A; DB[ah]A) | 24-hour average | 0.21 µg/m^3^
a. | (B[a]P; B[a]A; DB[ah]A) | Annual | 0.00057 µg/m^3^
a. | Connecticut
a. | (B[a]P;) | 8-hour average | 0.1000 µg/m^3^
a. | (Coal tar pitch volatiles) | 8-hour average | 2.0000 µg/m^3^
a. | (Fluorene) | 8-hour average | 50.000 µg/m^3^
a. | (Naphthalene) | 8-hour average | 10000.0000 µg/m^3^
a. | Florida- Ft Ldle
a. | Coal tar pitch volatiles | 8-hour average | 2.00×10^−3^ µg/m
a. | Florida-Pinella | | 0.0003 µg/m^3^
a. | (B[a]P) | Annual
a. | (B[a]A) | 8- and 24-hour average | 0.00 µg/m^3^
a. | (B[a]A) | Annual | 0.00110 µg/m^3^
a. | (DB[ah]A) | Annual | 7.10×10^−5^ µg/m^3^
a. | Coal tar pitch volatiles | 8-hour average | 2.00 µg/m^3^
a. | Coal tar pitch volatiles | 24-hour average | 0.48 µg/m^3^
a. | Indiana
a. | (B[a]P) | 8-hour average | 0.100 µg/m^3^
a. | (B[a]P) | Annual | 0.0006 µg/m^3^
a. | Kansas
a. | (B[a]P) | Annual | 3.03×10^−4^ µg/m^3^
a. | (Coal tar pitch volatiles) | Annual | 0.00161 µg/m^3^
a. | Kansas-KC | | 3.03×10^−4^ µg/m^3^
a. | (B[a]P) | Annual
a. | Louisiana
a. | (Fluoranthene) | Annual | 0.0600 µg/m^3^
a. | Maryland
a. | (B[a]P; B[a]A; DB[ah]A; Fluorene; Fluoranthene; Acenaphthene; Acenaphthylene; Anthracene; B[b]F; B[k]F; B[ghi]P; Chrysene; I[123cd]P; Phenanthrene; Pyrene; B[e]P) | | 0.00 µg/m^3^
a. | Maine
a. | (B[a]P) | Annual | 5.70×10^−4^ µg/m^3^
a. | Michigan
a. | (B[a]P) | Annual | 3.00×10^−4^ µg/m^3^
a. | Nevada
a. | (Coal tar pitch volatiles) | 8-hour average | 0.0050 mg/m^3^
a. | New York | | 0.00 µg/m^3^ | | NATICH 1992
a. | (B[a]P)
a. | North Carolina
a. | (B[a]P) | Annual | 3.30×10^−5^ mg/m^3^
a. | (Coal tar pitch volatiles) | Annual | 3.30×10^−5^ mg/m^3^
a. | North Dakota
a. | (B[a]P; B[a]A; DB[ah]A; B[b]F; Chrysene; I[123cd]P) | | 0.00 µg/m^3^
a. | Pennsylvania-Phila | 1-year average | 7.00×10^−4^ µg/m^3^
a. | (B[a]P) | Annual | 7.00×10^−4^ µg/m^3^
a. | (Coal tar pitch volatiles) | 1-year average | 0.4800 µg/m^3^
a. | Texas
a. | (B[a]P) | 30-minute average | 0.03 µg/m^3^
a. | (B[a]P) | Annual | 0.003 µg/m^3^
a. | (Chrysene) | 30-minute average | 0.500 µg/m^3^
a. | (Chrysene) | Annual | 0.05 µg/m^3^
a. | Virginia | 24-hour average | 0.00 µg/m^3^
a. | (B[a]P; chrysene)
a. | (Coal tar pitch volatiles) | 24-hour average | 2.0000 µg/m^3^
a. | Vermont
a. | (B[a]P) | Annual | 3.00×10^−14^ µg/m^3^
a. | (Phenanthrene) | Annual | 1.30 µg/m^3^
a. | (Pyrene) | Annual | 3.40 µg/m^3^
a. | Washington-SWest | Annual | 6.00×10^−4^ µg/m^3^
a. | (B[a]P)
a. | Kentucky | Significant emission levels of toxic air pollutants | | | 401 KAR 63:022; NREPC 1991
a. | Kentucky | B[a]P; B[b]F; B[a]A; DB[ah]A; I[123cd]P | 5.100×10^−7^ pounds/hour
a. | Kentucky | Chrysene; coal tar pitch volatiles | 5.103×10^−5^ pounds/hour
b. | Water:
b. | | Water quality standards | | | NYSDEC 1994
b. | New York
b. | Acenaphthene | | 20 µg/L
b. | | Drinking water quality standards
b. | Arizona | | | | FSTRAC 1990
b. | (B[a]P) | | 0.003 µg/L
b. | Kansas
b. | (B[a]P) | | 0.03 µg/L
b. | (All other PAHs) | | 0.029 µg/L
b. | Maine
b. | (PAHs) | | 25 µg/L
b. | Minnesota
b. | (PAHs) | | 0.028 µg/L
b. | New Hampshire
b. | (B[a]P) | | 0.003 µg/L
b. | New Mexico
b. | (B[a]P) | | 10 µg/L
b. | (All other PAHs) | | 30 µg/L
b. | New Jersey
b. | (All PAHs) | | 1 µg/L | | NJDEP 1989
b. | ACENAPHTHYLENE
b. | | Water Quality: Human Health | | | CELDs 1994
b. | AL | Consumption of Water and Fish | ** (no value recorded)
b. | AL | Fish Consumption Only | **
b. | AZ | Numeric Water Quality Criteria | 0.003 µg/L
b. | AZ | Domestic Water Supply (DWS) | 0.002 µg/L
b. | AZ | Fish Consumption (FC) | 0.12 µg/L
b. | AZ | Full Body Contact (FBC) | NNS (no numerical standard)
b. | AZ | Partial Body Contact (PBC)
b. | MO | Human Health Protection-Fish
b. | MO | Consumption | 0.03 µg/L
b. | MO | Drinking Water Supply | 0.003 µg/L
b. | MO | (This concentration is allowed for each of a goup of PAHs)
b. | MO | Groundwater | 0.003 µg/L
b. | | Groundwater Monitoring Parameters | | | CELDs 1994
b. | AL | | Yes
b. | CO | | Yes
b. | CA | | Yes
b. | IL | | Yes
b. | LA | | Yes
b. | KY | | Yes
b. | MN | | Yes
b. | NY | | Yes
b. | OH | | Yes
b. | SC | | Yes
b. | TN | | Yes
b. | VA | | Yes
b. | WI | | Yes
b. | WV | | Yes
b. | ACENAPHTHENE
b. | | Water Quality: Human Health | | | CELDS 1994
b. | AL | Consumption of Water and Fish | 20(0) µg/L
b. | AL | Fish Consumption Only | 20(0) µg/L
b. | AZ | Numeric Water Quality Criteria
b. | AZ | Domestic Water Source (DWS) | 420 µg/L
b. | AZ | Fish Consumption (FC) | 2600 µg/L
b. | AZ | Full Body Contact (FBC) | 8400 µg/L
b. | AZ | Partial Body Contact (PBC) | 8400 µg/L
b. | MO | Class II Human Health Protection-Fish Consumption | 2700 µg/L
b. | MO | Class III Drinking Water Supply | 20 µg/L
b. | WI | Threshold conc. for substances causing taste and odor in water (not toxic to humans) | 20 µg/L
b. | OH | Water Supply
b. | OH | Public Water Supply
b. | OH | Outside mixing zone
b. | OH | Human health 30 day-average | 20 µg/L
b. | DC | Numerical Standards for Water Quality
b. | DC | Criteria for Classes (Maximum)
b. | DC | Classes A, B, C | 50.0 µg/L
b. | DC | Classes D, E | 20.0 µg/L
b. | | Water Quality: Aquatic Life | | | CELDs 1994
b. | AZ | Acute Criteria for Aquatic and Wildlife Uses
b. | AZ | Cold Water Fishery (A&Wc) | 850
b. | AZ | Warm Water Fishery (A&Ws) | 850
b. | AZ | Effluent Dominated Water (A&Wedw) | 850
b. | AZ | Ephemeral (A&We) | NNS
b. | AZ | Chronic Criteria for Aquatic and Wildlife Uses | 550 µg/L
b. | AZ | Cold Water Fishery (A&Wc) | 5,500 µg/L
b. | AZ | Warm Water Fishery (A&Ws) | NNS
b. | AZ | Effluent Dominated Water (A&Wedw)
b. | AZ | Ephemeral (A&We)
b. | CO | Aquatic life segments-organic compounds to the second power
b. | CO | Standard (acute) | 1,700 µg/L
b. | CO | Standard (chronic) | 520 µg/L
b. | HI | Numeric Standards for Toxic Pollutants
b. | HI | Applied to All Waters | 570 µg/L
b. | HI | Freshwater (acute) | 320 µg/L
b. | HI | Saltwater (acute) | NS (no standard developed)
b. | HI | Fish Consumption
b. | OH | Aquatic Life Habitat-Coldwater
b. | OH | Outside mixing zone (maximum) | 67 µg/L
b. | OH | Outside mixing zone (30-day average) | 67 µg/L
b. | OH | Inside mixing zone (maximum) | 134 µg/L
b. | OH | Aquatic Life Habitat-Limited Resource Warmwater
b. | OH | Outside mixing zone (maximum) | 67 µg/L
b. | OH | Inside mixing zone (maximum) | 134 µg/L
b. | NY | Water Classes-A, A-S, AA, AA-S
b. | NY | Standards µg/L | 20 µg/L
b. | NY | Type-health (water source)
b. | NY | Basis code-chem.correlation
b. | | Groundwater Monitoring | | | CELDs 1994
b. | AL | | Yes
b. | CO | | Yes
b. | CA | | Yes
b. | IL | | Yes
b. | LA | | Yes
b. | KY | | Yes
b. | MN | | Yes
b. | NY | | Yes
b. | OH | | Yes
b. | SC | | Yes
b. | TN | | Yes
b. | VA | | Yes
b. | WI | | Yes
b. | WV | | Yes
b. | | Groundwater Quality Standards | | | CELDs 1994
b. | MO | Class VII-Groundwater | 20 µg/L
b. | ANTHRACENE
b. | | Water Quality: Human Health | | | CELDs 1994
b. | AZ | Numeric Water Quality Criteria
b. | AZ | Domestic Water Source (DWS) | 2100 µg/L
b. | AZ | Fish Consumption (FC) | 6300 µg/L
b. | AZ | Full Body Contact (FBC) | 420000µg/L
b. | AZ | Partial Body Contact (PBC) | NNS
b. | MO | Human Health Protection-Fish | 0.03 µg/L
b. | MO | Consumption | 0.003 µg/L
b. | MO | Drinking Water Supply | 0.003 µg/L
b. | MO | Groundwater
b. | OH | Water Supply
b. | OH | Public Water Supply
b. | OH | Outside mixing zone | 0.028 0.003 µg/L
b. | OH | Human Health 30-day average
b. | | Groundwater Monitoring Parameters | | | CELDs 1994
b. | AL | | Yes
b. | CA | | Yes
b. | IL | | Yes
b. | KY | | Yes
b. | NY | | Yes
b. | OH | | Yes
b. | SC | | Yes
b. | TN | | Yes
b. | VA | | Yes
b. | WI | | Yes
b. | WV | | Yes
b. | | Water Quality: Aquatic Life | | | CELDs 1994
b. | OH | Aquatic Life Habitat-Coldwater
b. | OH | Outside mixing zone
b. | OH | Human Health 30-day average | 0.31 µg/L*
b. | OH | Aquatic Life Habitat-Limited Resource Warmwater
b. | OH | Outside mixing zone
b. | OH | Human Health 30-day average | 0.31 µg/L*
b. | *This value applies to the sum of PAHs
b. | BENZ(a)ANTHRACENE
b. | | Hazardous Constituents | | | CELDs 1994
b. | AL | | Yes
b. | IL | | Yes
b. | LA | | Yes
b. | KY | | Yes
b. | MA | | Yes
b. | ME | | Yes
b. | MD | | Yes
b. | MN | | Yes
b. | MT | | Yes
b. | NH | | Yes
b. | NJ | | Yes
b. | NE | | Yes
b. | ND | | Yes
b. | NY | | Yes
b. | OH | | Yes
b. | SC | | Yes
b. | VA | | Yes
b. | VT | | Yes
b. | WI | | Yes
b. | WV | | Yes
b. | WY | | Yes
b. | | Water Quality: Human Health | | | CELDs 1994
b. | AL | Human Health Criteria:
b. | AL | Consumption of Water and Fish | **
b. | AL | Fish Consumption Only | **
b. | AL | -Classified as a carcinogen
b. | AZ | Numeric Water Quality Criteria:
b. | AZ | Domestic Water Source (DWS) | 0.03 µg/L
b. | AZ | Fish Consumption (FC) | 0.00008 µg/L
b. | AZ | Full Body Contact (FBC) | 0.12 µg/L
b. | AZ | Partial Body Contact (PBC) | NNS
b. | AZ | -known, probable, or possible human carcinogen
b. | MO | Human Health Protection-Fish
b. | MO | Consumption | 0.03 µg/L
b. | MO | Drinking Water Supply | 0.003 µg/L
b. | MO | Groundwater | 0.003 µg/L
b. | MO | Water Supply
b. | MO | Public Water Supply
b. | OH | Outside mixing zone
b. | OH | Human health
b. | OH | 30-day average | 0.028 µg/L
b. | WI | Human Cancer Criteria*
b. | WI | Public Water Supplies
b. | WI | Warm Water Sport Fish Communities | 0.023 mg/L
b. | WI | Cold Water Communities | 0.023 mg/L
b. | WI | Great Lakes | 0.023 mg/L
b. | WI | *Human cancer criteria for PAHs are applicable to any combination of 10 PAHs (specific)
b. | WI | Human Cancer Criteria*
b. | WI | Non-Public Water Supplies
b. | WI | Warmwater Sport Fish Communities | 0.1 mg/L
b. | WI | Cold Water Communities | 0.1 mg/L
b. | WI | Warm Water and Limited Fish and Limited Aquatic | 6.1 mg/L
b. | *Human cancer criteria are applicable to any combination of 9 PAHs.
b. | | Groundwater Monitoring Parameters | | | CELDs 1994
b. | AL | | Yes
b. | IL | | Yes
b. | LA | | Yes
b. | KY | | Yes
b. | MN | | Yes
b. | NY | | Yes
b. | OH | | Yes
b. | SC | | Yes
b. | TN | | Yes
b. | VA | | Yes
b. | WI | | Yes
b. | WV | | Yes
b. | | Water Quality: Aquatic Life | | | CELDs 1994
b. | OH | Aquatic Life Habitat-Coldwater
b. | OH | Outside mixing zone
b. | OH | Human Health
b. | OH | 30-day average | 0.31 µg/L*
b. | OH | Aquatic Life Habitat-Limited Resource Warmwater
b. | OH | Outside mixing zone
b. | OH | Human Health
b. | OH | 30-day average | 0.31 µg/L*
b. | * This value applied to the sum of 13 PAHs
b. | BENZO(b)FLUORANTHENE
b. | | Water Quality: Human Health | | | CELDs 1994
b. | OH | Water Supply-Public Water Supply
b. | OH | Outside Mixing Zone
b. | OH | Human Health
b. | OH | 30-day average | 0.028 µg/L*
b. | WI | Human Cancer Criteria
b. | WI | Public Water Supplies
b. | WI | Warm Water Sport Fish Communities | 0.023 µg/L
b. | WI | Cold Water Communities | 0.023 µg/L
b. | WI | Great Lakes | 0.023 µg/L
b. | WI | Non-Public Water Supplies
b. | WI | Warm Water Sport Fish Communities | 0.1 mg/L
b. | WI | Cold Water Communities | 0.1 mg/L
b. | WI | Warm Water and Limited Fish and Limited Aquatic | 6.1 mg/L
b. | | Water Quality: Aquatic Life | | | CELDs 1994
b. | OH | Aquatic Life Habitat-Coldwater
b. | OH | Outside Mixing Zone
b. | OH | Human Health
b. | OH | 30-day average | 0.31 µg/L
b. | OH | Aquatic Life Habitat-Limited Resource Warmwater
b. | OH | Outside Mixing Zone
b. | OH | Human Health
b. | OH | 30-day average | 0.31 mg/L
b. | | Groundwater Monitoring Parameters | | | CELDs 1994
b. | AL | | Yes
b. | CO | | Yes
b. | CA | | Yes
b. | IL | | Yes
b. | LA | | Yes
b. | KY | | Yes
b. | MN | | Yes
b. | NY | | Yes
b. | OH | | Yes
b. | SC | | Yes
b. | TN | | Yes
b. | VA | | Yes
b. | WI | | Yes
b. | WV | | Yes
b. | | Hazardous Constituents | | | CELDs 1994
b. | AL | | Yes
b. | CO | | Yes
b. | IL | | Yes
b. | LA | | Yes
b. | KY | | Yes
b. | MD | | Yes
b. | MN | | Yes
b. | MT | | Yes
b. | NE | | Yes
b. | ND | | Yes
b. | NY | | Yes
b. | OH | | Yes
b. | SC | | Yes
b. | VA | | Yes
b. | VT | | Yes
b. | WI | | Yes
b. | WV | | Yes
b. | WY | | Yes
b. | BENZO(k)FLUORANTHENE
b. | | Water Quality: Aquatic Life | | | CELDs 1994
b. | OH | Aquatic Life Habitat-Coldwater
b. | OH | Outside Mixing Zone
b. | OH | Human Health
b. | OH | 30-day average | 0.31 µg/L
b. | OH | Aquatic Life Habitat-Limited Resource Warmwater
b. | OH | Outside Mixing Zone
b. | OH | Human Health
b. | OH | 30-day average | 0.31 µg/L
b. | | Groundwater Monitoring Parameters | | | CELDs 1994
b. | AL | | Yes
b. | CO | | Yes
b. | CA | | Yes
b. | IL | | Yes
b. | LA | | Yes
b. | KY | | Yes
b. | MN | | Yes
b. | NY | | Yes
b. | OH | | Yes
b. | SC | | Yes
b. | TN | | Yes
b. | VA | | Yes
b. | WI | | Yes
b. | WV | | Yes
b. | | Hazardous Constituents | | | CELDs 1994
b. | AL | | Yes
b. | CO | | Yes
b. | IL | | Yes
b. | MD | | Yes
b. | MT | | Yes
b. | NE | | Yes
b. | OH | | Yes
b. | SC | | Yes
b. | VA | | Yes
b. | VT | | Yes
b. | WY | | Yes
b. | | Water Quality: Human Health | | | CELDs 1994
b. | AL | Consumption of Water and Fish | **
b. | AL | Fish Consumption Only | **
b. | AZ | Numeric Water Quality Criteria
b. | AZ | Domestic Water Source (DWS) | 0.003 µg/L
b. | AZ | Fish Consumption (FC) | 0.00001 µg/L
b. | AZ | Full Body Contact (FBC) | 0.12 µg/L
b. | AZ | Partial Body Contact (PBC) | NNS
b. | OH | Water Supply
b. | OH | Public Water Supply
b. | OH | Outside Mixing Zone
b. | OH | Human Health
b. | OH | 30-day average | 0.028 µg/L
b. | WI | Human Cancer Criteria
b. | WI | Public Water Supplies
b. | WI | Warm Water Sport Fish Communities | 0.023 mg/L
b. | WI | Cold Water Communities | 0.023 mg/L
b. | WI | Great Lakes | 0.023 mg/L
b. | WI | Non-Public Water Supplies
b. | WI | Warm Water Sport Fish Communities | 0.1 mg/L
b. | WI | Cold Water Communities | 0.1 mg/L
b. | WI | Warm Water and Limited Fish and Limited Aquatic | 6.1 mg/L
b. | BENZO(g,h,i)PERYLENE
b. | | Water Quality: Human Health | | | CELDs 1994
b. | AL | Consumption of Water and Fish | **
b. | AL | Fish Consumption Only | **
b. | AZ | Numeric Water Quality Criteria
b. | AZ | Domestic Water Source (DWS) | 0.003 µg/L
b. | AZ | Fish Consumption (FC) | 0.0001 µg/L
b. | AZ | Full Body Contact (FBC) | 0.12 µg/L
b. | AZ | Partial Body Contact (PBC) | NNS
b. | OH | Water Supply
b. | OH | Public Water Supply
b. | OH | Outside Mixing Zone
b. | OH | Human Health
b. | OH | 30-day average | 0.028 µg/L
b. | WI | Human Cancer Criteria
b. | WI | Public Water Supplies
b. | WI | Warm Water Sport Fish Communities | 0.023 mg/L
b. | WI | Cold Water Communities | 0.023 mg/L
b. | WI | Great Lakes | 0.023 mg/L
b. | WI | Non-Public Water Supplies
b. | WI | Warm Water Sport Fish Communities | 0.1 mg/L
b. | WI | Cold Water Communities | 0.1 mg/L
b. | WI | Warm Water and Limited Fish and Limited Aquatic | 6.1 mg/L
b. | | Water Quality: Aquatic Life | | | CELDs 1994
b. | OH | Aquatic Life Habitat-Coldwater
b. | OH | Outside Mixing Zone
b. | OH | Human Health
b. | OH | 30-day average | 0.31 µg/L
b. | OH | Aquatic Life Habitat-Limited Resource Warmwater
b. | OH | Outside Mixing Zone
b. | OH | Human Health
b. | OH | 30-day average | 0.31 µg/L
b. | | Groundwater Monitoring Parameters | | | CELDs 1994
b. | AL | | Yes
b. | CO | | Yes
b. | CA | | Yes
b. | IL | | Yes
b. | LA | | Yes
b. | KY | | Yes
b. | MN | | Yes
b. | NY | | Yes
b. | OH | | Yes
b. | SC | | Yes
b. | TN | | Yes
b. | VA | | Yes
b. | WI | | Yes
b. | WV | | Yes
b. | BENZO(a)PYRENE
b. | | Water Quality: Human Health Criteria | | | CELDs 1994
b. | AL | Consumption of Water and Fish | **
b. | AL | Fish Consumption Only | **
b. | AL | -Carcinogen
b. | AZ | Numeric Water Quality Criteria
b. | AZ | Domestic Water Supply (DWS) | 0.003 µg/L
b. | AZ | Fish Consumption (FC) | 0.002 µg/L
b. | AZ | Full Body Contact (FBC) | 0.12 µg/L
b. | AZ | Partial Body Contact (PBC) | NNS
b. | MO | Human Health Protection-Fish | 0.03 µg/L
b. | MO | Consumption | 0.003 µg/L
b. | MO | Drinking Water Supply* | 0.003 µg/L
b. | MO | Groundwater*
b. | *These conclusions are allowed for each of the PAHs
b. | NM | Groundwater Standards
b. | NM | Human Health Standards | 0.0007 mg/L
b. | OH | Water Supply-Public Water Supply
b. | OH | Outside Mixing Zone
b. | OH | Human Health
b. | OH | 30-day average | 0.028 µg/L
b. | OK | Maximum Allowable Levels for Organic Chemicals | 0.4 mg/L
b. | TN | National Primary Drinking Water
b. | TN | Standard Organic Chemicals | 0.002 mg/L
b. | WI | Human Cancer Criteria
b. | WI | Public Water Supplies
b. | WI | Warm Water Sport Fish Communities | 0.023 mg/L
b. | WI | Cold Water Communities | 0.023 mg/L
b. | WI | Great Lakes | 0.023 mg/L
b. | WI | Human Cancer Criteria
b. | WI | Non-Public Water Supplies
b. | WI | Warm Water Sport Fish Communities | 0.1 mg/L
b. | WI | Cold Water Communities | 0.1 mg/L
b. | WI | Warm Water and Limited Fish and Limited Aquatic | 6.1 mg/L
b. | WI | Special Monitoring, Reporting and Public Notification Requirements for Unregulated Organic and Inorganic Contaminants | Yes
b. | WI | Nonregulated Organic Contaminants
b. | | Water Quality: Aquatic Life | | | CELDs 1994
b. | NY | Water Classes-GA
b. | NY | Standards (µg/L)-ND
b. | NY | Type-H(WS)
b. | NY | Basis code-F
b. | OH | Aquatic Life Habitat-Coldwater
b. | OH | Outside Mixing Zone
b. | OH | Human Health
b. | OH | 30-day average | 0.31 µg/L*
b. | OH | Aquatic Life Habitat-Limited Resource Warm Water
b. | OH | Outside Mixing Zone
b. | OH | Human Health
b. | OH | 30-day average | 0.31 µg/L*
b. | *This value applies to the sum of 13 PAHs
b. | | Hazardous Constituents | | | CELDs 1994
b. | AL | | Yes
b. | CO | | Yes
b. | CA | | Yes
b. | IL | | Yes
b. | LA | | Yes
b. | KY | | Yes
b. | MA | | Yes
b. | ME | | Yes
b. | MD | | Yes
b. | MN | | Yes
b. | MT | | Yes
b. | NH | | Yes
b. | NJ | | Yes
b. | NE | | Yes
b. | ND | | Yes
b. | NY | | Yes
b. | OH | | Yes
b. | SC | | Yes
b. | VA | | Yes
b. | VT | | Yes
b. | WI | | Yes
b. | WV | | Yes
b. | WY | | Yes
b. | | Groundwater Monitoring Parameters | | | CELDs 1994
b. | AL | | Yes
b. | CO | | Yes
b. | CA | | Yes
b. | IL | | Yes
b. | LA | | Yes
b. | KY | | Yes
b. | MN | | Yes
b. | NY | | Yes
b. | OH | | Yes
b. | SC | | Yes
b. | TN | | Yes
b. | VA | | Yes
b. | WI | | Yes
b. | WV | | Yes
b. | | Groundwater Quality Standards | | | CELDs 1994
b. | NY | Groundwater Effluent Standard | Not detectable
b. | WI | Public Health Groundwater Quality Standards
b. | WI | Enforcement Standard | 0.003 µg/L
b. | WI | Preventive Action | 0.0003 µg/L
b. | CHRYSENE
b. | | Water Quality: Human Health | | | CELDs 1994
b. | AL | Consumption of Water and Fish | **
b. | AL | Fish Consumption Only | **
b. | AZ | Numeric Water Quality Criteria
b. | AZ | Domestic Water Supply (DWS) | 0.03 µg/L
b. | AZ | Fish Consumption (FC) | 0.0001 µg/L
b. | AZ | Full Body Contact (FBC) | 0.12 µg/L
b. | AZ | Partial Body Contact (PBC) | NNS µg/L
b. | MO | Human Health Protection-Fish | 0.03 µg/L
b. | MO | Consumption | 0.003 µg/L
b. | MO | Drinking Water Supply | 0.003 µg/L
b. | MO | Groundwater
b. | OH | Water Supply-Public Water Supply
b. | OH | Outside Mixing Zone
b. | OH | Human Health
b. | OH | 30-day average | 0.028 µg/L
b. | WI | Human Cancer Criteria
b. | WI | Public Water Supplies
b. | WI | Warm Water Sport Fish Communities | 0.023 mg/L
b. | WI | Cold Water Communities | 0.023 mg/L
b. | WI | Great Lakes | 0.023 mg/L
b. | WI | Human Cancer Criteria
b. | WI | Non-Public Water Supplies
b. | WI | Warm Water Sport Fish Communities | 0.1 mg/L
b. | WI | Cold Water Communities | 0.1 mg/L
b. | WI | Warm Water and Limited Fish and Limited Aquatic | 6.1 mg/L
b. | | Water Quality: Aquatic Life | | | CELDs 1994
b. | OH | Aquatic Life Habitat-Coldwater
b. | OH | Outside Mixing Zone
b. | OH | Human Health
b. | OH | 30-day average | 0.31 µg/L
b. | OH | Aquatic Life Habitat-Limited Resource Warmwater
b. | OH | Outside Mixing Zone
b. | OH | Human Health
b. | OH | 30-day average | 0.31 µg/L
b. | | Groundwater Monitoring Parameters | | | CELDs 1994
b. | AL | | Yes
b. | CO | | Yes
b. | CA | | Yes
b. | IL | | Yes
b. | LA | | Yes
b. | KY | | Yes
b. | MN | | Yes
b. | NY | | Yes
b. | OH | | Yes
b. | SC | | Yes
b. | TN | | Yes
b. | VA | | Yes
b. | WI | | Yes
b. | WV | | Yes
b. | | Hazardous Constituents | | | CELDs 1994
b. | AL | | Yes
b. | CO | | Yes
b. | CA | | Yes
b. | IL | | Yes
b. | LA | | Yes
b. | KY | | Yes
b. | MA | | Yes
b. | ME | | Yes
b. | MD | | Yes
b. | MN | | Yes
b. | MT | | Yes
b. | NH | | Yes
b. | NJ | | Yes
b. | NE | | Yes
b. | ND | | Yes
b. | NY | | Yes
b. | OH | | Yes
b. | SC | | Yes
b. | VA | | Yes
b. | VT | | Yes
b. | WI | | Yes
b. | WV | | Yes
b. | WY | | Yes
b. | DIBENZ(a,j)ACRIDINE
b. | | Hazardous Constituents | | | CELDs 1994
b. | AL | | Yes
b. | CO | | Yes
b. | IL | | Yes
b. | LA | | Yes
b. | KY | | Yes
b. | MD | | Yes
b. | MN | | Yes
b. | MT | | Yes
b. | NE | | Yes
b. | ND | | Yes
b. | OH | | Yes
b. | SC | | Yes
b. | VA | | Yes
b. | VT | | Yes
b. | WI | | Yes
b. | WV | | Yes
b. | WY | | Yes
b. | DIBENZO(a,h)ANTHRACENE
b. | | Water Quality: Human Health | | | CELDs 1994
b. | MO | Human Health Protection-Fish | 0.03 µg/L
b. | MO | Consumption | 0.003 µg/L
b. | MO | Drinking Water Supply | 0.003 µg/L
b. | MO | Groundwater
b. | AL | Human Health Criteria
b. | AL | Consumption of Water and Fish | **
b. | AL | Fish Consumption Only | **
b. | AZ | Numeric Water Quality Criteria
b. | AZ | Domestic Water Supply (DWS) | 0.003 µg/L
b. | AZ | Fish Consumption (FC) | 0.00003 µg/L
b. | AZ | Full Body Contact (FBC) | 0.12 µg/L
b. | AZ | Partial Body Contact (PBC) | NNS
b. | OH | Water Supply-Public Water Supply
b. | OH | Outside Mixing Zone
b. | OH | Human Health
b. | OH | 30-day average | 0.028 µg/L
b. | WI | Human Cancer Criteria
b. | WI | Public Water Supplies
b. | WI | Warm Water Sport Fish Communities | 0.023 mg/L
b. | WI | Cold Water Communities | 0.023 mg/L
b. | WI | Great Lakes | 0.023 mg/L
b. | WI | Human Cancer Criteria
b. | WI | Non-Public Water Supplies
b. | WI | Warm Water Sport Fish Communities | 0.1 mg/L
b. | WI | Cold Water Communities | 0.1 mg/L
b. | WI | Warm Water and Limited Fish and Limited Aquatic | 6.1 mg/L
b. | | Water Quality: Aquatic Life | | | CELDs 1994
b. | OH | Aquatic Life Habitat-Coldwater
b. | OH | Outside Mixing Zone
b. | OH | Human Health
b. | OH | 30-day average | 0.31 µg/L
b. | OH | Aquatic Life Habitat-Limited Resource Warmwater
b. | OH | Outside Mixing Zone
b. | OH | Human Health
b. | OH | 30-day average | 0.31 µg/L
b. | | Groundwater Monitoring Parameters | | | CELDs 1994
b. | AL | | Yes
b. | CO | | Yes
b. | IL | | Yes
b. | KY | | Yes
b. | LA | | Yes
b. | MN | | Yes
b. | NY | | Yes
b. | OH | | Yes
b. | SC | | Yes
b. | TN | | Yes
b. | VA | | Yes
b. | WI | | Yes
b. | WV | | Yes
b. | | Hazardous Constituents | | | CELDs 1994
b. | AL | | Yes
b. | CA | | Yes
b. | CO | | Yes
b. | IL | | Yes
b. | LA | | Yes
b. | KY | | Yes
b. | MA | | Yes
b. | ME | | Yes
b. | MD | | Yes
b. | MT | | Yes
b. | NH | | Yes
b. | NJ | | Yes
b. | NE | | Yes
b. | ND | | Yes
b. | NY | | Yes | | ,
b. | OH | | Yes
b. | SC | | Yes
b. | VA | | Yes
b. | VT | | Yes
b. | WI | | Yes
b. | WV | | Yes
b. | WY | | Yes
b. | FLUORANTHENE
b. | | Water Quality: Human Health | | | CELDs 1994
b. | AL | Consumption of Water and Fish | **
b. | AL | Fish Consumption Only | **
b. | AZ | Numeric Water Quality Criteria
b. | AZ | Domestic Water Source (DWS) | 280 µg/L
b. | AZ | Fish Consumption (FC) | 130 µg/L
b. | AZ | Full Body Contact (FBC) | 5600 µg/L
b. | AZ | Partial Body Contact (PBC) | 5600 µg/L
b. | IN | Continuous Criterion Concentration (4-Day) Average for Human Health
b. | IN | Outside of Mixing Zone | 54 (T)*
b. | IN | Point of Water | 42
b. | *(T) - T is derived from threshold toxicity
b. | KY | Water Quality Criteria for Protection of Human Health from the Consumption of Fish Tissue Substances Not Linked to Cancer | 54 µg/L
b. | KY | Organics
b. | KY | Domestic Water Supply Source Criteria Substances Not Linked to Cancer Maximum Contaminant Level (organics) | 0.042 mg/L
b. | MO | Drinking Water Supply | 40 µg/L
b. | MO | Human Health Protection-Fish | 54 µg/L
b. | MO | Consumption | 40 µg/L
b. | MO | Groundwater
b. | OH | Water Supply-Public Water Supply
b. | OH | Outside Mixing Zone
b. | OH | Human Health
b. | OH | 30-day average | 42 µg/L
b. | WI | Human Threshold Criteria
b. | WI | Public Water Supplies
b. | WI | Warm Water Sport Fish Communities | 28 µg/L
b. | WI | Cold Water Communities | 9.1 µg/L
b. | WI | Great Lakes | 9.3 µg/L
b. | WI | Non-Public Water Supplies
b. | WI | Warm Water Sport Fish Communities | 32 µg/L
b. | WI | Cold Water Communities | 9.5 µg/L
b. | WI | Warm Water and Limited Fish and Limited Aquatic | 41,000 µg/L
b. | HI | (Water Quality Standards: Basic Water Quality Criteria for All Waters)
b. | HI | Numeric Standards for Toxic Pollutants
b. | HI | Applicable to All Waters
b. | HI | Freshwater
b. | HI | Acute | 1,300 µg/L
b. | HI | Chronic | NS
b. | HI | Saltwater
b. | HI | Acute | 13 µg/L
b. | HI | Chronic | NS
b. | HI | Fish Consumption | 18 µg/L
b. | | Water Quality: Aquatic Life | | | CELDs 1994
b. | AZ | Acute Criteria for Aquatic and Wildlife Uses | 2000 µg/L
b. | AZ | A&Wc: Cold Water Fishery | 2000 µg/L
b. | AZ | A&Ws: Warm Water Fishery | 2000 µq/L
b. | AZ | A&Wedw: Effluent Dominated Water | NNS
b. | AZ | A&We: Ephemeral
b. | AZ | Chronic Criteria for Aquatic and Wildlife Uses | 1600 µg/L
b. | AZ | A&Wc: Cold Water Fishery | 1600 µg/L
b. | AZ | A&Ws: Warm Water Fishery | 1600 µg/L
b. | AZ | A&Wedw: Effluent Dominated Water | NNS
b. | AZ | A&We: Ephemeral
b. | CO | Aquatic Life Segments
b. | CO | (organic compounds to the second power) | 3,980 µg/L
b. | CO | Standard (acute)
b. | FL | Maximum Concentration Levels for Mixing Zone Pollutants | 540 µg/L
b. | OH | Aquatic Life Habitat-Coldwater
b. | OH | Outside mixing zone
b. | OH | Maximum | 200 µg/L
b. | OH | 30-day average | 8.9 µg/L
b. | OH | Human Health
b. | OH | 30-day average | 54 µg/L
b. | OH | Inside Mixing Zone
b. | OH | Maximum | 400 µg/L
b. | OH | Outside Mixing Zone
b. | OH | Maximum | 200 µg/L
b. | OH | Human Health
b. | OH | 30-day average | 54 µg/L
b. | OH | Inside Mixing Zone
b. | OH | Maximum | 400 µg/L
b. | | Groundwater Monitoring Parameters | | | CELDs 1994
b. | AL | | Yes
b. | CO | | Yes
b. | CA | | Yes
b. | IL | | Yes
b. | LA | | Yes
b. | KY | | Yes
b. | MN | | Yes
b. | NY | | Yes
b. | OH | | Yes
b. | SC | | Yes
b. | TN | | Yes
b. | VA | | Yes
b. | WI | | Yes
b. | WV | | Yes
b. | | Hazardous Constituents | | | CELDs 1994
b. | AL | | Yes
b. | CO | | Yes
b. | CA | | Yes
b. | IL | | Yes
b. | LA | | Yes
b. | KY | | Yes
b. | MA | | Yes
b. | ME | | Yes
b. | MD | | Yes
b. | MN | | Yes
b. | MT | | Yes
b. | NH | | Yes
b. | NJ | | Yes
b. | NE | | Yes
b. | ND | | Yes
b. | NY | | Yes
b. | OH | | Yes
b. | SC | | Yes
b. | VA | | Yes
b. | VT | | Yes
b. | WI | | Yes
b. | WV | | Yes
b. | WY | | Yes
b. | FLUORENE
b. | | Water Quality: Human Health | | | CELDs 1994
b. | AL | Consumption of Water and Fish | **
b. | AL | Fish Consumption Only | **
b. | AZ | Numeric Water Quality Criteria
b. | AZ | Domestic Water Source (DWS) | 280 µg/L
b. | AZ | Fish Consumption (FC) | 580 µg/L
b. | AZ | Full Body Contact (FBC) | 5600 µg/L
b. | AZ | Partial Body Contact (PBC) | 5600 µg/L
b. | MO | Human Health Protection-Fish | 0.03 µg/L
b. | MO | Consumption | 0.003 µg/L
b. | MO | Drinking Water Supply | 0.003 µg/L
b. | MO | Groundwater
b. | OH | Water Supply
b. | OH | Public Water Supply
b. | OH | Outside mixing zone
b. | OH | Human Health 30-day average | 0.028 µg/L
b. | OH | Water Quality: Aquatic Life | | | CELDs 1994
b. | OH | Aquatic Life Habitat-Coldwater
b. | OH | Outside mixing zone
b. | OH | Human Health
b. | OH | 30-day average | 0.31 µg/L
b. | OH | Aquatic Life Habitat-Limited Resource Warmwater
b. | OH | Outside mixing zone
b. | OH | Human Health
b. | OH | 30-day average | 0.31 µg/L
b. | | Groundwater Monitoring Parameters | | | CELDs 1994
b. | AL | | Yes
b. | CO | | Yes
b. | CA | | Yes
b. | IL | | Yes
b. | LA | | Yes
b. | KY | | Yes
b. | MN | | Yes
b. | NY | | Yes
b. | OH | | Yes
b. | SC | | Yes
b. | TN | | Yes
b. | VA | | Yes
b. | WI | | Yes
b. | WV | | Yes
b. | INDENO(1,2,3-CD)PYRENE
b. | | Water Quality: Human Health Criteria | | | CELDs 1994
b. | AL | Consumption of Water and Fish | **
b. | AL | Fish Consumption Only | **
b. | AZ | Numeric Water Quality Criteria
b. | AZ | Domestic Water Supply (DWS) | 0.003 µg/L
b. | AZ | Fish Consumption (FC) | 0.000003 µg/L
b. | AZ | Full Body Contact (FBC) | 0.12 µg/L
b. | AZ | Partial Body Contact (PBC) | NNS µg/L
b. | MO | Human Health Protection-Fish | 0.03 µg/L
b. | MO | Consumption | 0.003 µg/L
b. | MO | Drinking Water Supply | 0.003 µg/L
b. | MO | Groundwater
b. | OH | Water Supply-Public Water Supply
b. | OH | Outside Mixing Zone
b. | OH | Human Health
b. | OH | 30-day average | 0.028 µg/L
b. | WI | Human Cancer Criteria
b. | WI | Public Water Supplies
b. | WI | Warm Water Sport Fish Communities | 0.023 mg/L
b. | WI | Cold Water Communities | 0.023 mg/L
b. | WI | Great Lakes | 0.023 mg/L
b. | WI | Human Cancer Criteria
b. | WI | Non-Public Water Supplies
b. | WI | Warm Water Sport Fish Communities | 0.1 mg/L
b. | WI | Cold Water Communities | 0.1 mg/L
b. | WI | Warm Water and Limited Fish and Limited Aquatic | 6.1 mg/L
b. | | Water Quality: Aquatic Life | | | CELDs 1994
b. | OH | Aquatic Life Habitat-Coldwater
b. | OH | Outside mixing zone
b. | OH | Human Health
b. | OH | 30-day average | 0.31 µg/L
b. | OH | Aquatic Life Habitat-Limited Resource Warm water
b. | OH | Outside mixing zone
b. | OH | Human Health
b. | OH | 30-day average | 0.31 µg/L*
b. | | Hazardous Constituents | | | CELDs 1994
b. | AL | | Yes
b. | CO | | Yes
b. | CA | | Yes
b. | IL | | Yes
b. | LA | | Yes
b. | KY | | Yes
b. | MA | | Yes
b. | ME | | Yes
b. | MD | | Yes
b. | MN | | Yes
b. | MT | | Yes
b. | NH | | Yes
b. | NJ | | Yes
b. | NE | | Yes
b. | ND | | Yes
b. | NY | | Yes
b. | OH | | Yes
b. | SC | | Yes
b. | VA | | Yes
b. | VT | | Yes
b. | WI | | Yes
b. | WV | | Yes
b. | WY | | Yes
b. | | Groundwater Monitoring Parameters | | | CELDs 1994
b. | AL | | Yes
b. | CO | | Yes
b. | CA | | Yes
b. | IL | | Yes
b. | LA | | Yes
b. | KY | | Yes
b. | MN | | Yes
b. | NY | | Yes
b. | OH | | Yes
b. | SC | | Yes
b. | TN | | Yes
b. | VA | | Yes
b. | WI | | Yes
b. | WV | | Yes
b. | PHENANTHRENE
b. | | Water Quality: Human Health | | | CELDs 1994
b. | AL | Consumption of Water and Fish
b. | AL | Fish Consumption Only | **
b. | A2 | Numeric Water Quality Criteria
b. | A2 | Domestic Water Supply (DWS) | 0.003 µg/L
b. | A2 | Fish Consumption (FC) | 0.0005 µg/L
b. | A2 | Full Body Contact (FBC) | 0.12 µg/L
b. | A2 | Partial Body Contact (PBC) | NNS
b. | MO | Human Health Protection-Fish | 0.03 µg/L
b. | MO | Consumption | 0.003 µg/L
b. | MO | Drinking Water Supply | 0.003 µg/L
b. | MO | Groundwater
b. | WI | Human Cancer Criteria
b. | WI | Public Water Supplies
b. | WI | Warm Water Sport Fish Communities | 0.023 mg/L
b. | WI | Cold Water Communities | 0.023 mg/L
b. | WI | Great Lakes | 0.023 mg/L
b. | WI | Non-Public Water Supplies
b. | WI | Warm water Sport Fish Communities | 0.1 mg/L
b. | WI | Cold Water Communities | 0.1 mg/L
b. | WI | Warm Water and Limited Fish and Limited Aquatic | 6.1 mg/L
b. | | Water Quality: Aquatic Life | | | CELDs 1994s
b. | AZ | Acute Criteria for Aquatic and Wildlife Uses | 30 µg/L
b. | AZ | A&Wc: Cold Water Fishery | 30 µg/L
b. | AZ | A&Ws: Warm Water Fishery | 540 µg/L
b. | AZ | A&Wedw: Effluent Dominated Water | NNS
b. | AZ | A&We: Ephemeral
b. | AZ | Chronic Criteria for Aquatic and Wildlife Uses | 6.3 µg/L
b. | AZ | A&Wc: Cold Water Fishery | 6.3 µg/L
b. | AZ | A&Ws: Warm Water Fishery | 6.3 µg/L
b. | AZ | A&Wedw: Effluent Dominated Water | NNS
b. | AZ | A&We: Ephemeral
b. | | Groundwater Monitoring Parameters | | | CELDs 1994
b. | AL | | Yes
b. | CO | | Yes
b. | CA | | Yes
b. | IL | | Yes
b. | LA | | Yes
b. | KY | | Yes
b. | MN | | Yes
b. | NY | | Yes
b. | OH | | Yes
b. | SC | | Yes
b. | TN | | Yes
b. | VA | | Yes
b. | WI | | Yes
b. | WV | | Yes
b. | PYRENE
b. | | Water Quality: Human Health | | | CELDs 1994
b. | AL | Consumption of Water and Fish | **
b. | AL | Fish Consumption Only | **
b. | AZ | Numeric Water Quality Criteria
b. | AZ | Domestic Water Source (DWS) | 210 µg/L
b. | AZ | Fish Consumption (FC) | 1100 µg/L
b. | AZ | Full Body Contact (FBC) | 4200 µg/L
b. | AZ | Partial Body Contact (PBC) | 4200 µg/L
b. | MO | Human Health Protection-Fish | 0.03 µg/L
b. | MO | Consumption | 0.003 µg/L
b. | MO | Drinking Water Supply | 0.003 µg/L
b. | MO | Groundwater
b. | OH | Water Supply
b. | OH | Public Water Supply
b. | OH | Outside mixing zone
b. | OH | Human Health
b. | OH | 30-day average | 0.028 µg/L
b. | WI | Human Cancer Criteria
b. | WI | Public Water Supplies
b. | WI | Warm Water Sport Fish Communities | 0.023 mg/L
b. | WI | Cold Water Communities | 0.023 mg/L
b. | WI | Great Lakes | 0.023 mg/L
b. | WI | Human Cancer Criteria
b. | WI | Non-Public Water Supplies
b. | WI | Warm Water Sport Fish Communities | 0.1 mg/L
b. | WI | Cold Water Communities | 0.1 mg/L
b. | WI | Warm Water and Limited Fish and Limited Aquatic | 6.1 mg/L
b. | | Water Quality: Aquatic Life | | | CELDs 1994
b. | OH | Aquatic Life Habitat-Coldwater
b. | OH | Outside mixing zone
b. | OH | Human Health
b. | OH | 30-day average | 0.31 µg/L
b. | OH | Aquatic Life Habitat-Limited Resource Warmwater
b. | OH | Outside mixing zone
b. | OH | Human Health
b. | OH | 30-day average | 0.31 µg/L
b. | | Groundwater Monitoring Parameters | | | CELDs 1994
b. | AL | | Yes
b. | CO | | Yes
b. | CA | | Yes
b. | IL | | Yes
b. | LA | | Yes
b. | KY | | Yes
b. | MN | | Yes
b. | NY | | Yes
b. | OH | | Yes
b. | SC | | Yes
b. | TN | | Yes
b. | VA | | Yes
b. | WI | | Yes
b. | WV | | Yes

a Degree of evidence in animals revised on the basis of data that appeared after the most recent monograph and/or on the basis of present criteria. Overall evaluation based on evidence of carcinogenicity in monograph 32, 1983.

b Group 2A = Probable human carcinogen

c Group 2B = Possible human carcinogen

d Group 3 = Not classifiable as to carcinogenicity

e The following PAHs were used as indicators in deriving this standard: B[a]P; B[b]F; B[a]F; B[k]F; fluoranthene; and I[123cd]P. Source: EPA 1986b.

f Includes anthracene, B[a]P, phenanthrene, acridine, chrysene, and pyrene

g Agent recommended by NIOSH to be treated as a potential occupational carcinogen.

h Because of their carcinogenic potential, the EPA-recommended concentration for PAHs in ambient water is zero. However, because attainment of this level may not be possible, the recommended criteria requires a E-G estimated incremental lifetime cancer risks.

i Group D = not classifiable as to human carcinogenicity, Group B2 = Probable Human Carcinogen

When “all PAHs” are listed, it includes the following compounds, unless specified otherwise:

- Anthracene, Acenaphthylene, Acenaphthene, B[a]A, B[a]P, B[b]F, B[h]F, B[g,h,i]P, Chrysene, DB[a,h]A, Fluoranthene, Flourene, I[1,2,3-cd]P, Phenanthrene, Pyrene

ACHIH = American Conference of Governmental Industrial Hygienists; B[a]A = Benzo[a]Anthracene; B[a]P = Benzo[a]Pyrene; B[b]F = Benzo[b]Fluoranthene; B[e]P = Benzo[e]Pyrene; B[ghi]P = Benzo(ghi)perylene; B[J]F = Benzo[j]Fluoranthene; B[k]F = Benzo[k]Fluoranthene; B[ghi]P = Benzo[ghi]perylene; BP = Benzopyrene; DB[a,h]A = Dibenz[a,h]Anthracene; DB[a,e]P = Dibenzo[a,e]pyrene; DB[a,i] = Dibenzo[a,i]pyrene; DOT = Department of Transportation; EPA = Environmental Protection Agency; IARC = International Agency for Research on Cancer; I[123cd]P = Indeno[1,2,3-c,d]Pyrene; ng = nanogram; NIOSH = Natinonal Institute for Occupational Safety and Health; OERR = Office of Emergency and Remedial Response; OSHA = Occupational Safety and Health Administration; OWRS = Office of Water Regulations and Standards; PAH = Polycyclic Aromatic Hydrocarbons; PEL = Permissible Exposure Limit; RCRA = Resource Conservation and Recovery Act; REL = Recommended Exposure Limit; RfD = Reference Dose; TLV = Threshold Limit Value; TWA = Time-Weighted Average; u.f. = Uncertainty Factor; WHO = World Health Organization