# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Information regarding the chemical identity of PAHs is located in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of PAHs is located in Table 3-2.

TABLE 3-1 Chemical Identity of Polycyclic Aromatic Hydrocarbons^a^

Characteristic | Acenapthene | Acenaphthylene | Anthracene
Synonym(s) | 1.2-Dihydroacenaphthylene; 1.8-dihydroacenapthaline; 1.8-ethylenenapthalene; 1.2-dihydroacenapththylene | Cyclopenta[d,e]naphthalene | Anthracin; green oil; paranaphthalene^b^
Registered trade name(s) | No data | No data | Tetra olive NZG; Anthracene oil^d^
Chemical formula | C_12_H_10_ | C_12_H_8_ | C_14_H_10_^b^
Chemical structure | [image] | [image] | [image]
CAS registry | 83–29–9 | 208–96–8 | 120–12–7^b^
NIOSH RTECS | AB1000000 | AB1254000 | CA 9350000
EPA hazardous waste | No data | No data | No data
OHM/TADS | 8200126 | No data | 82001222
DOT/UN/NA/IMCO shipping | No data | No data | No data
HSDB | 2659 | 2661 | 702
NCI | No data | No data | No data

Characteristic | Benzo[a]anthracene | Benzo[a]pyrene | Benzo[b]fluoranthene
Synonym(s) | BA; benz[a]anthracene; 1,2-benzanthracene; benzo[b]phenanthrene; 2,3-benzophenanthrene; tetraphene^c,d^ | Benzo[d,e,f]chrysene; 3,4-benzopyrene, 3,4-benzpyrene; benz[a]pyrene; BP; B[a]P^b^ | 3,4-Benz[e]acephenanthrylene; 2,3-benzfluoranthene; 3,4-benzfluoranthene; 2,3-benzofluoranthene; 3,4-benzofluoranthene; benzo[e]fluoranthene;B[b]F^b^
Registered trade name(s) | No data | No data | No data
Chemical formula | C_18_H_12_ | C_20_H_12_^b^ | C_20_H_12_^b^
Chemical structure | [image] | [image] | [image]
Identification numbers:
CAS Registry | 56–55–3 | 50–32–8 | 205–99–2^b^
NIOSH RTECS | CV 9275000^e^ | DJ3675000 | CU 1400000^e^
EPA Hazardous Waste | U018 | U022 | No data
OHM/TADS | 8200123 | No data | 8200124^e^
DOT/UN/NA/IMCO shipping | No data | No data | No data
HSDB | 4003 | 2554 | 4035
NCI | No data | No data | No data

Characteristic | Benzo[e]pyrene | Benzo[k]fluoranthene | Benzo[g,h,i]perylene
Synonym(s) | 1.2-Benzopyrene; 1.2-benzpyrene; 4.5 benzopyrene; 4.5-benzpyrene; B[e]P^e^ | 8.9-Benzfluoranthene; 8.9-benzofluoranthene; 11.12-benzofluoranthene; 2,3,1.8-binaphthylene; dibenzo[b,j,k]fluorene^b^ | 1,12-Benzoperylene^c^
Registered trade name(s) | No data | No data | No data
Chemical formula | C_20_H_12_^e^ | C_20_H_12_^b^ | C_22_H_12_^c^
Chemical structure | [image] | [image] | [image]
CAS registry | 192–97–2^e^ | 207–08–9^b^ | 191–24–2^c^
NIOSH RTECS | D4500000^e^ | DF 350000^e^ | DI 6200500^e^
EPA hazardous waste | No data | No data | No data
OHM/TADS | No data | 8200125^e^ | No data
DOT/UN/NA/IMCO shipping | No data | No data | No data
HSDB | 4031^e^ | 6012^e^ | 6177^e^
NCI | No data | No data | No data

Characteristic | Benzo[j]fluoranthene | Chrysene | Dibenz[a,h]anthracene
Synonym(s) | 10.11-Benzofluoranthene; benzo-12.13-fluoranthene; dibenzo[a,j,k]-fluorene; 7.8-benzofluoranthene; B[j]F^e^ | 1.2-Benzophenanthrene; benzo[a]-phenanthrene; 1,2-benzphenanthrene; benz[a]phenanthrene; 1,2,5,6-dibenzonaphthalene | Dibenz[a,h]anthracene; DB[a,h]A; DBA; 1,2:5,6-dibenz[a]anthracene^b,e^
Registered trade name(s) | No data | No data | No data
Chemical formula | C_20_H_12_ | C_18_H_12_^b^ | C_22_H_14_^b^
Chemical structure | [image] | [image] | [image]
CAS registry | 205–82–3^e^ | 218–01–9^b^ | 53–70–3^b^
NIOSH RTECS | DF 6300000^e^ | GC 0700000^e^ | HN 2625000^e^
EPA hazardous waste | No data | U050^e^ | U063
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMCO shipping | No data | No data | No data
HSDB | 4034^e^ | 2810 | 5097
NCI | No data | No data | No data

Characteristic | Fluoranthene | Fluorene | Indeno[1,2,3-c,d]pyrene
Synonym(s) | 1.2-[1,8-Naphthylene]benzene; 1.2-benzacenaphthene; 1.2-[1.8-naphthalenediyl] benzene; benzo[j,k]fluorene | ortho-Biphenylene methane; diphenylenemethane; 2,2-methylene biphenyl; 2.3-benzidene^b,f^ | Indenopyrene; IP; ortho-phenylene pyrene; 1,10-[ortho-phenylene]pyrene; 1,10-[1,2-phenylenejpyrene; 2,3-ortho-phenylene pyrene^b^
Registered trade name(s) | No data | No data | No data
Chemical formula | C_16_H_10_ | C_13_H_10_^b^ | C_22_H_12_^b^
Chemical structure | [image] | [image] | [image]
Identification numbers:
CAS registry | 206–44–0 | 86–73–7^b^ | 193–39–5^b^
NIOSH RTECS | LL4025000 | LL5670000 | NK 9300000
EPA hazardous waste | U120 | No data | U137
OHM/TADS | 8200136 | No data | No data
DOT/UN/NA/IMCO shipping | No data | No data | No data
HSDB | 5486 | 2165 | 5101
NCI | No data | No data | No data

Characteristic | Phenanthrene | Pyrene
Synonym(s) | Phenanthrene; Phenantrin^b^ | Benzo[d,e,f]phenanthrene; 8-pyrene^b^
Registered trade name(s) | No data | No data
Chemical formula | C_14_H_10_^b^ | C_16_H_10_^b^
Chemical structure | [image] | [image]
Identification numbers:
CAS registry | 85–01–8^b^ | 129–00–00^b^
NIOSH RTECS | SF7175000 | UR 245000^e^
EPA hazardous waste | No data | No data
OHM/TADS | 8200140 | No data
DOT/UN/NA/IMCO shipping | No data | No data
HSDB | 2166 | 4023
NCI | No data | No data

a AII information obtained from HSDB 1994, except where noted.

b IARC 1983

c Eller 1984

d Sax and Lewis 1989

e HSDB 1992

f Weast et al. 1988

CAS = Chemical Abstracts Service; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substance Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; PAHs = polycyclic aromatic hydrocarbons; RTECS = Registry of Toxic Effects of Chemical Substances; → = bay region; ↝ = pseudo bay region

TABLE 3-2 Physical and Chemical Properties of Polycyclic Aromatic Hydrocarbons^a^

Property | Acenaphthene | Acenaphthylene | Anthracene
Molecular weight | 154.21 | 152.20 | 178.2^b^
Color | White | No data | Colorless with violet fluorescence when pure; yellow with green fluorescence when impure
Physical state | Solid (needles) | Solid (prisms/plates) | Solid (tablet or prism)^b^
Melting point | 95 °C | 92–93 °C | 218 °C^b^
Boiling point | 96.2 °C | 265–275 °C | 342 °C^b^, 340 °C^e^
Density at 20/4 °C | 1.225 g/cm^3^ at 0 °C | No data | No data
Specific gravity | 1.0242 at 90 °C/4 °C^e^ | 0.8988 at 16 °C/2 °C | 1.25 at 27 °C/4 °C; 1.283 at 25 °C/4 °C^e^
Odor | No data | No data | Weak aromatic odor
Odor threshold:
Water | 0.08 ppm | No data | No data
Air | 0.08 ppm | No data | No data
Solubility:
Water | 1.93 mg/L^p^ | 3.93 mg/L water | 0.076 mg/L^p^
Organic solvents | Soluble in alcohol, methanol, propanol, chloroform, benzene, toluene, glacial acetic acid | Alcohol, ether, benzene | Acetone: benzene, carbon disulphide, carbon tetrachloride, chloroform, ether, ethanol, methanol, toluene^e,b^
Partition coefficients:
Log K_ow_ | 3.98^k^ | 4.07^k^ | 4.45^k^
Log K_oc_ | 3.66^k^ | 1.40^k^ | 4.15^k^
Vapor pressure | 4.47×10^−3^ mm Hg^m^ | 0.029 mm Hg at 20 °C^k^ | 1 mm Hg at 145 °C^b^; 1.7×10^−5^ mm Hg at 25 °C^k^
Henry’s law constant | 7.91×10^−5^ atm^−3^/mol^r^ | 1.45×10^−3^ atm-m^3^/mol | 1.77×10^−5^ atm-m^3^/mol^r^
Autoignition temperature | No data | No data | 540 °C^i^
Flashpoint | No data | No data | 121 °C(closed cup)^d^
Flammability limits | Dust is moderately flammable^n^ | No data | No data
Conversion factors | 0 | 0 | 0
Explosive limits | No data | No data | Lower, 0.6% by volume^d^

Property | Benzo[a]anthracene | Benzo[a]pyrene | Benzo[b]fluoranthene
Molecular weight | 228.29^c^ | 252.3^b^ | 252.3^b^
Color | Yellow-blue fluorescence^e^ | Pale yellow | Colorless
Physical state | Solid (plates) | Solid (plates or needles)^f^ | Solid (needles)^e^ (recrystallized from benzene/ligroin)
Melting point | 158–159 °C^c^; 162 °C^e^ | 179–179.3 °C^f^ | 168.3 °C^b^
Boiling point | 400 °C^i^; 435 °C sublimes^f^ | 310–312 °C at 10 mm Hg^f^; 495 °C^j^ | No data
Density | 1.274 g/cm^3^ at 20 °C | 1.351 g/cm^3,h^ | No data
Specific gravity | No data | No data | No data
Odor | No data | Faint aromatic odor | No data
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water | 0.010 mg/L^p^ | 2.3×10^−3^ mg/L^p^ | 0.0012 mg/L^q^
Organic solvents | Slightly soluble in acetic acid and hot ethanol; soluble in acetone and diethyl ether; very soluble in benzene^b^ | Sparingly soluble in ethanol and methanol; soluble in benzene, toluene, xylene, and ether | Slightly soluble in benzene, acetone^b^
Partition coefficients:
Log K_ow_ | 5.61^k^ | 6.06^k^ | 6.04^k^
Log K_oc_ | 5.30^k^ | 6.74^k^ | 5.74^k^
Vapor pressure | 2.2×10^−8^ mm Hg at 20 °C | 5.6×10^−9^ mm Hg^k^ | 5.0×10^−7^ mm Hg at 20–25 °C^r^
Henry’s law constant | 1×10^−6^ atm–m^3^/mol | 4.9×10^−7^ atm-m^3^/mol^k^ | 1.22×10^−5^ atm-m^3^/mol^k^
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability limits | No data | No data | No data
Conversion factors | 0 | 0 | 0
Explosive limits | No data | No data | No data

Property | Benzo[e]pyrene | Benzo[k]fluoranthene | Benzo[g,h,i]perylene
Molecular weight | 252.30^d^ | 252.3 | 276.34^c^
Color | Colorless^b^ | Pale yellow | Pale yellow-green
Physical state | Prisms or plates (recrystallized from benzene)^g^ | Solid (needles) | Solid (plate)
Melting point | 178–179 °C^d^ | 215.7 °C | 273 °C^c^
Boiling point | 310–312 °C at 10 mm Hg^g^ | 480 °C | 550 °C
Density | No data | No data | No data
Specific gravity | No data | No data | No data
Odor | No data | No data | No data
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water | 6.3×10^−3^ mg/L at 25 °C^d^ | 7.6×10^−4^ mg/L at 25 °C | 2.6×10^−4^ mg/L at 25 °C
Organic solvents | Acetone^g^ | Soluble in benzene, acetic acid, ethanol^b^ | Soluable in benzene, dichloromethane, acetone^g^
Partition coefficients:
Log K_ow_ | No data | 6.06^k^ | 6.50^k^
Log K_oc_ | No data | 5.74^k^ | 6.20^k^
Vapor pressure | 5.7×10^−9^ mm Hg at 25 °C^d^ | 9.59×10^−11^ mm Hg | 1.03×10^−10^ mm Hg at 25 °C^k^
Henry’s law constant | No data | 3.87×10^−5^ atm–m^3^/mol^k^ | 1.44×10^−7^ atm-m^3^/mol^k^
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability limits | No data | No data | No data
Conversion factors | 0 | 0 | 0
Explosive limits | No data | No data | No data

Property | Benzo[j]fluoranthene | Chrysene | Dibenz[a,h]anthracene
Molecular weight | 252.32^d^ | 228.3^b^ | 278.35^c^
Color | Yellow or orange^d^ | Colorless with blue or red-blue fluorescence^b,e^ | Colorless^b^
Physical state | Plates (recrystallized from ethanol) or needles (recrystallized from acetic acid)^d,h^ | Solid (plates)^e^ | Solid (plates or leaftlets)^e^
Melting point | 166 °C^d^ | 255–256 °C^b^ | 262 °C^c^
Boiling point | No data | 448 °C^b^ | No data
Density | No data | No data | 1.282 g/cm^3,h^
Specific gravity | No data | 1.274 at 20 °C/4 °C^i^ | No data
Odor | No data | No data | No data
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water | 6.76×10^−3^ mg/L at 25 °C^d^ | 2.8×10^−3^ mg/L^p^ | 5×10^−4^ mg/L^b^
Organic solvent(s) | Slightly soluble in alcohol and acetic acid; soluble in hydrogen sulfide on heating^d^ | Slightly soluble in acetone, carbon disulphide, diethyl ether, ethanol glacial acetic acid toluene hot xylene; soluble in benzene^b^ | Slightly soluble in ethyl alcohol; soluble in acetone, acetic acid, benzene, toluene and xylene^e^
Partition coefficients:
Log K_ow_ | 6.12^d^ | 5.16^k^ | 6.84^k^
Log K_oc_ | 4.7–4.8^d^ | 5.30^k^ | 6.52^k^
Vapor pressure | 1.50×10^−8^ mm Hg at 25 °C^d^ | 6.3×10^−7^ mm Hg at 25 °C^k^ | 1×10^−10^ mm Hg at 20 °C^k^
Henry’s law constant | 1×10^−6^ atm–m^3^/mol^d^ | 1.05×10^−6^ atm-m^3^/mol^k^ | 7.3×10^−8^ atm-m^3^/mol^k^
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability limits | No data | No data | No data
Conversion factors | 0 | 0 | 0
Explosive limits | No data | No data | No data

Property | Fluoranthene | Fluorene | Indeno[1,2,3-c,d]pyrene
Molecular weight | 202.26 | 166.2^g^ | 276.3^g^
Color | Pale yellow | White^g^ | Yellow plates or needles showing a greenish-yellow fluorescence^g^
Physical state | Solid (needles or plates) | Solid (leaflets or flakes; crystalline plates)^g^ | Solid (plates or needles)^g^
Melting point | 11 °C | 116–117 °C^g^ | 163.6 °C^g^
Boiling point | −375 °C | 295 °C^g^ | 530 °C
Density | No data | No data | No data
Specific gravity | 1.252 at 0 °C/4 °C | 1.203 at 0 °C/4 °C | No data
Odor | No data | No data | No data
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water | 0.20–0.26 mg/L^g^ | 1.68–1.98 mg/L^g^ | 0.062 mg/L^g^
Organic solvents | Alcohol, ether, benzene, acetic acid | Acetic acid, acetone, benzene, carbon disulphide, carbon tetrachloride, diethyl ether, ethanol, pyrimidine, solution, toluene^g^ | Soluble in organic solvents^g^
Partition coefficients:
Log K_ow_ | 4.90^k^ | 4.18^k^ | 6.58^k^
Log K_oc_ | 4.58^k^ | 3.86^k^ | 6.20^k^
Vapor pressure | 5.0×10^−6^ mm Hg at 25 °C^k^ | 3.2×10^−4^ mm Hg at 20 °C^d^ | −10^−11^-10^−6^ mm Hg at 20 °C^k^
Henry’s law constant | 6.5×10^−6^ atm–m^3^/mol^k^ | 1.0×10^−4^ atm-m^3^/mol^r^ | 6.95×10^−8^ atm-m^3^/mol^k^
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability limits | No data | No data | No data
Conversion factors | 0 | 0 | 0
Explosive limits | No data | No data | No data

Property | Phenanthrene | Pyrene
Molecular weight | 178.2^b^ | 202.3^b^
Color | Colorless^b^ | Colorless, pale yellow plates (recrystallized from toluene) or slight blue fluorescence (recrystallized from ethanol or sublimation)^b^
Physical state | Solid (plates, crystals, or leaflets)^b^ | Solid (plates or tablets)^b^
Melting point | 100 °C^b^ | 156 °C
Boiling point | 340 °C | 393 °C^e^; 404 °C^l^
Density | 0.980 g/cm^3^ at 4 °C | 1.271 g/cm^3^ at 23 °C
Specific gravity | No data | 1.271 at 23 °C/4 °C
Odor | Faint aromatic odor | No data
Odor threshold:
Water | No data | No data
Air | No data | No data
Solubility:
Water at 25 °C | 1.20 mg/L^p^ | 0.077 mg/L^p^
Organic solvents | Soluble glacial acetic acid, benzene, carbon disulphide, carbon tetrachloride, anhydrous diethyl ether, ethanol, toluene^b^ | Soluble in alcohol benzene, carbon disulphide, diethyl ether, ethanol, petroleum ether, toluene, race tone^b^
Partition coefficients:
Log K_ow_ | 4.45^k^ | 4.88^k^
Log K_oc_ | 4.15^k^ | 4.58^k^
Vapor pressure | 6.8×10^−4^ mm Hg at 25 °C^d^ | 2.5×10^−6^ mm Hg at 25 °C^k^
Henry’s law constant | 2.56×10^−5^ atm–m^3^/mol^r^ | 1.14×10^−5^ atm-m^3^/mol^r^
Autoignition temperature | No data | No data
Flashpoint | No data | No data
Flammability limits | No data | No data
Conversion factors | 0 | 0
Explosive limits | No data | No data

a AII information obtained from HSDB except where noted

b IARC 1973

c Eller 1984

d HSDB 1994

e Weast et al. 1988

f Weast 1987

g IARC 1983

h Temperature not specified

i Sax and Lewis 1989

j Aldrich 1986

k Mabey et al. 1982

l Windholz 1983

m EPA 1987a

n ITII 1982

p Yalkowsky et al 1993

q Sims and Overcash 1983

r Nirmalakhandan and Speece 1988

The following equation can be used for the converstion of vapor phase PAHs at 25 °C:

(mg/m^3^ × 24.45)/(Mol . wt .)