# 9 REFERENCES

*Cited in text

*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
*Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Notice. Federal Register 54(174):37618–37634.
Agency for Toxic Substances and Disease Registry. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Atlanta, GA: Subcommittee on Biomarkers of Organ Damage and Dysfunction.
Agency for Toxic Substances and Disease Registry. 1994. Toxicological profile for chlorodibenzofurans. Atlanta, GA: U.S. Department of Health and Human Services.
Agency for Toxic Substances and Disease Registry. 1998. Toxicological profile for chlorinated dibenzo-p-dioxins. Atlanta, GA: U.S. Department of Health and Human Services.
*Agency for Toxic Substances and Disease Registry. 2000. Toxicological profile for polychlorinated biphenyls. Atlanta, GA: U.S. Department of Health and Human Services.
*Ahmadizadeh M, Kuo C-H, Echt R, . 1984. Effect of polybrominated biphenyls, B-naphthoflavone and phenobarbital on arylhydrocarbon hydrolase activities and chloroform-induced nephrotoxicity and hepatotoxicity in male C57BL/6J and DBA/2J mice. Toxicology 31:343–352.6330937
*Akoso BT, Sleight SD, Aust SD, . 1982a. Pathologic effects of purified polybrominated biphenyl congeners in rats. J Am Coll Toxicol 1:1–21.
*Akoso BT, Sleight SD, Nachreiner RF, . 1982b. Effects of purified polybrominated biphenyl congeners on the thyroid and pituitary glands in rats. J Am Coll Toxicol 1:23–36.
*Akutsu K, Obana H, Okihashi M, . 2001. GC/MS analysis of polybrominated diphenyl in fish collected from the inland sea of Seto, Japan. Chemosphere 44:1325–1333.11513108
Alaee M. 2001. Levels and trends of PBDEs in North American environment. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 131–134.
Alaee M, Wenning RJ. 2002. The significance of brominated flame retardants in the environment: Current understanding, issues and challenges. Chemosphere 46(5):579–582.11999783
Alaee M, Arias P, Sjodin A, . 2003. An overview of commercially used brominated flame retardants, their applications, their use patterns in different countries/regions and possible modes of release. Environ Int 29:683–689.12850087
Alaee M, Cannon C, Muir D, . 2001a. Brominated flame retardants. Spatial distribution and seasonal variation of PBDEs in Arctic and Great Lakes air. Organohalogen Compounds 52:26–29.
Alaee M, Luross M, Whittle DM, . 2002. Bioaccumulation of polybrominated diphenyl ethers in the Lake Ontario pelagic food web. Organohalogen Compounds 57:427–430.
Alaee M, Sergeant DB, Ikonomou MG, . 2001b. A gas chromatography/high-resolution mass spectrometry (GC/HRMS) method for determination of polybrominated diphenyl ethers in fish. Chemosphere 44(6):1489–1895.11523530
Alaee M, Sergeant DB, Muir DCG, . 1999. Distribution of polybrominated diphenyl ethers in the Canadian environment. Organohalogen Compounds 40:347–350.
Alcock RE, Jones KC. 1999. New directions “new” organic compounds in the environment. Atmos Environ 33(10):1645–1646.
Allchin CR, de Boer J. 2001. Brominated flame retardants. Results of a comprehensive survey for PBDEs in the River Tees, UK. Organohalogen Compounds 52:30–34.
Allchin CR, Law RJ, Morris S. 1999. Polybrominated diphenylethers in sediments and biota downstream of potential sources in the UK. Environ Pollut 105:197–207.
Allchin CR, Morris S, Law RJ, . 2000. Polybrominated diphenyl ether residues in cormorant (Phalocrocorax L.) livers from England, UK. Organohalogen Compounds 47:190–193.
*Allen JR, Barsotti DA, Lambrecht LK, . 1979. Reproductive effects of halogenated aromatic hydrocarbons on nonhuman primates. Ann N Y Acad Sci 320:419–424.222194
*Allen JR, Lambrecht LK, Barsotti DA. 1978. Effects of polybrominated biphenyls in nonhuman primates. J Am Vet Med Assoc 173:1485–1489.
*Allen-Rowlands CF, Castracane VD, Hamilton MG, . 1981. Effect of polybrominated biphenyls (PBB) on the pituitary-thyroid axis of the rat. Proc Soc Exp Biol Med 166:506–514.6261263
*Altman PL, Dittmer DS. 1974. In: Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
Amirova Z, Matorova N, Kruglov E, . 2001. Human exposure. Cohort of firemen, Shelekhovo, Russia, PCDD/Fs, PCBs and PBDEs in blood lipids. Organohalogen Compounds 52:217–221.
*Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York: Marcel Dekker, Inc., 9–25.
*Andersen ME, Clewell HJ III, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
Anderson BE, Zeigler E, Shelby MD, . 1990. Chromosome aberration and sister chromatid exchange test results with 42 chemicals. Environ Mol Mutagen 16(18):55–137.2091924
*Anderson HA. 1985. Utilization of adipose tissue biopsy in characterizing human halogenated hydrocarbon exposure. Environ Health Perspect 60:127–131.2992921
*Anderson HA, Falk C, Hanrahan L, . 1998. Profiles of Great Lakes critical pollutants: A sentinel analysis of human blood and urine. Environ Health Perspect 106(5):279–289.9560354
*Anderson HA, Holstein EC, Daum SM, . 1978a. Liver function tests among Michigan and Wisconsin dairy farmers. Environ Health Perspect 23:333–339.209996
*Anderson HA, Lilis R, Selikoff IJ, . 1978b. Unanticipated prevalence of symptoms among dairy farmers in Michigan and Wisconsin. Environ Health Perspect 23:217–226.209979
*Anderson HA, Rosenman KD, Snyder J. 1978c. Carcinoembryonic antigen (CEA) plasma levels in Michigan and Wisconsin dairy farmers. Environ Health Perspect 23:193–197.209976
*Anderson HA, Wolff MS, Fischbein A, . 1978d. Investigation of the health status of Michigan Chemical Corporation employees. Environ Health Perspect 23:187–191.209974
*Anderson HA, Wolff MS, Lilis R, . 1979. Symptoms and clinical abnormalities following ingestion of polybrominated-biphenyl-contaminated food products. Ann N Y Acad Sci 320:684–702.222195
*Andersson O, Blomkvist G. 1981. Polybrominated aromatic pollutants found in fish in Sweden. Chemosphere 10(9):1051–1060.
Andersson O, Wartanian A. 1992. Levels of polybrominated camphenes toxaphene chlordane compounds and polybrominated diphenyl ethers in seals from Swedish waters. Ambio 21(8):550–552.
Andersson PL, Wagman N, Berg H, . 1999. Biomagnification of structurally matched polychlorinated and polybrominated diphenylethers (PCDE/PBDE) in zebrafish (Danio rerio). Organohalogen Compounds 43:9–12.
*Andres J, Lambert I, Robertson L, . 1983. The comparative biologic and toxic potencies of polychlorinated biphenyls and polybrominated biphenyls. Toxicol Appl Pharmacol 70:204–215.6312630
Ankarberg E, Fredriksson A, Jakobsson E . 2001. Increased susceptibility to adult flame retardants exposure (PBDE 99) in mice neonatal exposed to nicotine. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 233–235.
*Anliker R, Moser P, Poppinger D. 1988. Bioaccumulation of dyestuffs and organic pigments in fish. Relationships to hydrophobicity and steric factors. Chemosphere 17:1631–1644.
Anonymous. 1981. Workplace environmental exposure level guide- decabromodiphenyl oxide. Am Ind Hyg Assoc J 12(4):A-76–77.
Anonymous. 1998. Swedish research spotlights brominated flame retardant risks. ENDS Rep 276:6.
Anonymous. 2000. TV makers battle with bromine barons over fire safety. ENDS Rep 309:30–31.
Arend MW, Jarman WM, Ballschmiter K. 2001. Levels in biotic compartments. Organohalogen POPs in fish of the northern Pacific. Organohalogen Compounds 58:437–440.
Argus Research Laboratories. 1984. Dosage-range embryo/fetal toxicity & teratogenic potential of Saytex 115 administered orally via gavage to Crl:CONB CD (SD) BR presumed pregnant to rats. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0522189.
Argus Research Laboratories. 1985a. Embryo/fetal toxicity and teratogenic potential study of Saytex^®^ 115 administered orally via gavage to Crl:COBS^®^ CD^®^ (SD) BR presumed pregnant rats. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0000973.
Argus Research Laboratories. 1985b. Embryo/fetal toxicity and teratogenic potential study of Saytex^®^ 115 administered orally via gavage to Crl:COBS^®^ CD^®^ (SD) BR presumed pregnant rats. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0509725.
Arneric SP, McCormack KM, Braselton WE, . 1980. Altered metabolism of progesterone by hepatic microsomes from rats following dietary exposure to polybrominated biphenyls. Toxicol Appl Pharmacol 54:187–196.6252660
Ashby J, Tennant RW. 1988. Chemical structure, Salmonella mutagenicity and extent of carcinogenicity as indicators of genotoxic carcinogenesis among 222 chemicals tested in rodents by the U.S. NCI/NTP. Mutat Res 204:17–115.3277047
Ashby J, Tennant RW. 1991. Definitive relationships among chemical structure carcinogenicity and mutagenicity for 301 chemicals tested by the U.S. NTP. Mutat Res 257:229–306.1707500
Asplund L, Athanasiadou M, Sjodin A, . 1999a. Organohalogen substances in muscle, egg and blood from healthy Baltic salmon (Salmo salar) and Baltic salmon that produced offspring with the M74 syndrome. Ambio 28(1):67–76.
Asplund L, Hornung M, Peterson RE, . 1999b. Levels of polybrominated diphenyl ethers (PBDEs) in fish from the Great Lakes and Baltic Sea. Organohalogen Compounds 40:351–354.
*Atkinson R. 1987a. Estimation of OH radical reaction rate constants and atmospheric lifetimes for polychlorobiphenyls, dibenzo-p-dioxins, and dibenzofurans. Environ Sci Technol 21:305–307.22185111
*Atkinson R. 1987b. A structure-activity relationship for the estimation of rate constants for the gas-phase reactions of OH radicals with organic compounds. Int J Chem Kinet 19:779–828.
*Atlas E, Giam CS. 1987. Ambient concentration and precipitation scavenging of atmospheric organic pollutants. Water Air Soil Pollut 38:19–36.
*Aulerich RJ, Ringer RK. 1979. Toxic effects of dietary polybrominated biphenyls on mink. Arch Environ Contam Toxicol 8:487–498.226005
Aust SD. 1984. On the mechanism of anorexia and toxicity of TCDD and related compounds. Banbury Rep 18:309–318.
*Aust SD, Dannan GA, Slieght SD . 1981. Toxicology of polybrominated biphenyls. In: Khan MAQ, Stanton RH, eds. Toxicology of halogenated hydrocarbons: Health and ecological effects. Oxford, NY: Pergamon Press, 73–96.
Babish JG, Stoewsand GS. 1977. Polybrominated biphenyls: Inducers of hepatic microsomal enzymes and type A cytochrome P450 in the rat. J Toxicol Environ Health 3:673–682.201767
Babish JG, Stoewsand GS, Lisk DJ. 1978. Effect of diet on the hepatotoxicity of polybrominated biphenyls (FireMaster PB-6). Environ Health Perspect 23:133–137.209966
*Bahn AK, Mills JL, Snyder PJ, . 1980. Hypothyroidism in workers exposed to polybrominated biphenyls. N Engl J Med 302(1):31–33.6243165
*Ballschmiter K, Zell M. 1980. Baseline studies of the global pollution: Occurrence of organohalogens in pristine European and Antarctic aquatic environments. Int J Environ Anal Chem 8:15–25.7399798
Bank PA, Cullum ME, Jensen RK, . 1989. Effect of hexachlorobiphenyl on vitamin A homeostasis in the rat. Biochim Biophys Acta 990:306–314.2923910
*Bannister R, Biegel L, Davis D, . 1989. 6-Methyl-1,3,8-trichlorodibenzofuran (MCDF) as a 2,3,7,8-tetrachlorodibenzo-p-dioxin antagonist in C57BL/6 mice. Toxicology 54:139–150.2922766
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Barontini F, Cozzani V, Cussola A, . 2001. Investigation of hexabromocyclododecane thermal degradation pathways by gas chromatography/mass spectrometry. Rapid Commun Mass Spectrom 15(9):690–698.11319791
*Barr M. 1980. Pediatric aspects of the Michigan polybrominated biphenyl contamination. Environ Res 21:255–274.6250815
*Beaudoin AR. 1977. Teratogenicity of polybrominated biphenyls in rats. Environ Res 14:81–86.196845
*Beaudoin AR. 1979. Embryo toxicity of polybrominated biphenyls. Adv Study Birth Defects 2:211–222.
Behnish PA, Hosoe K, Brouwer A, . 2001. DR.-CALUX- and EROD-TEF values for dioxin-like compounds (PXBs/PXDDs/Fs; X=Br, Cl) and others (e.g. PAHs). Organohalogen Compounds 52:49–52.
*Bekesi JG, Anderson HA, Roboz JP, . 1979. Immunologic dysfunction among PBB-exposed Michigan dairy farmers. Ann N Y Acad Sci 320:717–728.222196
*Bekesi JG, Holland JF, Anderson HA, . 1978. Lymphocyte function of Michigan dairy farmers exposed to polybrominated biphenyls. Science 199:1207–1209.204005
*Bekesi JG, Roboz J, Fischbein A, . 1985. Immunological, biochemical, and clinical consequences of exposure to polybrominated biphenyls. In: Dean JH, Luster MI, Munson AE, ., eds. Immunotoxicology and immunopharmacology. New York, NY: Raven Press, 393–406.
*Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag.
Bergman A. 2000. Brominated flame retardants-a burning issue. Organohalogen Compounds 47:35–40.
Bergman A, Athanasiadou M, Wehler EK, . 1999. Polybrominated environmental pollutants. Human and wildlife exposures. Organohalogen Compounds 43:89–92.
Bergman A, Oestman C, Nybom R, . 1997. Flame retardants and plasticizers on particulates in the modern computerized indoor environment. Organohalogen Compounds 1987:414–419.
Bernert JT, Groce DF. 1984. Acute response of rat liver microsomal lipids, lipid peroxidation, and membrane anisotropy to a single oral dose of polybrominated biphenyls. J Toxicol Environ Health 13:673–687.6092655
*Bernert JT, Groce DF, Kimbrough RD. 1983. Long-term effects of a single oral dose of polybrominated biphenyls on serum and liver lipids in rats. Toxicol Appl Pharmacol 68:424–433.6304939
*Berry DL, DiGiovanni J, Juchou MR, . 1978. Lack of tumor-promoting ability of certain environmental chemicals in a two-stage mouse skin tumorigenesis assay. Res Commun Chem Pathol Pharmacol 20:101–108.208126
*Berry DL, Slaga TJ, DiGiovanni J, . 1979. Studies with chlorinated dibenzo-(p)-dioxins, polybrominated biphenyls, and polychlorinated biphenyls in a two-stage system of mouse skin tumorigenesis: Potent anticarcinogenic effects. Ann N Y Acad Sci 320:405–414.222192
Betts KS. 2002. Rapidly rising PBDE levels in North America. Environ Sci Technol 36(3):50A–52A.
Beutler B, Cerami A. 1987. Cachectin: More than a tumor necrosis factor. N Engl J Med 316(7):379–385.3543677
BFRIP. 2002. Decabromodiphenyl ether (a.k.a. decabromodiphenyl oxide, DBDPO). Voluntary children’s chemical evaluation program (VCCEP). Data Summary. Arlington, VA: American chemistry council’s brominated flame retardant industry panel (BFRIP).
Bidleman TF. 1988. Atmospheric processes. Wet and dry deposition of organic compounds are controlled by their vapor-particle partitioning. Environ Sci Technol 22:361–367.
Bieniek D, Bahadir M, Korte F. 1989. Formation of heterocyclic hazardous compounds by thermal degradation of organic compounds. Heterocycles 28(2):719–722.
Biesemeier J. 2004. Email communication to Hana Pohl, ATSDR, regarding ongoing non-clinical toxicity studies being conducted by Great Lakes Chemical Corporation (GLCC) in collaboration with Health Canada. John Biesemeier, Manager, Regulatory Toxicology. West Lafayette, IN. June 08, 2004.
Birnbaum LS. 2001. Health effects of polybrominated dioxins and furans. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 81–84.
*Birnbaum LS, Darcey DJ, McKinney JD. 1983. Hexabromonaphthalene contaminants of polybrominated biphenyls: Chemical composition and disposition in the rat. J Toxicol Environ Health 12:555–573.6321745
Bjorklund J, Tollback P, Ostman C. 2003. Large volume injection GC-MS in electron capture negative ion mode utilizing isotopic dilution for the determination of polybrominated diphenyl ethers in air. J Sep Sci 26:1104–1110.
Blake BW, Enslein K, Gombar VK, . 1990. Salmonella mutagenicity and rodent carcinogenicity: Quantitative structure-activity relationships. Mutat Res 241(3):261–271.2195334
Blanck H, Marcus M, Hertzberg V, . 2000a. Determinants of polybrominated biphenyl serum decay among women in the Michigan PBB cohort. Environ Health Perspect 108(2):147–152.10656855
*Blanck H, Marcus M, Rubin C, . 2000b. Growth in girls exposed perinatally to polybrominated biphenyls and polychlorinated biphenyls. Am J Epidemiol 151(11):S23.
Blanck H, Marcus M, Tolbert PE, . 1999. Age at menarche in girls exposed perinatally to polybrominated biphenyl. Am J Epidemiol 149:S21.
Blay P, Nilsson C, Owman C, . 1993. Transthyretin expression in the rat brain: Effect of thyroid functional state and role in thyroxine transport. Brain Res 632(1–2):114–120.8149219
Bleavins MR, Aulerich RJ. 1987. Feed consumption and food passage time in mink (Mustela vison) and European ferrets (Mustela putorius furo). Lab Anim Sci 31:268–269.
*Bleavins MR, Aulerich MR, Ringer RK. 1980. Placental and mammary transfer of polychlorinated and polybrominated biphenyls in the mink and ferret. ASTM Spec Tech Publ 757:121–131.
BLR. 2002. Book of chemical lists on CD-Rom. Old Saybrook, CT: Business & Legal Reports, Inc.
Bocio A, Llobet JM, Domingo JL, . 2003. Polybrominated diphenyl ethers (PBDEs) in foodstuffs: Human exposure through the diet. J Agric Food Chem 7(51):3191–3195.
*Boethling SB, Mackay D. 2000. Handbook of property estimation methods for chemicals. Boca Raton, FL: CRC Press LLC.
Booij K, Zegers BN, Boon JP. 2000. Levels of some polybrominated diphenyl ether (PBDE) flame retardants along the Dutch coast as derived from their accumulation in SPMDs and blue mussels (Mytilus edulis). Organohalogen Compounds 47:89–92.
Booij K, Zegers BN, Boon JP. 2002. Levels of some polybrominated diphenyl ether (PBDE) flame retardants along the Dutch coast as derived from their accumulation in SPMDs and blue mussels (Mytilus edulis). Chemosphere 46(5):683–688.11999791
Boon JP, Lewis WE, Tjoen-a-Choy MR, . 2002. Levels of polybrominated diphenyl ether (PBDE) flame retardants in animals representing different trophic levels of the North Sea food web. Environ Sci Technol 36:4025–4032.12380070
*Borlakoglu JT, Wilkins JP. 1993. Metabolism of di-, tri- and tetrabromobiphenyls by hepatic microsomes isolated from control animals and animals treated with Aroclor 1254, a commercial mixture of polychlorinated biphenyls (PCBs). Comp Biochem Physiol C 105(1):107–112.8101787
Boyages SC. 2000. The neuromuscular system and brain in hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid. Philadelphia, PA: Lippincott Williams & Wilkins, 803–810.
Braekevelt E, Tittlemier SA, Tomy GT. 2003. Direct measurement of octanol-water partition coefficients of some environmentally relevant brominated diphenyl ether congeners. Chemosphere 51(7):563–567.12615110
Branchi I, Alleva E, Costa LG. 2001. A preliminary characterization of behavioural alterations following perinatal exposure to a polybrominated diphenylether (PBDE 99). The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 75.
Branchi I, Alleva E, Costa LG. 2002. Effects of perinatal exposure to a polybrominated diphenyl ether (PBDE 99) on mouse neurobehavioural development. Neurotoxicology 23(3):375–384.12387364
Brenner KS, Knies H. 1990. Formation of polybrominated dibenzofurans (PBDFs) and -dioxins (PBDDs) during extrusion production of a polybutyleneterephthalate (PBTP)/glass fiber resin blended with decabromodiphenylether (DBDPE)/antimony trioxide: Product and workplace analysis. Organohalogen Compounds 2:319–324.
Brenner KS, Knies H. 1993. Workplace of PBDFs and PBDDs during extrusion production and injection modeling of a polybutyleneterephthalate (PBTP) glass fiber/tetrabromo-bisphenol A carbonate oligomer (BC52)/Sb2O3-resin; part II. Chemosphere 26(11):1953–1963.
Breslin WJ, Kirk HD, Zimmer MA. 1989. Teratogenic evaluation of a polybromodiphenyl oxide mixture in New Zealand white rabbits following oral exposure. Fundam Appl Toxicol 12(1):151–157.2538377
*Brilliant LB, Van Amburg G, Isbister J, . 1978. Breast-milk monitoring to measure Michigan’s contamination with polybrominated biphenyls. Lancet Sept:643–646.
British Industrial Biological Research Association. 1977. The acute oral toxicity of pentabromodiphenylether to rats. Submitted to U.S. Environmental Protection Agency under TSCA Section 8D. OTS052287.
Brouwer A. 1998. Structure-dependent multiple interactions of polyhalogenated aromatic hydrocarbons with the thyroid hormone system. Organohalogen Compounds 37:225–232.
Brouwer A, Meerts IATM, Bergman A, . 2001. Thyroidenic, estrogenic, and dioxin-like activity of polybrominated diphenyl ethers (PBDEs) in vitro. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 241–245.
Brown DJ, Van Overmeire I, Goeyens L, . 2001. Analysis of brominated flame retardants and brominated dibenzodioxins and biphenyls for Ah receptor activation using the Calux bioassay. Organohalogen Compounds 54:12–15.
Brown DJ, Van Overmeire I, Goeyens L, . 2004. Analysis of Ah receptor pathway activation by brominated flame retardants. Chemosphere 55:1509–1518.15099731
Brown GG, Nixon R. 1979. Exposure to polybrominated biphenyls. Some effects on personality and cognitive functioning. JAMA 242:523–527.221695
*Brown GG, Preisman RC, Anderson MD, . 1981. Memory performance of chemical workers exposed to polybrominated biphenyls. Science 212:1413–1415.6262920
Brown V. 2003. Disrupting a delicate balance: Environmental effects on the thyroid. Environ Health Perspect 111(12):A642–A649.12948907
BSEF. 2002. An introduction to brominated flame retardants. Brussels, Belgium: Bromine Science and Environmental Forum, 1–28.
BSEF. 2003. Major brominated flame retardants volume estimate. Total market demand by region in 2001. Brussels, Belgium: Bromine Science and Environmental Forum. http://www.bsef-site.com/bromine/our_industry/.
*Buchmann A, Ziegler S, Wolf A, . 1991. Effects of polychlorinated biphenyls in rat liver: Correlation between primary subcellular effects and promoting activity. Toxicol Appl Pharmacol 111:454–468.1684070
Bunce NJ, Chen G, Joyce EM, . 2001a. Capacity of PBDEs to induce CYPUA by the Ah receptor mediated pathway. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 77–79.
Bunce NJ, Konstantinov AD, Chittim BG. 2001b. New synthetic methods for polybrominated diphenyl ether congeners. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 183–186.
Burreau S, Axelman J, Brogman D, . 1997. Dietary uptake in pike (Esox incius) of some polychlorinated biphenyls, polychlorinated naphthalenes and polybrominated diphenyl ethers administered in natural diets. Environ Toxicol Chem 16:2508–2513.
Burreau S, Broman D, Zebuhr Y. 1999. Biomagnification quantification of PBDEs in fish using stable nitrogen isotopes. Organohalogen Compounds 40:363–366.
Burreau S, Zeb HR, Ishaq R, . 2000. Comparison of biomagnification of PBDEs in food chains from the Baltic Sea and the North Atlantic Sea. Organohalogen Compounds 47:253–255.
*Burse VW, Needham LL, Liddle JA, . 1980. Interlaboratory comparison for polybrominated biphenyls in human serum. J Anal Toxicol 4:22–26.6098783
Buser HR. 1986. Polybrominated dibenzofurans and dibenzo-p-dioxins: Thermal reaction products of polybrominated diphenyl ether flame retardants. Environ Sci Technol 20:404–408.22300214
Butt CM, Truong J, Diamond ML, . 2003. Polybrominated diphenyl ether (PBDE), dioxin and furan (PCDD/F) concentrations in organic window films from southern Ontario. In: Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
*Byrne JJ, Carbone JP, Hanson EA. 1987. Hypothyroidism and abnormalities in the kinetics of thyroid hormone metabolism in rats treated chronically with polychlorinated biphenyl and polybrominated biphenyl. Endocrinology 21:520–527.
*Byrne JJ, Carbone JP, Pepe MG. 1988. Suppression of serum adrenal cortex hormones by chronic low-dose polychlorobiphenyl or polybromobiphenyl treatments. Arch Environ Contam Toxicol 17:47–53.2827589
*Cabe PA, Tilson HA. 1978. Hind limb extensor response: A method for assessing motor dysfunction in rats. Pharmacol Biochem Behav 9:133–136.212765
*Cagen SZ, Preache MM, Gibson JE. 1977. Enhanced disappearance of drugs from plasma following polybrominated biphenyls. Toxicol Appl Pharmacol 40:317–325.195365
California Assembly. 2003. Assembly Bill No. 302. An act to add Chapter 10 (polybrominated diphenyl ethers) to Part 3 of Division 104 of the Health and Safety Code, relating to toxic substances. Approved August 9, 2003. http://www.leginfo.ca.gov/cgi-bin/calawquery?codesection=hsc.
California Assembly. 2004. Assembly Bill No. 2587. A proposed act to amend Sections 108921 and 108922 of the Health and Safety Code, relating to toxic substances. Amended in Senate August 23, 2004. http://www.leginfo.ca.gov/cgi-bin/calawquery?codesection=hsc.
Canton RF, Letcher R, Sanderson T, . 2003. Effects of brominated flame retardants on activity of the steroidogenic enzyme aromatase (CYP19) in H295R human adrenocortical carcinoma cells in culture. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65
Capen CC. 1997. Mechanistic data and risk assessment of selected toxic points of the thyroid gland. Toxicol Pathol 25:39–48.9061850
Carlson GP. 1980a. Induction of xenobiotic metabolism in rats by brominated diphenyl ethers administered for 90 days. Toxicol Lett 6:207–212.6250253
Carlson GP. 1980b. Induction of xenobiotic metabolism in rats by short-term administration of brominated phenyl ethers. Toxicol Lett 5(1):19–26.7376196
*Castracane VD, Allen-Rowlands CF, Hamilton MG, . 1982. The effect of polychlorinated biphenyl (PBB) on testes, adrenal, and pituitary function in the rat. Proc Soc Exp Biol Med 169:343–347.6278511
*CDC/ATSDR. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems: Centers for Disease Control/Agency for Toxic Substances and Disease Registry. Atlanta, GA.
*Chanda JJ, Anderson HA, Glamb RW, . 1982. Cutaneous effects of exposure to polybrominated biphenyls (PBBs): The Michigan PBB incident. Environ Res 29:97–108.6291929
Chen E. 1979. An American tragedy prentice. Englewood Cliffs, NJ: Prentice-Hall Inc.
Chen G, Bunce NJ. 2001. PBDE congeners as Ah receptor agonist and antagonists. Organohalogen Compounds 53:353–356.
Chen G, Konstantinov AD, Chittim BG, . 2001. Synthesis of polybrominated diphenyl ethers and their capacity to induce CYPIA by the Ah receptor mediated pathway. Environ Sci Technol 35(18):3749–3756.11783655
Chen JW, Harner T, Yang P, . 2003. Quantitative predictive models for octanol-air partition coefficients of polybrominated diphenyl ethers at different temperatures. Chemosphere 51(7):577–584.12615112
Chen LC, Berberian I, Koch B, . 1992. Polychlorinated and polybrominated biphenyl congeners and retinol levels in rat tissues: Structural-activity relationships. Toxicol Appl Pharmacol 114(1):47–55.1316647
*Chessells M, Hawker DW, Connell DW. 1992. Influence of solubility in lipid on bioconcentration of hydrophobic compounds. Ecotoxicol Environ Saf 23:260–273.1376231
*Chhabra RS, Bucher JR, Hasman JK, . 1993. Comparative carcinogenicity of polybrominated biphenyls with or without perinatal exposure in rats and mice. Fundam Appl Toxicol 21(4):451–460.8253298
Choi J-W, Fujimaki S, Kitamura K, . 2002. Polybrominated dibenzo-p-dioxins (PBDEs), dibenzofurans (PBDFs) and diphenyl ethers (PBDEs) in Japanese human adipose tissue. Organohalogen Compounds 58:169–171.
Choi J-W, Fujimaki S, Kitamura K, . 2003. Historical trends of PBDD/Fs, PBDEs, PCDD/Fs and dioxin-like PCBs in sediment cores from Tokyo Bay. Organohalogen compounds. Boston, MA: Dioxins 2003. 60–65.
Chou SF, Jacobs LW, Penner, D, . 1978. Absence of plant uptake and translocation of polybrominated biphenyls (PBBs). Environ Health Perspect 23:9–12.210006
Choudhry GG, Sundstrom G, Ruzo LO, . 1977. Photochemistry of chlorinated diphenyl ethers. J Agric Food Chem 25:1371–1376.
Christensen JH, Platz J. 2001. Screening of polybrominated diphenyl ethers in blue mussels, marine and freshwater sediments in Denmark. J Environ Monit 3(5):543–547.11695126
Christensen JH, Glasius M, Pecseli M, . 2002. Polybrominated diphenyl ethers (PBDEs) in marine fish and blue mussels from southern Greenland. Chemosphere 47(6):631–638.12047074
*Chu I, Villeneuve DC, Becking GC, . 1980. Short-term study of the combined effects of mirex, photomirex, and ketone with halogenated biphenyls in rat. J Toxicol Environ Health 6:421–432.6156243
*Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
*Colborn T, Clement C, eds. 1992. Chemically-induced alterations in sexual and functional development: The wildlife-human connection. In: Advances in modern environmental toxicology, Vol. XXI. Princeton, NJ: Princeton Scientific Publishing.
*Colborn T, vom Saal F, Soto A. 1993. Developmental effects of endocrine-disrupting chemicals in wildlife and humans. Environ Health Perspect 101(5):378–384.8080506
Collins WT, Capen CC, Garthoff LH, . 1978. Comparative toxicity of polychlorinated biphenyl and polybrominated biphenyl in the rat thyroid gland: Light and electron microscopic alterations after subacute dietary exposure. J Environ Pathol Toxicol 1:587–599.214505
*Corbett TH, Beaudoin AR, Cornell RG, . 1975. Toxicity of polybrominated biphenyls (Firemaster BP-6) in rodents. Environ Res 10:390–396.1082414
Corbett TH, Simmons JL, Kawanishi H, . 1978. EM changes and other toxic effects of FireMaster BP-6 (polybrominated biphenyls) in the mouse. Environ Health Perspect 23:275–281.209987
*Cordle F, Corneliussen P, Jelinek C, . 1978. Human exposure to polychlorinated biphenyls and polybrominated biphenyls. Environ Health Perspect 24:157–172.17539143
Covaci A, Chu SG, Van de Vijver K, . 2002a. Levels in biotic compartments. Determination of POPs in harbour porpoises (Phocoena phocoena) stranded on the Belgian North sea coast. Organohalogen Compounds 58:443–436.
*Covaci A, de Boer J, Ryan JJ, . 2002b. Determination of polybrominated diphenyl ethers and polychlorinated biphenyls in human adipose tissues by large-volume injection-narrow-bore capillary gas chromatography/electron impact low-resolution mass spectrometry. Anal Chem 74(4):790–798.11866059
Covaci A, de Boer J, Ryan JJ, . 2002c. Distribution of organobrominated and organochlorinated contaminants in Belgian human tissue. Environ Res 88:210–228.12051799
*Covaci A, Voorspoels S, de Boer J. 2003. Determination of brominated flame retardants with emphasis on polybrominated diphenyl ethers (PBDEs) in environmental and human samples- a review. Environ Int 29:735–756.12850093
Cramer PH, Ayling RE, Thornburg KR, . 1990. Evaluation of an analytical method for the determination of polybrominated dibenzo-p-dioxins/dibenzofurans (PBDD/PBDF) in human adipose. Chemosphere 20(7–9):821–827.
Crhova S, Cerna M, Grabie R, . 2002. Polybrominated flame retardants. Polybrominated flame retardants in human adipose tissue in Czech Republic inhabitants. The pilot study. Organohalogen Compounds 58:241–244.
*Crisp TM, Clegg ED, Cooper RL, . 1998. Environmental endocrine disruption: An effects assessment and analysis. Environ Health Perspect 106(1):11–56.9539004
Cushing CA, Holocky KC, Pyatt DW, . 2003. Estimated children’s exposure to decabromodiphenyl oxide in the US. Toxicol Sci 72(S-1):393.
Dagnani MJ, Barda HJ, Benya TJ, . 1986. Bromine compounds. In: Gerhartz W, ed. Ullman’s encyclopedia of industrial chemistry. Baton Rouge, Louisiana, 405–417.
*Damstra T, Jurgelski W, Posner HS, . 1982. Toxicity of polybrominated biphenyls (PBBs) in domestic and laboratory animals. Environ Health Perspect 44:175–188.6282577
Danerud PO, Aune M, Atuma S, . 2002. Time trend of polybrominated diphenyl ether (PBDE) levels in breast milk from Uppsala, Sweden, 1996-2001. Organohalogen Compounds 58:233–236.
Danerud PO, Eriksen GS, Johannesson T, . 2001. Polybrominated diphenyl ethers: Occurrence, dietary exposure, and toxicology. Environ Health Perspect Suppl 109:49–68.11250805
Danish EPA. 1999. Brominated flame retardants. Substance flow analysis and assessment of alternatives. Danish Environmental Protection Agency, 1–200.
*Dannan GA, Guengerich FP, Kaminsky LS, . 1983. Regulation of cytochrome P-450. Immunochemical quantitation of eight isozymes in liver microsomes of rats treated with polybrominated biphenyl congeners. J Biol Chem 258(2):1282–1288.6296075
*Dannan GA, Moore RW, Aust SD. 1978a. Studies on the microsomal metabolism and binding of polybrominated biphenyls (PBBs). Environ Health Perspect 23:51–61.28220
*Dannan GA, Moore RW, Besaw LC, . 1978b. 2,4,5,3’,4’,5’-Hexabromobiphenyl is both a 3-methylcholanthrene- and a phenobarbital-type inducer of microsomal drug metabolizing enzymes. Biochem Biophys Res Commun 85:450–457.217380
*Dannan GA, Sleight SD, Aust SD. 1982a. Toxicity and microsomal enzyme induction effects of several polybrominated biphenyls fo Firemaster. Fundam Appl Toxicol 2:313–321.6309595
*Dannan GA, Sleight SD, Fraker PJ, . 1982b. Liver microsomal enzyme induction and toxicity studies with 2,4,5,3’,4’-pentabromobiphenyl. Toxicol Appl Pharmacol 64:187–203.6289491
*Darjono, Sleight SD, Stowe HD, . 1983. Vitamin A status, polybrominated biphenyl (PBB) toxicosis, and common bile duct hyperplasia in rats. Toxicol Appl Pharmacol 71:184–193.6314606
Darnerud PO, Sinjari T. 1996. Effects of polybrominated diphenyl ethers (PBDEs) and polybrominated biphenyls (PCBs) on thyroxine and TSH blood levels in rats and mice. Organohalogen Compounds 29:316–319.
Darnerud PO, Thuvander A. 1998. Studies on immunological effects of polybrominated diphenyl ether (PBDE) and polychlorinated biphenyl (PCB) exposure in rats and mice. Organohalogen Compounds 35:415–418.
Darnerud PO, Atuma S, Aune M, . 1998. Polybrominated diphenyl ethers (PBDEs) in breast milk from primiparous women in Uppsala County, Sweden. Organohalogen Compounds 35:411–414.
Darnerud PO, Eriksen GS, Johannesson T, . 2001. Polybrominated diphenyl ethers: Occurrence, dietary exposure, and toxicology. Environ Health Perspect 109:49–64.11250805
*Daston GP, Gooch JW, Breslin WJ, . 1997. Environmental estrogens and reproductive health: A discussion of the human and environmental data. Reprod Toxicol 11(4):465–481.9241667
de Boer J. 1989. Organochlorine compounds and bromodiphenylethers in livers of Atlantic cod (Gadus morhua) from the North Sea, 1977-1987. Chemosphere 18(11/12):2131–2140.
de Boer J. 1990. Brominated diphenyl ethers in Dutch freshwater and marine fish. Organohalogen Compounds 2:315–318.
de Boer J. 2000. First worldwide interlaboratory study on polybrominated diphenyl ethers (PBDEs). Organohalogen Compounds 45:118–121.
de Boer J, Allchin C. 2001. Brominated flame retardants. An indication of temporal trends in environmental PBDE levels in Europe. Organohalogen Compounds 52:13–17.
de Boer J, Cofino WP. 2002. First world-wide interlaboratory study on polybrominated diphenyl ethers (PBDEs). Chemosphere 46(5):625–633.11999785
de Boer J, Korytar P. 2001. Analysis of brominated flame retardants - Methodological issues. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 45–49.
*de Boer J, de Boer K, Boon JP. 2000a. Polybrominated biphenyls and diphenylethers. In: Paasivirta J., ed. Handbook of environmental chemistry Vol. 3 part K. Berlin Heidelberg: Springer-Verlag, 61–95.
de Boer J, Larry R, Dettmer LW, . 1998a. Polybrominated diphenyls in human adipose tissue and relation with watching television. A case study. Organohalogen Compounds 35:407–410.
de Boer J, van der Horst A, Wester PG. 2000b. PBDEs and PBBs in suspended particulate matter, sediments, sewage treatment plant in- and effluent and biota from The Netherlands. Organohalogen Compounds 47:85–88.
de Boer J, van der Zande TE, Pieters H, . 2001. Organic contaminants and trace metals in flounder liver and sediment from the Amsterdam and Rotterdam harbours and off the Dutch coast. J Environ Monit 3(4):386–393.11523438
de Boer J, Wester PG, Klamer HJ, . 1998b. Do flame retardants threaten ocean life? Nature 394(6688):28–29.9665124
*de Boer J, Wester PG, Pastor RD, . 1998c. Polybrominated biphenyls and diphenylethers in sperm whales and other marine mammals. A new threat to ocean life? Organohalogen Compounds 35:383–386.
de Boer J, Wester PG, van der Horst A, . 2003. Polybrominated diphenyl ethers in influents, suspended particulate matter, sediments, sewage treatment plant and effluents and biota from the Netherlands. Environ Pollut 122:63–74.12535596
*DeCarlo VJ. 1979. Studies in brominated chemicals in the environment. Ann N Y Acad Sci 320:678–681.287406
*de Kok JJ, De Kok A, Brinkman UA, . 1977. Analysis of polybrominated biphenyls. J Chromatogr 142:367–383.199610
de Kok JJ, de Kok A, Brinkman UA. 1979. Analysis of polybrominated aromatic ethers. J Chromatogr 171:269–278.
Denison MS, Fisher JM, Whitlock JP. 1989. Protein-DNA interactions at recognition sites for the dioxin-Ah receptor complex. J Biol Chem 264:16478–16482.2550446
*Dent JG. 1978. Characteristics of cytochrome P-450 and mixed function oxidase enzymes following treatment with PBBs. Environ Health Perspect 23:301–307.209991
Devito M, Zhou T, Taylor M, . 2001. Effects of brominated diphenyl ethers on thyroid hormones in a short-term screen and in developmental studies. Organohalogen Compounds 53:1–4.
de Winter-Sorkina R, Bakker MI, Baumann RA, . 2003. Exposure assessment for Dutch nursing infants to brominated flame retardants via breast milk. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
de Wit CA. 2000. Levels and trends of BFRs in the European environment. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 135–138.
de Wit CA. 2002. An overview of brominated flame retardants in the environment. Chemosphere 46(5):583–624.11999784
*Di Carlo FJD, Seifter J, De Carlo VJ. 1978. Assessment of the hazards of polybrominated biphenyls. Environ Health Perspect 23:351–365.209999
*Dixon D, Sleight SD, Aust SD, . 1988. Tumor-promoting, initiating, and hepatotoxic effects of 3,4,3’,3’-tetrabromobiphenyl (34-TBB) in rats. J Am Coll Toxicol 7(5):687–697.
Dodder NG, Strandberg B, Hites RA. 2000. Concentrations and spatial variations of polybrominated diphenyl ethers in fish and air from the northeastern United States. Organohalogen Compounds 47:69–72.
Dodder NG, Strandberg B, Hites RA. 2002. Concentrations and spatial variations of polybrominated diphenyl ethers and several organochlorine compounds in fishes from the northeastern United States. Environ Sci Technol 36(2):146–151.11827047
*Domino EF, Wright DD, Domino SE. 1980. GC-EC analysis of polybrominated biphenyl constituents of Firemaster FF-1 using tetrabromobiphenyl as an internal standard. J Anal Toxicol 4:299–304.6259446
*Domino LE, Domino SE, Domino EF. 1982. Toxicokinetics of 2,2’,4,4’,5,5’-hexabromobiphenyl in the rat. J Toxicol Environ Health 9:815–833.6288970
Donnelly J, Grange AH, Nunn NJ, . 1987. Analysis of thermoplastic resins for brominated dibenzofurans. Biomed Environ Mass Spectrom 18(10):884–896.
*Doucette WJ, Andren AW. 1988. Estimation of octanol/water partition coefficients: Evaluation of six methods for highly hydrophobic aromatic hydrocarbons. Chemosphere 17:345–359.
Dow Chemical Company. 1971. Results of 30 day dietary feeding studies on octabromodiphenyl SA-1902 and decabromodiphenyl oxide SA-1892.1. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0522265.
Dow Chemical Company. 1975. Results of a reproduction study in rats maintained on diets containing decabromodiphenyl oxide. Submitted to U.S. Environmental Protection Agency under TSCA Section 8D. OTS0522252.
Dow Chemical Company. 1985. Decabromodiphenyloxide: A summary of an oral teratology study in Sprague-Dawley rats. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0522284.
Dumler R, Lenoir D, Thoma H, . 1990. Thermal formation of polybrominated dibenzofurans and dioxins from decabromodiphenyl ether flame retardants influence of antimony-III oxide and the polymer matrix. Chemosphere 20(10–12):1867–1874.
Dumler R, Thoma H, Lenoir D, . 1989a. PBDF and PBDD from the combustion of bromine containing flame retarded polymers: A survey. Chemosphere 19(12):2023–2031.
Dumler R, Thoma H, Lenoir D, . 1989b. Thermal formation of polybrominated dibenzodioxins (PBDD) and dibenzofurans (PBDF) from bromine containing flame retardants. Chemosphere 19(1–6):305–308.
Dumler-Gradl R, Tartler D, Thoma H, . 1995. Detection of polybrominated diphenylethers (PBDE), dibenzofurans (PBDF) and dibenzodioxins (PBDD) in scrap of electronics and recycled products. Organohalogen Compounds 24:101–104.
*Dunckel AE. 1975. An updating on the polybrominated biphenyl disaster in Michigan. J Am Vet Med Assoc 167:838–841.1184446
Dungey S. 2001. Environmental risk assessment of octa- and decabromodiphenyl ether. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 37–39.
*Durst HI, Willett LB, Brumm CJ, . 1977. Effects of polybrominated biphenyls on health and performance of pregnant Holstein heifers. J Dairy Sci 60:1294–1299.198446
Easton MDL, Luszniak D, Von der Geest E. 2002. Preliminary examination of contaminant loadings in farmed salmon, wild salmon and commercial salmon feed. Chemosphere 46(7):1053–1074.11999769
Ebert J, Lorenze W, Bahadir M. 1999. Optimization of the analytical performance of polybrominated dibenzo-p-dioxins and dibenzofurans (PBDD-F). Chemosphere 39(6):977–986.
Ecobichon DJ, Hansell MM, Safe S. 1977. Halogen substituents at the 4- and 4’-positions of biphenyl: Influence on hepatic function in the rat. Toxicol Appl Pharmacol 42:359–366.595014
*Ecobichon DJ, Hansell MM, Safe S. 1979. Isomerically pure bromobiphenyl congeners and hepatic mono-oxygenase activities in the rat: Influence of position and degree of bromination. Toxicol Appl Pharmacol 47:341–352.222009
*Ecobichon DJ, Hidvegi S, Comeau AM, . 1983. Transplacental and milk transfer of polybrominated biphenyls to perinatal guinea pigs from treated dams. Toxicology 28:51–63.6314608
Egginton J. 1980. The poisoning of Michigan. New York, NY: WW Norton & Company.
*Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15(1):30–38.
el Dareer SM, Kalin JR, Tillery KF, . 1987. Disposition of decabromobiphenyl ether in rats dosed intravenously or by feeding. J Toxicol Environ Health 22(4):405–415.3694703
*Elferink CJ, Whitlock JPJ. 1990. 2,3,7,8-Tetrachlorodibenzo-p-dioxin-inducible, Ah receptor-mediated bending of enhancer DNA. J Biol Chem 265(10):5718–5721.2156826
Eljarrat E, Lacorte S, Barcelo D. 2002. Optimization of congener-specific analysis of 40 polybrominated diphenyl ethers by gas chromatography/mass spectrometry. J Mass Spectrom 37(1):76–84.11813314
ENVIRON. 2003a. Voluntary children’s chemical evaluation program pilot. Tier I assessment of the potential health risks to children associated with exposure to the commercial octabromodiphenyl ether product. CAS No. 32536-52-0. Emeryville, CA: ENVIRON Int. Corp.
ENVIRON. 2003b. Voluntary children’s chemical evaluation program pilot. Tier I assessment of the potential health risks to children associated with exposure to the commercial pentabromodiphenyl ether product. CAS No. 32534-81-9. Emeryville, CA: ENVIRON Int. Corp.
EPA. 1977. Market input/output studies. Task IV. Polybrominated biphenyls. U.S. Environmental Protection Agency. EPA560677017.
EPA. 1981. Development of test for determining anaerobic biodegradation potential: Washington, DC: U.S. Environmental Protection Agency.
EPA. 1988a. Polybrominated biphenyl. Code of Federal Regulations: Washington, DC: U.S. Environmental Protection Agency 704.195.
EPA. 1988b. U.S. Environmental Protection Agency: Part 372. Toxic chemical release reporting: Community right-to-know. 40 CFR Ch 1 (7-1-88-ed.).
*EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066A.
EPA. 1995. Toxic chemical release inventory. Reporting form R and instructions. Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. EPA745K95051.
*EPA. 1997a. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
EPA. 1997b. Automated form R for Windows: User’s guide (RY97). Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics.
*EPA. 1998. Instructions for reporting for the 1998 partial updating of the TSCA chemical inventory data base. U.S. Environmental Protection Agency. Office of Prevention, Pesticides and Toxic Substances. EPA749B98001.
EPA. 2001. List of lists. Consolidated list of chemicals subject to the Emergency Planning and Community Right-to-Know Act (EPCRA) and Section 112(r) of the Clean Air Act. U.S. Environmental Protection Agency. Office of Solid Waste and Emergency Response. EPA550B98003.
EPA. 2002a. Criteria for municipal solid waste landfills. List of hazardous inorganic and organic constituents. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 258, Appendix II. http://ecfr.access.gpo.gov/otcgi/cfr/otfilter. April 19, 2002.
EPA. 2002b. Identification and listing of hazardous waste. Discarded commercial chemical products, off-specification species, container residues, and spill residues thereof. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.33(f). http://ecfr.access.gpo.gov/otcgi/cf. April 19, 2002.
EPA. 2002c. Land disposal restrictions. Universal treatment standards. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.48(a). http://ecfr.access.gpo.gov/otcg. April 19, 2002.
EPA. 2002d. Radiation protection program. Health and environmental protection standards for uranium and thorium mill tailings. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 192, Appendix I. http://ecfr.access.gpo.gov/otcg. April 19, 2002.
EPA. 2002e. Standards for owners and operators of hazardous waste treatment, storage, and disposal facilities. Ground-water monitoring list. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264, Appendix IX. http://ecfr.access.gpo.gov/otcgi/cfr/otfilter. April 19, 2002.
EPA. 2002f. Superfund, emergency planning, and community right-to-know programs. Designation, reportable quantities, and notification. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://ecfr.access.gpo.gov/otcgi/cfr/otfilter. April 19, 2002.
*EPA. 2002g. The prior informed consent (PIC) procedure: International right-to-know. U.S. Environmental Protection Agency. Office of Pesticide Programs. http://www.epa.gov/oppfod01/international/pic.htm. April 19, 2002.
*EPA. 2002h. Toxic chemical release reporting: Community right-to-know. Chemicals and chemical categories to which this part applies. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65(c). http://ecfr.access.gpo.gov/otcgi/cf. April 18, 2002.
EPA. 2002i. Toxic Substances Control Act. Chemical information rules. Chemical lists and reporting periods. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 712.30(d). http://ecfr.access.gpo.gov/otcgi/cfr/otfil. April 19, 2002.
EPA. 2002j. Toxic Substances Control Act. Dibenzo-para-dioxins/dibenzofurans. Chemical substances for testing. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 766.25(a)(1). http://ecfr.access.gpo.gov/otcg. April 19, 2002.
EPA. 2002k. Toxic Substances Control Act. Dibenzo-para-dioxins/dibenzofurans. Reporting requirements. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 766.35. http://ecfr.access.gpo.gov/otcgi/cfr/otfilter. April 19, 2002.
EPA. 2002l. Toxic Substances Control Act. Health and safety data reporting. Substances and listed mixtures to which this subpart applies. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 716.120. http://ecfr.access.gpo.gov/otcgi/cfr/otfilter. April 19, 2002.
EPA. 2002m. Toxic Substances Control Act. Significant new uses of chemical substances. 4-Bromophenyl phenyl ether. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 721.3430. http://ecfr.access.gpo.gov/otcg. April 19, 2002.
*EPA. 2002n. Toxic Substances Control Act. Significant new uses of chemical substances. Polybrominated biphenyls. U.S. Environmental Protection Agency. Code of Federal Regulations. 40CFR 721.1790. http://ecfr.access.gpo.gov/otcg. April 18, 2002.
EPA. 2002o. Voluntary children’s chemical evaluation program. U.S. Environmental Protection Agency. Office of Pollution Prevention and Toxics. http://www.epa.gov/chemrtk/childhlt.htm. April 19, 2002.
EPA. 2004a. Decabromodiphenyl ether (CAS No. 1163-19-5). Voluntary children’s chemical evaluation program. U.S. Environmental Protection Agency. Office of Pollution Prevention and Toxics. http://www.epa.gov/chemrtk/vccep/chem21.htm. June 24, 2004.
EPA. 2004b. Pentabromodiphenyl ether (CAS No. 32534-81-9). Voluntary children’s chemical evaluation program. U.S. Environmental Protection Agency. Office of Pollution Prevention and Toxics. http://www.epa.gov/chemrtk/vccep/chem22.htm. June 24, 2004.
EPA. 2004c. Octabromodiphenyl ether (CAS No. 32536-52-0). Voluntary children’s chemical evaluation program. U.S. Environmental Protection Agency. Office of Pollution Prevention and Toxics. http://www.epa.gov/chemrtk/vccep/chem23.htm. June 24, 2004.
*EPA. 2004d. NCER. STAR. Science to achieve results. National Center for Environmental Research. U.S. Environmental Protection Agency. http://cfpub.epa.gov/ncer_abstracts/index.cfm/fuseaction/search.welcome. September 1, 2004.
Eriksson J, Jakobsson E, Marsh G, . 2001a. Photo decomposition of brominated diphenylethers in methanol/water. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 203–206.
Eriksson P, Anakarberg E, Viberg H, . 2001b. Neonatal exposure to toxicants defined critical period: Altered adult susceptibility. Neurotoxicology 22(4):510.
Eriksson P, Fischer C, Karlsson H, . 2003. Interaction between a brominated flame-retardant (PBDE 99) and an ortho-substituted PCB (PCB 52) enhances developmental neurotoxic effects. Toxicol Sci 72(S-1):323–324.
Eriksson P, Jakobsson E, Fredriksson A. 1998. Developmental neurotoxicity of brominated flame-retardants, polybrominated diphenyl ethers, and tetrabromo-bis-phenol A. Organohalogen Compounds 35:375–377.
Eriksson P, Jakobsson E, Fredriksson A. 2001c. Brominated flame retardants: A novel class of developmental neurotoxicants in our environment. Environ Health Perspect 109(9):903–908.11673118
Eriksson P, Viberg H, Ankarberg E, . 2001d. Polybrominated diphenylethers (PBDEs): A novel class of developmental neurotoxicants in our environment. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 71–73.
Eriksson P, Viberg H, Fischer C, . 2002a. A comparison on developmental neurotoxic effects of hexabromocyclododecane, 2,2’,4,4’,5,5’-hexabromodiphenyl ether (PBDE 153) and 2,2’,4,4’,5,5’-hexachlorobiphenyl (PCB 153). Organohalogen Compounds 57:389–390.
Eriksson P, Viberg H, Jakobsson E, . 1999. PBDE 2,2’, 4,4’, 5-pentabromodiphenyl ether, causes permanent neurotoxic effects during a defined period of neonatal brain development. Organohalogen Compounds 40:333–336.
Eriksson P, Viberg H, Jakobsson E, . 2002b. A brominated retardant, 2,2’4,4’,5-pentabromodiphenyl ether: Uptake, retention, and induction of neurobehavioral alterations in mice during a critical phase of neonatal brain development. Toxicol Sci 67:98–103.11961221
*Erney DR. 1975. Confirmation of polybrominated biphenyl residues in feeds and dairy products, using an ultraviolet irradiation-gas-liquid chromatographic technique. J Assoc Off Anal Chem 58(6):1202–1205.1194183
EU. 2001. Diphenyl ether, pentabromo derivative (pentabromodiphenyl ether). European Union Risk Assessment Report. Luxembourg: Office for Official Publications of the European Committees, 1–124.
EU. 2002. Bis(pentabromophenyl) ether. European Union Risk Assessment Report. Luxembourg: Office for Official Publications of the European Committees. EINECS No. 214-604-9, 1–279.
EU. 2003a. Diphenyl ether, octabromo derivative. European Union Risk Assessment Report. Luxembourg: Office for Official Publications of the European Committees, 1–279.
EU. 2003b. Consolidated TEXT. CONSLEG system. Office for Official Publications of the European Communities. European Union. http://europa.eu.int/eru-lex/en/consleg/pdf/2003/en_2003L0011_do_001.pdf. September 01, 2004.
*EU. 2004. EU funded research projects. European Union. http://europa.eu.int/comm/research/endocrine/projects_ongoing_en.html. September 1, 2004.
*Evans MG, Sleight SD. 1989. Effects of simultaneous dietary exposure to 2,2’,4,4’,5,5’-hexa-bromobiphenyl and 3,3’,4,4’,4,4’-hexachlorobiphenyl on hepatic tumor promotion in rats. J Am Coll Toxicol 8(6):1201–1206.
*Eyster JT, Humphrey HEB, Kimbrough RD. 1983. Partitioning of polybrominated biphenyls (PBBs) in serum, adipose tissue, breast milk, placenta, cord blood, and biliary fluid, and feces. Arch Environ Health 38:47–53.6299210
*Farber T, Kasza L, Giovetti A, . 1978. Effect of polybrominated biphenyls (Firemaster BP-6) on the immunologic system of the beagle dog. Toxicol Appl Pharmacol 45:343.
Farrar DB, Crump KS. 1988. Exact statistical tests for any carcinogenic effect in animal bioassays. Fundam Appl Toxicol 11(4):652–663.3229589
Farrar DB, Crump KS. 1990. Exact statistical tests for any carcinogenic effect in animal bioassays. Fundam Appl Toxicol 15(4):710–721.2086315
Farrar NJ, Smith KEC, Lee RGM, . 2004. Atmospheric emissions of polybrominated diphenyl ethers and other persistent organic pollutants during a major anthropogenic combustion event. Environ Sci Technol 38:1681–1685.15074675
Farrell TJ. 1980. Glass capillary gas chromatography of chlorinated dibenzofurans, chlorinated anisoles, and brominated biphenyls. J Chromatogr Sci 18:10–17.
Fattore E, Filipsson AF, Hanberg A, . 2001. Toxicity of a technical mixture of polybrominated diphenyl ethers following 28 days of oral exposure in male and female rats. Organohalogen Compounds 53:357–361
*Fawkes J, Albro PW, Walters DB, . 1982. Comparison of extraction methods for determination of polybrominated biphenyl residues in animal tissue. Anal Chem 54:1866–1871.6293342
*FDA. 1989. Tolerances for unavoidable poisonous or deleterious substances. Food and Drug Administration. 21 CFR 109.30.
*FDA. 2001. Indirect food additives: Adhesives and components of coatings. Adhesives. Food and Drug Administration. Code of Federal Regulations. 21 CFR 175.105(c)(5). http://www.accessdata.fda.gov. April 11, 2002.
*FEDRIP. 2002. Federal Research in Progress. The Dialog Corporation: Cary, NC.
*FEDRIP. 2003. Federal Research in Progress. The Dialog Corporation: Cary, NC.
*Fehringer NV. 1975a. Determination of polybrominated biphenyl residues in dairy products. J Assoc Off Anal Chem 58(5):978–982.1158841
*Fehringer NV. 1975b. Determination of polybrominated biphenyl residues in dry animal feeds. J Assoc Off Anal Chem 58(6):1206–1210.1194184
Fernlof G, Gadhasson I, Podra K, . 1997. Lack of effects of some individual polybrominated diphenyl ether (PBDE) and polychlorinated biphenyl congeners on human lymphocyte functions in vitro. Toxicol Lett 90(2–3):189–197.9067487
*Filonow AB, Jacobs LW, Mortland MM. 1976. Fate of polybrominated biphenyls (PBBs) in soils. Retention of hexabromobiphenyl in four Michigan soils. J Agric Food Chem 24(6):1201–1204.187635
Fisher DA, Brown RS. 2000. Thyroid physiology in the prenatal period and during childhood. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid. Philadelphia, PA: Lippincott Williams & Wilkins, 959–972.
Focant J-F, Sjodin A, Patterson DG. 2003. Qualitative evaluation of thermal desorption-programmable temperature vaporization-comprehensive two-dimensional gas chromatography-time-of-flight mass spectrometry for the analysis of selected halogenated contaminants. J Chromatogr A 1019(1–2):143–154.14650611
*Fomon SJ. 1966. Body composition of the infant: Part I: The male “reference infant”. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
*Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Foureman P, Mason JM, Valencia R, . 1994. Chemical mutagenesis testing in Drosophila. X. Results of 70 coded chemicals tested for the National Toxicology Program. Environ Mol Mutagen 23(3):208–227.8162896
Fowles JR, Fairbrother A, Baecher-Steppan L, . 1994. Immunologic and endocrine effects of the flame-retardant pentabromodiphenyl ether (DE-71) in C57BL/6J mice. Toxicology 86(1–2):49–61.8134923
*Fraker PJ. 1980. The antibody-mediated and delayed type hypersensitivity response of mice exposed to polybrominated biphenyls. Toxicol Appl Pharmacol 53:1–7.6247784
*Fraker PJ, Aust SD. 1978. The effect of polybrominated biphenyls on the immune response of BALB/c mice. In: Asher IM, ed. Inadvertent modifications of the immune response: The effect of foods, drugs, and environmental contaminants. Proceedings of the 4^th^ FDA Science Symposium. HHS Publication no. (FDA) 80-1074, 270–271.
Francis BM. 1989. Relative developmental toxicities of nine diphenyl ethers related to nitrofen. Environ Toxicol Chem 8(8):681–688.
Francis BM, Metcalf RL. 1984. Structure activity relationships in diphenyl ether teratogenicity. Teratology 29:29A.6701805
Freeman PK, Jang J-S, Haugen CM. 1996. The photochemistry of polyhaloarenes. XIII. The photohydrodehalogenation of 3,4-dibromobiphenyl. Tetrahedron 52(25):8397–8406.
*Fries GF. 1985a. Bioavailability of soil-borne polybrominated biphenyls ingested by farm animals. J Toxicol Environ Health 16:565–579.3003374
*Fries GF. 1985b. The PBB episode in Michigan: An overall appraisal. CRC Crit Rev Toxicol 16:105–156.
*Fries GF, Jacobs IW. 1980. Residual polybrominated biphenyl contamination: Locations, amounts and significance on dairy farms. J Dairy Sci 63:114.
Fu X, Schmitz FJ. 1999. New brominated diphenyl ether from an unidentified species of Dysidea sponge. 13C NMR data for some brominated diphenyl ethers. J Nat Prod 59(1):1102–1103.
Fu X, Schmitz FJ, Govindan M, . 1995. Enzyme inhibitors: New and known polybrominated phenols and diphenyl ethers from four Indo-Pacific Dysidea sponges. J Nat Prod 58(9):1384–1391.7494145
Gallet G, Perez G, Karlsson S. 2001. Two approaches for extraction and analysis of brominated flame retardants (BFR) and their degradation products in recycled polymers and BFR containing water. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 177–179.
*Galloway SM, Armstrong MJ, Reuben C, . 1987. Chromosome aberrations and sister chromatid exchanges in Chinese hamster ovary cells: Evaluations of 108 chemicals. Environ Mol Mutagen 10:1–175.3319609
*Gardner AM, Righter HF, Roach JAG. 1976. Excretion of hydroxylated polychlorinated biphenyl metabolites in cow’s milk. J Assoc Off Anal Chem 59(2):273–277.815234
*Gardner AM, Warren VL, Chen JT, . 1979. A metabolite of polybrominated biphenyls: Its identification and decomposition to a brominated dibenzofuran in the gas chromatograph-mass spectrometer. J Agric Food Chem 27(1):116–119.216714
Gause EM, Ross DH, Hamilton MG, . 1979. Correlation of systemic and biochemical effects of PBB with behavioral effects. Neurobehav Toxicol 1:269–274.233318
*Geller I, Gause EM, Leal BZ, . 1985. Behavioral effects of drugs as a function of maternal polybrominated biphenyl body burden. Toxicol Lett 24:229–234.2984808
*Geller I, Hartman RJ, Garcia C, . 1979. Effects of polybrominated biphenyl on a discrimination. Neurobehav Toxicol 1:263–267.233317
Gerlienke SA, Legger FF, Van Meeteren ME, . 1998. In vitro inhibition of thyroid hormone sulfation by hydroxylated metabolites of halogenated aromatic hydrocarbons. Chem Res Toxicol 11(9):1075–1081.9760282
*Getty SM, Rickert DE, Trapp AL. 1977. Polybrominated biphenyl (PBB) toxicosis: An environmental accident. CRC Crit Rev Environ Control 7:309–323.
*Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Glatt H, Anklam E, Robertson LW. 1992. Biphenyl and fluorinated derivatives: Liver enzyme-mediated mutagenicity detected in Salmonella typhimurium and Chinese hamster V79 cells. Mutat Res 281(3):151–156.1371835
*Glinoer D, De Nayer P, Bourdoux P, . 1990. Regulation of maternal thyroid during pregnancy. J Clin Endocrinol Metab 71:276–287.2116437
*Gobas FAPC, Clark KE, Shiu WY, . 1989. Bioconcentration of polybrominated benzenes and biphenyls and related superhydrophobic chemicals in fish: Elimination into the feces. Environ Toxicol Chem 8:231–245.
*Goldstein JA, Safe S. 1989. Mechanism of action and structure-activity relationships for the chlorinated dibenzo-p-dioxins and related compounds. In: Kimbrough RD, Jenson A, eds. Halogenated biphenyls, terphenyls, naphthalenes, dibenzodioxins and related products. Amsterdam, NY: Elsevier Science Publishers, 239–293.
*Goldstein JA, Linko PC, Levy LA, . 1979. A comparison of a commercial polybrominated biphenyl mixture, 2,4,5,2’,4’,5’-hexabromobiphenyl and 2,3,6,7-tetrabromonaphthalene as inducers of liver microsomal drug-metabolizing enzymes. Biochem Pharmacol 28:2947–2956.229864
Golub MS, Chernoff GF. 1994. Issues in regulatory protection of reproductive health in the workplace. Occup Med 9(3):373–386.7831587
Gouin T, Thomas GO, Cousins I, . 2002. Air-surface exchange of polybrominated diphenyl ethers and polychlorinated biphenyls. Environ Sci Technol 36:1426–1434.11999047
Great Lakes Chemical Corporation. 1978. Octabromodiphenyl ether. Subacute inhalation toxicity study in rats. International Research and Development Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0522293.
Great Lakes Chemical Corporation. 1984. 90-Day dietary study in rats with pentabromodiphenyl oxide (DE-71) (Final Report). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0524336.
Great Lakes Chemical Corporation. 2000. A 90-day inhalation toxicity study of octabromodiphenyl oxide in albino rats, dated 04/04/02. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0574171-1.
Great Lakes Chemical Corporation. 2001a. Initial submission: Letter from Great Lakes Chemical Corporation to U.S. EPA summarizing 90-day inhalation toxicity study of octabromodiphenyl oxide in albino rats, dated 05/25/01. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0574171.
Great Lakes Chemical Corporation. 2001b. Support: Letter from Great Lakes Chemical Corporation to U.S. EPA summarizing 90-day inhalation toxicity study of octabromodiphenyl oxide in albino rats, dated 05/25/01. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0574171-1. [unpublished study]
Great Lakes Chemical Corporation. 2004a. Technical information sheets for DE-60F special, DE-61, DE-62, and DE-71. http://www.el.greatlakes.com. February 17, 2004.
Great Lakes Chemical Corporation. 2004b. Technical information sheet for DE-79. http://www.el.greatlakes.com. February 17, 2004.
*Great Lakes Water Quality Board. 1983. An inventory of chemical substances identified in the Great Lakes ecosystem: Vol. 2: Windsor, Ontario, Canada, 19, 26, 28.
*Great Lakes Water Quality Board. 1989. Report on the Great Lakes water quality: Appendix B-Great Lake surveillance, Vol. 1, 2.3-9–2.3-11.
*Greaves J, Roboz J, Holland JF, . 1984. Determination of the binding of polybrominated biphenyls to serum proteins by negative chemical ionization mass spectrometry. Chemosphere 13(5/6):651–656.
*Griffin RA, Chou SFJ. 1981a. Attenuation of polybrominated biphenyls and hexachlorobenzene by earth materials. Cincinnati, OH: EPA600281191, 25–27.
*Griffin RA, Chou FJ. 1981b. Movement of PCBs and other persistent compounds through soil. Water Sci Technol 13:1153–1163.
*Groce DF, Kimbrough RD. 1984. Stunted growth, increased mortality, and liver tumors of polybrominated biphenyl (PBB) dosed Sherman rats. J Toxicol Environ Health 14:695–706.6097695
*Gupta BN, Moore JA. 1979. Toxicologic assessments of a commercial polybrominated biphenyl mixture in the rat. Am J Vet Res 40(10):1458–1468.230756
Gupta BN, McConnell EE, Goldstein JA, . 1983a. Effects of polybrominated biphenyl mixture in the rat and mouse. Toxicol Appl Pharmacol 68:1–18.6302948
*Gupta BN, McConnell EE, Harris MW, . 1981. Polybrominated biphenyl toxicosis in the rat and mouse. Toxicol Appl Pharmacol 57:99–118.6163229
Gupta BN, McConnell EE, Moore JA, . 1983b. Effects of a polybrominated biphenyl mixture in the rat and mouse. Toxicol Appl Pharmacol 68:19–35.6302950
Gustafsson K, Bjork M, Burreau S, . 1999. Bioaccumulation kinetic of brominated flame retardants (polybrominated diphenyl ethers) in blue mussels (Mytilus edulis). Environ Toxicol Chem 18(6):1218–1224.
Guvenius DM, Noren K. 2000. Multicomponent analysis of organochlorine and organobromine contaminants in human milk, blood plasma, liver and adipose tissue. Organohalogen Compounds 45:45–48.
*Guzelian PS. 1985. Clinical evaluation of liver structure and function in human exposed to halogenated hydrocarbons. Environ Health Perspect 60:159–164.2411535
*Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
*Haake JM, Merrill JC, Safe S. 1985. The in vitro metabolism of benzo[a]pyrene by polychlorinated and polybrominated biphenyl induced rat hepatic microsomal monooxygenases. Can J Physiol Pharmacol 63:1096–1100.2996731
Hackenberg R, Looser R, Froescheis O, . 2002. Trends of POPs in biota of the Atlantic Ocean - samples of 1981/82 reanalyzed and characterized with GC/ECD, GC/EI-MSD and GC/NCI-MSD. Organohalogen Compounds 56:495–498.
Haddad S, Poulin P, Krishnan K. 2000. Relative lipid content as the sole mechanistic determinant of the adipose tissue:blood partition coefficients of highly lipophilic organic chemicals. Chemosphere 40(8):839–843.10718576
Hagenmaier H, She J, Benz T, . 1992. Analysis of sewage sludge for polyhalogenated dibenzo-p-dioxins, dibenzofurans, and diphenylethers. Chemosphere 25(1–10):1457–1462.
Haglund PS, Zook DR, Buser H-R, . 1997. Identification and quantification of polybrominated ethers and methoxy-polybrominated diphenyl ethers in Baltic biota. Environ Sci Technol 31:3281–3287.
Hagmar L, Bergman A. 2001. Human exposure to BFRs in Europe. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 107–111.
Hagmar L, Bjork J, Sjodin A, . 2001. Plasma levels of persistent organohalogens and hormone levels in adult male humans. Arch Environ Health 56(2):138–143.11339677
Hagmar L, Jakobsson K, Thuresson K, . 2000a. Computer technicians are occupationally exposed to polybrominated diphenyl ethers and tetrabromobisphenol A. Organohalogen Compounds 47:202–205.
Hagmar L, Sjodin A, Hoglund P, . 2000b. Biological half-lives of polybrominated diphenyl ethers and tetrabromobisphenol A in exposed workers. Organohalogen Compounds 47:198–201.
Hairstom DW. 1995. CRC alternatives: A cold war. Chem Eng (NY) 102:65–66.
Hakk H, Letcher RJ. 2003. Metabolism in the toxicokinetics and fate of brominated flame retardants - a review. Environ Int 29:801–828.12850098
Hakk H, Huwe J, Lorentzsen M. 2001. A mass balance study of a commercial pentabromodiphenyl ether mixture in male Sprague-Dawley rats. Organohalogen Compounds 52:5–8.
Hakk H, Larsen G, Bergman A, . 2000. Metabolism, excretion and distribution of the flame retardant tetrabromobisphenol-A in conventional and bile-duct cannulated rats. Xenobiotica 30(9):881–890.11055266
Hakk H, Larsen G, Klasson-Wehler E, . 1999. Tissue disposition, excretion, and metabolism of 2,2’, 4,4,’5-pentabromodiphenyl ether (BDE-99) in male Sprague-Dawley rats. Organohalogen Compounds 40:337–340.
Hakk H, Larsen G, Klasson-Wehler E. 2002. Tissue disposition, excretion and metabolism of 2,2’,4,4’5-pentabromodiphenyl ether (BDE-99) in the male Sprague-Dawley rat. Xenobiotica 32(5):369–382.12065060
Hakk H, Larsen GL, Orn U, . 2000. Association of decabromodiphenyl ether with urinary and biliary carrier proteins. Organohalogen Compounds 49:108–111.
Halbert F, Halbert S. 1978. Bitter harvest. Grand Rapids, Michigan: William B. Erdmans Publishing company.
Hale RC, Alaee M, Manchester-Neesvig JB, . 2003. Polybrominated diphenyl ether flame retardants in the North American environment. Environ Int 29:771–779.12850095
Hale RC, La Guardia MJ, Harvey EP, . 2000. Comparison of brominated diphenyl ether fire retardant and organochlorine burdens in fish from Virginia (USA). Organohalogen Compounds 47:65–68.
Hale RC, La Guardia MJ, Harvey EP, . 2001a. Brominated diphenyl ethers in land-spoiled sewage sludges in the US. BFR:149–152.
Hale RC, La Guardia MJ, Harvey EP, . 2001b. Polybrominated diphenyl ether flame retardants in Virginia freshwater fishes (USA). Environ Sci Technol 35(23):4585–4591.11770759
Hale RC, La Guardia MJ, Harvey EP, . 2002. Potential role of fire retardant-treated polyurethane foam as a source of brominated diphenyl ethers to the US environment. Chemosphere 46(5):729–735.11999796
Hallgren S, Darnerud P. 1998. Effects of polybrominated diphenyl ethers (PBDEs), polychlorinated biphenyls (PCBs) and chlorinated paraffins (CPs) on thyroid hormone levels and enzyme activities in rats. Organohalogen Compounds 35:391–394.
Hallgren S, Sinjari T, Hakansson H, . 2001. Effects of polybrominated diphenyl ethers (PBDEs) and polychlorinated biphenyls (PCBs) on thyroid hormone and vitamin A levels in rats and mice. Arch Toxicol 75(4):200–208.11482517
*Halvorson MR, Phillips TD, Safe SH, . 1985. Metabolism of aflatoxin B1 by rat hepatic microsomes induced by polyhalogenated biphenyl congeners. Appl Environ Microbiol 49(4):882–886.2988440
Hamm S, Strikkeling M, Ranken PF, . 2001. Determination of polybrominated diphenyl ethers and PBDD/Fs during the recycling of high impact polystyrene containing decabromodiphenyl ether and antimony oxide. Chemosphere 44(6):1353–1360.11513112
Hanigan MH, Winkler ML, Drinkwater NR. 1993. Induction of three histochemically distinct populations of hepatic foci in C57BL/6J mice. Carcinogenesis 14(5):1035–1040.8099313
Hardell L, Lindstom G, van Bavel B, . 1998. Concentrations of the flame retardant 2,2’,4,4’-tetrabrominated diphenyl ether in human adipose tissue in Swedish persons and the risk for non-Hodgkin’s lymphoma. Oncol Res 10(8):429–432.10100760
Hardy ML. 1999. Regulatory status and environmental properties of brominated flame retardants undergoing risk assessment in the EU: DBDPO, OBDPO, PEBDPO and HBCD. Polym Degrad Stab 64(3):545–556.
*Hardy ML. 2000a. Properties of the major commercial PBDPO flame retardant, DBDPO, in comparison to PBB and PCB. Organohalogen Compounds 47:233–236.
Hardy ML. 2000b. The toxicity of the commercial polybrominated diphenyl oxide flame retardants: DBDPO, OBDPO, PeBDPO. Organohalogen Compounds 47:41–44.
Hardy ML. 2001. Assessment of reported decabromodiphenyl oxide blood and air levels in Swedish workers and their workplace. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 121–124.
*Hardy ML. 2002a. A comparison of the properties of the major commercial PBDPO/PBDE product to those of major PBB and PCB products. Chemosphere 45(5):717–728.
Hardy ML. 2002b. The toxicology of the three commercial polybrominated diphenyl oxide (ether) flame retardants. Chemosphere 46(5):757–777.11999799
Hardy M, Biesemeier J, Manor O. 2001. Results of a prenatal developmental toxicity study of decabromodiphenyl oxide in rats. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 253–257.
Hardy ML, Schroeder R, Biesemeier J, . 2002. Prenatal oral (gavage) developmental toxicity study of decabromodiphenyl oxide in rats. Int J Toxicol 21:83–91 12022634
Harju M, Andersson, PL, Haglund P, . 2002. Multivariate physiochemical characterization and quantitative structure-property relationship modelling of polybrominated diphenyl ethers. Chemosphere 47:375–384.11999613
Harner T. 2001. Measurements of octanol-air partition coefficients (KOA) for polybrominated diphenyl ethers (PBDEs): Predicting partitioning in the environment. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 55–58.
Harner T, Shoeib M. 2002. Measurements of octanol-air partition coefficients (KOA) for polybrominated diphenyl ethers (PBDEs): Predicting partitioning in the environment. J Chem Eng Data 47(2):228–232.
Harner T, Ikonomou M, Shieb M, . 2002. Passive air sampling results for polybrominated diphenyl ethers along an urban-rural transect. Organohalogen Compounds 57:33–36.
Harrad S, Wijesekera R, Hunter S, . 2004. Preliminary assessment of U.K. human dietary and inhalation exposure to polybrominated diphenyl ethers. Environ Sci Technol 38:2345–2350.15116839
Harris SJ, Cecil HC, Bitman J. 1978a. Effects of feeding a polybrominated biphenyl flame retardant (FireMasterBP-6) to male rats. Bull Environ Contam Toxicol 19:692–696.209841
*Harris SJ, Cecil HC, Bitman J. 1978b. Embryotoxic effects of polybrominated biphenyls (PBB) in rats. Environ Health 23:295–300.
Hartonen K, Bowadt S, Hawthorne SB, . 1997. Supercritical fluid extraction with solid-phase trapping of chlorinated and brominated pollutants from sediment samples. J Chromatogr A 774(1–2):229–242.
*Hass JR, McConnell EE, Harvan DJ. 1978. Chemical and toxicologic evaluation of Firemaster BP-6. J Agric Food Chem 26:94–99.202620
Haung Q, Rusling JF. 1995. Formula reduction potentials and redox chemistry of polyhalogenated biphenyls in a bicontinuous microemulsion. Environ Sci Technol 29(1):98–103.22200206
*Haworth S, Lawlor T, Mortelmans K, . 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen 5:3–142.
Hayakawa K, Takatsuki H, Watanabe I, . 2002. Polybrominated diphenyl ethers (PBDEs), polybrominated dioxins/furans (PBDD/Fs) and monobromo-polychlorinated dioxins/furans (MoBPXDD/Fs) in atmospheric and bulk deposition in Kyoto, Japan. Organohalogen Compounds 59:299–302.
*HazDat. 2004. PBBs and PBDEs. Hazardous substance release and health effects database. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/hazdat.html.
*Heinz GH, Erdman TC, Haseltine SD, . 1985. Contaminant levels in colonial waterbirds from Green Bay and Lake Michigan, 1975-80. Environ Monit Assess 5:223–236.24258029
*Heinz GH, Haseltine SD, Reichel WL, . 1983. Relationships of environmental contaminants to reproductive success in red-breasted mergansers [Mergu serrator] from Lake Michigan. Environ Pollut Ser A 32:211–232.
Helleday T, Tuominen KL, Bergman A, . 1999. Brominated flame retardants induce intragenic recombination in mammalian cells. Mutat Res 439(2):137–147.10023042
*Henck JW, Rech RH. 1986. Effect of perinatal polybrominated biphenyl exposure on acquisition and performance of an autoshaping paradigm. Neurotoxicology 7(2):651–664.3024082
*Henck JW, Mattson JL, Rezabek DH, . 1994. Development neurotoxicity of polybrominated biphenyls. Neurotoxicol Teratol 16(4):391–399.7968941
*Henderson AK, Rosen D, Miller GL, . 1995. Breast cancer among women exposed to polybrominated biphenyls. Epidemiology 6(5):544–546.8562633
Henry B, Grant SG, Klopman G, . 1998. Induction of forward mutations at the thymidine kinase locus of mouse lymphoma cells: Evidence for electrophilic and non-electrophilic mechanisms. Mutat Res 397(2):313–335.9541657
*Hesse JL, Powers RA. 1978. Polybrominated biphenyl (PBB) contamination of the Pine River, Gratiot, and Midland counties, Michigan. Environ Health Perspect 23:19–25.209975
*Hill RH. 1985. Effects of polyhalogenated aromatic compounds on porphyrin metabolism. Environ Health Perspect 60:139–143.4029097
*Hill RH, Patterson DG, Orti DL, . 1982. Evidence of degradation of polybrominated biphenyls in soil samples from Michigan. J Environ Sci Health B 17(1):19–33.6279720
Hillery BR, Basu I, Sweet CW, . 1997. Temporal and spatial trends in a long-term study of gas-phase PCB concentrations near the Great Lakes. Environ Sci Technol 31:1811–1816.
Hirai T, Fortutani H, Myouren M, . 2002. Concentration of polybrominated diphenyl ethers (PBDEs) in the human bile in relation to those in the liver and blood. Organohalogen Compounds 58:277–280.
Hites RA. 2004. Polybrominated diphenyl ethers in the environment and in people: A meta-analysis of concentrations. Environ Sci Technol 38(4):945–956.14998004
*Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
Hoel DG, Haseman JK, Hogan MD, . 1988. The impact of toxicity on carcinogenicity studies: Implications for risk assessment. Carcinogenesis 9(11):2045–2052.3052903
Holladay SD. 1999. Prenatal immunotoxicant exposure and postnatal autoimmune disease. Environ Health Perspect Suppl 107:687–691.
Holladay SD, Smialowicz RJ. 2000. Development of the murine and human immune system: Differential effects of immunotoxicants depend on time of exposure. Environ Health Perspect Suppl 108:463–473.
*Hollowell G, Norman W, Staehling W, . 1998. Iodine nutrition in the United States. Trends and public health implications: Iodine excretion data from national health and nutrition examination surveys I and III (1971-1974 and 1988-1994). J Clin Endocrinol Metab 83(10):3401–3408.9768638
Hooper H, McDonald TA. 2000. The PBDEs: An emerging environmental challenge and another reason for breast-milk monitoring programs. Environ Health Perspect 108(5):387–392.10811563
Hooper K, She J. 2003. Lessons from the polybrominated diphenyl ethers (PBDEs): Precautionary principle, primary prevention, and the value of community-based body-burden monitoring using breast milk. Environ Health Perspect 111(1):109–114.12515688
*Hoque A, Sigurdson AJ, Burau KD, . 1998. Cancer among a Michigan cohort exposed to polybrominated biphenyls in 1973. Epidemiology 9(4):373–378.9647899
Hori S, Akutsu K, Kitagawa M, . 2000. Development of analysis for polybrominated diphenyl ether in seafood and actual contamination of seafood. Organohalogen Compounds 47:214–217.
Hori S, Akutsu K, Oda H, . 2002. Development of an analysis method for polybrominated diphenyl ethers and their levels in Japanese human mother’s milk. Organohalogen Compounds 58:245–248.
Hovander L, Bergman A, Jakobsson K. 2001. PBDE levels among personnel employed at an electronics dismantling plant in the Stockholm area. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 295–297.
*Howard SK, Werner PR, Sleight SD. 1980. Polybrominated biphenyl toxicosis in swine: Effects on some aspects of the immune system in lactating sows and their offspring. Toxicol Appl Pharmacol 55:146–153.6252665
Howie L, Dickerson R, Davis D, . 1990. Immunosuppressive and monooxygenase induction activities of polychlorinated diphenyl ether congeners in C57BL/6N mice: Quantitative structure-activity relationships. Toxicol Appl Pharmacol 105:254–263.2120796
*HSDB. 2002. Hazardous Substances Data Bank. http://toxnet.nlm.nih.gov/cgi-bin/sis/search. April 18, 2002.
Hua I, Kang N, Jafvert CT, . 2003. Heterogeneous photochemical reactions of decabromodiphenyl ether. Environ Toxicol Chem 22:798–804.12685715
Huber S, Ballschmiter K. 2001. Characterization of five technical mixtures of brominated flame retardants. Fresenius J Anal Chem 371(6):882–890.11768481
Hughs MF, Edwards BC, Mitchell CT, . 2001. In vitro dermal absorption of flame retardant chemicals. Food Chem Toxicol 39(12):1263–1270.11696400
*Humble CG, Speizer FE. 1984. Polybrominated biphenyls and fetal mortality in Michigan. Am J Public Health 74(10):1130–1132.6433729
*Humphrey HE, Hayner NS. 1975. Polybrominated biphenyls: An agricultural incident and its consequences. II. An epidemiological investigation of human exposure. In: Proceedings of the 9^th^ Trace Substances in Environmental Health Annual Conference, Columbia, MO, April 12-23, 1975. University of Missouri, Columbia, MO, 57–63.
Huwe JK, Hakk H, Lorentzsen M. 2002b. A mass balance feeding study of a commercial octabromodiphenyl ether mixture in rats. Organohalogen Compounds 58:229–223.
Huwe JK, Lorentzsen M, Thuresson K, . 2002a. Analysis of mono- to deca-brominated diphenyl ethers in chickens at the part per billion level. Chemosphere 46:635–640.11999786
*IARC. 1978. IARC monographs on the evaluation of carcinogenic risks humans. Vol. 18: Polychlorinated biphenyls and polybrominated biphenyls. World Health Organization, Lyon, France, 108–125.
*IARC. 1986. IARC monographs of the evaluation of carcinogenic risks humans. Vol. 41: Some halogenated hydrocarbons and pesticide exposures. World Health Organization, Lyon, France, 261–292.
*IARC. 1987. IARC monographs on the evaluation of carcinogenic risks to humans. Vol. 1-42: Polybrominated biphenyls (Group 2B) overall evaluations of carcinogenicity: An updating of IARC monographs. World Health Organization, Lyon, France, 321–322.
IARC. 1990. IARC Monographs on the evaluation of carcinogenic risks to humans. Vol. 48: Decabromodiphenyl oxide. World Health Organization, Lyon, France, 73–84.
Ikonomou MG, Rayne S. 2002. Chromatographic and ionization properties of polybrominated diphenyl ethers using GC/high-resolution MS with metastable atom bombardment and electron impact ionization. Anal Chem 74:5263–5272.12403580
Ikonomou MG, Crewe N, He T, . 1999. Polybrominated-diphenyl-ether in biota samples from coastal British Columbia, Canada. Organohalogen Compounds 40:341–345.
Ikonomou MG, Fischer M, Antcliffe B, . 2001. PBDEs on the rise: As reflected by aquatic species from British Columbia and the Arctic. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 325–328.
Ikonomou MG, Fisher M, He T, . 2000. Congener patterns, spatial and temporal trends of polybrominated diphenyl ethers in biota samples from the Canadian west coast and the Northwest Territories. Organohalogen Compounds 47:77–80.
Ikonomou MG, Rayne S, Addison RF. 2002a. Exponential increases of the brominated flame retardants, polybrominated diphenyl ethers, in the Canadian Arctic from 1981 to 2000. Environ Sci Technol 36:1886–1892.12026966
Ikonomou MG, Rayne S, Fischer M, . 2002b. Occurrence and congener profiles of polybrominated diphenyl ethers (PBDEs) in environmental samples from coastal British Columbia, Canada. Chemosphere 46(5):649–663.11999788
*Imamura M, Tung TC. 1984. A trial of fasting cure for PCB-poisoned patients in Taiwan. Am J Ind Med 5:147–153.6422746
IRDC. 1974. Decabromodiphenyl ether. Acute toxicity studies in rats and rabbits. International Research and Development Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0523319.
IRDC. 1975a. Octabromodiphenyl ether. Acute toxicity studies in rats and rabbits. International Research and Development Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS052222968.
IRDC. 1975b. Pentabromodiphenyl ether. Acute toxicity studies in rats and rabbits. International Research and Development Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0522286.
IRDC. 1976. Decabromodiphenyl ether and octabromodiphenyl ether. A twenty-eight day toxicity study in rats. International Research and Development Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0523322.
IRDC. 1977. Octabromodiphenyl ether. Thirteen week feeding study in rats. International Research and Development Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0522297.
IRIS. 2002. Integrated Risk Information System. http://www.epa.gov/iris. April 18, 2002.
IRIS. 2004. Integrated Risk Information System. http://www.epa.gov/iris. September 01, 2004.
Jackson MA, Stack HF, Waters MD. 1993. The genetic toxicology of putative nongenotoxic carcinogens. Mutat Res 296(3):241–277.7680106
*Jackson TF, Halbert FL. 1974. A toxic syndrome associated with the feeding of polybrominated biphenyl-contaminated protein concentrate to dairy cattle. J Am Vet Med Assoc 165:437–439.4425399
*Jacobs LW, Chou SF, Tiedje JM. 1976. Fate of polybrominated biphenyls (PBBs) in soils: Persistence and plant uptake. J Agric Food Chem 24:1198–1201.187634
*Jacobs LW, Chou SF, Tiedje JM. 1978. Field concentrations and persistence of polybrominated biphenyls in soils and solubility of PBB in natural waters. Environ Health Perspect 23:1–8.209960
Jacobs MN, Lewis DFV. 1999. A QSAR study of organochlorine and isoflavenoid compounds ligand binding affinity to the human oestrgen receptor α. Organohalogen Compounds 41:517–520.
*Jacobson JL, Fein GG, Jacobson SW, . 1984. The transfer of polychlorinated biphenyls (PCBs) and polybrominated biphenyls (PBBs) across the human placenta and into maternal milk. Am J Public Health 74(4):378–379.6322600
Jacobson JL, Humphrey HEB, Jacobson SW, . 1989. Determinants of polychlorinated biphenyls (PCBs), polybrominated biphenyls (PBBs), and dichlorodiphenyl trichloroethane (DDT) levels in the sera of young children. Am J Public Health 79:1401–1404.2551196
*Jaffe R, Stemmler EA, Eitzer BD, . 1985. Anthropogenic, polyhalogenated, organic compounds in sedentary fish from Lake Huron and Lake Superior tributaries and embayments. J Great Lakes Res 11(2):156–162.
Jakobsson K, Thuresson K, Rylander L, . 2002. Exposure to polybrominated diphenyl ethers and tetrabromobisphenol A among computer technicians. Chemosphere 46(5):709–716.11999794
*Jansson B, Asplund L, Olsson M. 1987. Brominated flame retardants-ubiquitous environmental pollutants? Chemosphere 16(10–12):2343–2349.
Jansson B, Andersson R, Asplund L, . 1991. Multiresidue method for the gas-chromatographic analysis of some polychlorinated and polybrominated pollutants in biological samples. Fresenius Z Anal Chem 340:439–445.
Jansson B, Andersson R, Asplund L, . 1993. Chlorinated and brominated persistent organic compounds in biological samples from the environment. Environ Toxicol Chem 12(7):1163–1174.
Jaret P. 2000. Health concerns: Defense systems under fire. Natl Wildl 38(6):36–41.
Jaward FM, Meijer SN, Steinnes E, . 2004. Further studies on the latitudinal and temporal trends of persistent organic pollutants in Norwegian and U.K. background air. Environ Sci Technol 38:2523–2530.15180046
*Jensen RK, Sleight S. 1986. Sequential study on the synergistic effects of 2,2’,4,4’,5,5’-hexa-bromobiphenyl and 3,3’,4,4’,5,5’-hexabromobiphenyl on hepatic tumor promotion. Carcinogenesis 7:1771–1774.2875811
Jensen RK, Zile MH. 1988. Effect of dietary retinoic acid on circulatory vitamin A homeostasis in polybrominated biphenyl-treated rats. J Nutr 118:416–419.2832570
*Jensen RK, Sleight SD, Aust SD, . 1983. Hepatic tumor-promoting ability of 3,3’,4,4’,5,5’-hexabromobiphenyl: The interrelationships between toxicity, induction of hepatic microsomal drug metabolizing enzymes, and tumor-promoting ability. Toxicol Appl Pharmacol 71:163–176.6314605
*Jensen RK, Sleight SD, Aust SD. 1984. Effect of varying the length of exposure to polybrominated biphenyls on the development of gamma-glutamyl transpeptidase enzyme-altered foci. Carcinogenesis 5:63–66.6140088
*Jensen RK, Sleight SD, Goodman JI, . 1982. Polybrominated biphenyls as promoters in experimental hepatocarcinogenesis in rats. Carcinogenesis 3:1183–1186.6129071
*Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs. cerebral cortex. Brain Res 190:3–16.6769537
*Johansson M, Larsson C, Bergman A, . 1998. Structure-activity relationship for inhibition of CYP11B1-dependent glucocorticoid synthesis in Y1 cells by aryl methyl sulfones. Pharmacol Toxicol (Amsterdam) 83:225–230.
Johnson A, Olson N. 2001. Analysis and occurrence of polybrominated diphenyl ethers in Washington state freshwater fish. Arch Environ Contam Toxicol 41(3):339–344.11503071
Johnston CA, Demarest KT, McCormack KM, . 1980. Endocrinological, neurochemical, and anabolic effects of polybrominated biphenyls in male and female rats. Toxicol Appl Pharmacol 56:240–247.6258268
Jones KC, Alcock RE, Kalantzi OI, . 2001. Environmental measurements and the global distribution of PBDEs. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 163–166.
Juchau MR. 1993. Chemical teratogenesis. Prog Drug Res 41:9–50.8108564
Kaiser R, Marcus M, Blanck HM, . 2003. Polybrominated biphenyl exposure and benign breast disease in a cohort of US women. Ann Epidemiol 13(1):1–23.12547479
Kaiser R, Marcus M, Michels Blanck H, . 2001. PBB exposure and benign breast disease in a cohort of U.S. women. Am J Epidemiol 153:S266.
*Kaiser TE, Reichel WL, Locke LN, . 1980. Organochloride pesticide, PCB, and PBB residues and necropsy data for bald eagles from 29 states-1975-77. Pestic Monit J 13(4):145–149.6247694
*Kang K-S, Wilson MR, Hayashi T, . 1996. Inhibition of gap junction intercellular communication in normal human breast epithelial cells after treatment with pesticides, PCBs, and PBBs, alone or in mixtures. Environ Health Perspect 104(2):192–200.8820588
*Kasza L, Collins WT, Capen CC, . 1978a. Comparative toxicity of polychlorinated biphenyl and polybrominated biphenyl in the rat thyroid gland: Light and electron microscope alterations after subacute dietary exposure. J Environ Pathol Toxicol 1:587–599.214505
Kasza L, Weinberger MA, Hinton DE, . 1978b. Comparative toxicity of polychlorinated biphenyl and polybrominated biphenyl in the rat liver: Light and electron microscopic alterations after subacute dietary exposure. J Environ Pathol Toxicol 1:241–257.214504
*Kateley JR, Insalaco R, Codere S, . 1982. Host defense systems in cattle exposed to polybrominated biphenyl. Am J Vet Res 43(7):1288–1295.6285777
Kato Y, Haragughi K, Yumoto S, . 2002. Metabolite of 2,2’4’,5-tetrabromobiphenyl 3-methylsulphonyl-2,2’4’,5-tetrabromobiphenyl, a potent inducer of CYP2B1/2 in rat. Xenobiotica 32(4):289–303.12028663
Kato Y, Yumoto S, Nagano Y, . 2000. 3-Methylsulfonyl-2,2’,4’,5-tetrabromobiphenyl, a metabolite of 2,2’,4’,5-tetrabromodiphenyl induces CYP2B1/2 in rats. Organohalogen Compounds 49:209–212.
*Kavanagh TJ, Rubinstein C, Liu PL, . 1985. Failure to induce mutations in Chinese hamster V79 cells and WB rat liver cells by polybrominated biphenyls, Firemaster BP-6, 2,2’,4,4’,5,5’-hexa-bromobiphenyl, 3,3’,4,4’,5,5’-hexabromobiphenyl, and 3,3’,4,4’-tetrabromobiphenyl. Toxicol Appl Pharmacol 79:91–98.2996176
Kawakami I, Sase E, Yagi Y, . 2000. Dioxin-like compounds from an incineration plant of normal municipal solid waste. Organohalogen Compounds 46:197–200.
*Kawasaki M. 1980. Experiences with the test scheme under the chemical control law of Japan: An approach to structure-activity correlations. Ecotoxicol Environ Saf 4:444–454.7472248
*Kay K. 1977. Polybrominated biphenyls (PBB) environmental contamination in Michigan, 1973-1976. Environ Res 13:74–93.191251
Kester MHA, Bulduk S, van Toor H, . 2002. Potent inhibition of estrogen sulfotransferase by hydroxylated metabolites of polyhalogenated aromatic hydrocarbons reveals alternative mechanism for estrogenic activity of endocrine disrupter. J Clin Endocrinol Metab 87(3):1142–1150.11889178
Kholkute SD, Rodriguez J, Dukelow WR. 1994. The effects of polybrominated biphenyls and perchlorinated terphenyls on in vitro fertilization in the mouse. Arch Environ Contam Toxicol 26(2):208–211.8311512
Kierkegaard A, Balk L, Tiarnlund U, . 1999a. Dietary uptake and biological effects on decabromodiphenyl ether in rainbow trout (Oncorhynchus mykiss). Environ Sci Technol 33:1612–1617.
Kierkegaard A, Sellstrom U, Bignert A, . 1999b. Temporal trends of a polybrominated diphenyl ether (PBDE), a methoxylated OBDE, and hexabromocyclododecane (HBCD) in Swedish biota. Organohalogen Compounds 40:367–370.
Kim TS, Shin SK, Hwang SR, . 2002. Method for the analysis of polybrominated biphenyls (PBBs) in environmental samples. Organohalogen Compounds 55:81–84.
*Kimbrough RD. 1987. Human health effects of polychlorinated biphenyls (PCBs) and polybrominated biphenyls (PBBs). Annu Rev Pharmacol Toxicol 27:87–111.3034142
*Kimbrough R, Buckley J, Fishbein L, . 1978a. Animal toxicology. Environ Health Perspect 24:173–184.17539145
*Kimbrough RD, Burse VW, Liddle JA. 1978b. Persistent liver lesions in rats after a single oral dose of polybrominated biphenyls (FireMaster FF-1) and contaminant PBB tissue levels. Environ Health Perspect 23:265–273.209985
*Kimbrough RD, Groce DF, Korver MP, . 1981. Induction of liver tumors in female Sherman strain rats by polybrominated biphenyls. J Natl Cancer Inst 66(3):535–542.6259400
*Kimbrough RD, Korver MP, Burse VW, . 1980. The effect of different diets or mineral oil on liver pathology and polybrominated biphenyl concentration in tissues. Toxicol Appl Pharmacol 52:442–453.6245483
Kitchin KT, Brown JL. 1994. Dose-response relationship for rat liver DNA damage caused by 49 rodent carcinogens. Toxicology 88:31–49.8160204
Kitchin KT, Brown JL, Kulkarni AP, . 1993. Predicting rodent carcinogenicity of halogenated hydrocarbons by in vivo biochemical parameters. Teratog Carcinog Mutagen 13(4):167–184.7903485
Klamer HJC, Leonards EG, Bakker JF. 2002. Chemical and toxicological risk assessment of North Sea surface sediments, brominated flame retardants and dioxin-type toxicity. Organohalogen Compounds 59:111–114.
Klasson-Wehler EK, Hovander L, Bergman A. 1997. New organohalogen in human plasma-Identification and quantification. Organohalogen Compounds 33:420–425.
Klasson Wehler E, Morck A, Hakk H. 2001. Metabolism of polybrominated diphenyl ethers in the rat. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 93–97.
*Kluwe WM, Hook JB. 1978. Polybrominated biphenyl-induced potentiation of chloroform toxicity. Toxicol Appl Pharmacol 45:861–869.214900
*Kluwe WM, Herrmann CL, Hook JB. 1979. Effects of dietary polychlorinated biphenyls and polybrominated biphenyls on the renal and hepatic toxicities of several chlorinated hydrocarbon solvents in mice. J Toxicol Environ Health 5:605–615.226724
*Kluwe WM, Hook JB, Berstein J. 1982. Synergistic toxicity of carbon tetrachloride and several aromatic organohalide compounds. Toxicology 23:321–336.6289492
*Kluwe WM, McCormack KM, Hook JB. 1978. Potentiating of hepatic and renal toxicity of various compounds by prior exposure to polybrominated biphenyls. Environ Health Perspect 23:241–246.209982
*Kluwe WM, McNish R, Smithson K, . 1981. Depletion by 1,2-dibromoethane, 1,2-dibromo-3-chloropropane, tris(2,3-dibromopropyl)phosphate, and hexachloro-1,3-butadiene of reduced nonprotein sulfhydryl groups in target and nontarget organs. Biochem Pharmacol 30:2265–2271.6794573
Kociba RJ, Frauson LO, Humiston CG, . 1975. Results of a two-year dietary feeding study with decabromodiphenyl oxide (DBDPO) in rats. J Combust Toxicol 2(4):267–285.
Kodavanti PRS. 2003. Differential effects of polybrominated diphenyl ethers and polychlorinated biphenyls on intracellular signaling in rat neuronal cultures. Organohalogen compounds. Dioxins, 60–65.
Kodavanti PRS, Derr-Yellin E. 2001. Differential effects of polybrominated diphenyl ethers and polychlorinated biphenyls on [3H]arachidonic acid release in rat neural cells. Organohalogen Compounds 53:185–189.
Kodavanti PRS, Derr-Yellin EC. 2002. Differential effects of polybrominated diphenyl ethers and polychlorinated biphenyls on [3H]arachidonic acid release in rat cerebellar granule neurons. Toxicol Sci 68:452–457.
Kodavanti PRS, Ward TR, Derr-Yellin EC, . 1998. Congener-specific distribution of polychlorinated biphenyls in brain regions, blood, liver, and fat of adult rats following repeated exposure to Aroclor 1254. Toxicol Appl Pharmacol 153:199–210.9878591
Kohler M, Zennegg M, Gerecke AC, . 2003. Increasing concentrations of decabromodiphenyl ether (decaBDE) in Swiss sewage sludge since 1993. Organohalogen compounds. Dioxins, 60–65.
*Kohli J, Safe S. 1976. The metabolism of brominated aromatic compounds. Chemosphere 6(6):433–437.
*Kohli J, Wyndham C, Smylie M, . 1978. Metabolism of bromobiphenyls. Biochem Pharmacol 27:1245–1249.212083
*Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
*Kong HL, Sayler GS. 1983. Degradation and total mineralization of monohalogenated biphenyls in natural sediment and mixed bacterial culture. Appl Environ Microbiol 46(3):666–672.6639021
*Kong HL, Sayler GS. 1984. Microbial degradation and mineralization of brominated biphenyls and brominated benzoates. In: Proceedings of the 84^th^ American Society for Microbiology Annual Meeting, St. Louis, MO, March 4-9 [Abstract Q76]. American Society for Microbiology, Washington, DC, 217.
Koss G, Weider T, Seubert S, . 1994. 2,2’ 4,4’,5,5’-Hexabromobiphenyl: Its toxicokinetics, biotransformation and porphyrinogenic action in rats. Food Chem Toxicol 32(7):605–610.8045473
Koster P, Debets FMH, Strik JJTWA. 1980. Porphyrinogenic action of fire retardants. Bull Environ Contam Toxicol 25(2):313–315.7426777
*Kotake AN, Schoeller DA, Lambert GH, . 1982. The caffeine CO_2_ breath test: Dose response and route of N-demethylation in smokers and nonsmokers. Clin Pharmacol Ther 32:261–269.6807598
*Kraus AL, Bernstein IA. 1986. Influence of adipocyte triglyceride on the partition of 2,2’,4,4’,5,5’-hexabromobiphenyl between 3T2L1 adipocytes and surrounding pseudoblood. J Toxicol Environ Health 19:541–554.3023648
*Kreiss K, Roberts C, Humphrey HEB. 1982. Serial PBB levels, PCB levels, and clinical chemistries in Michigan’s PBB cohort. Arch Environ Health 37(3):141–146.6284069
*Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
*Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kristofferson A, Voie AOA, Funnum F. 2002. Ortho-substituted polybrominated biphenyls activate respiratory burst in granulocytes from humans. Toxicol Lett 24(1–2):161–166.
*Krüger, C. (1988) Polybrominated biphenyl and polybrominated diphenyl ethers – detection and quantification in selected foods. Munster, University of Munster (Thesis).
*Ku PK, Hogberg MG, Trapp AL, . 1978. Polybrominated biphenyl (PBB) in the growing pig diet. Environ Health Perspect 23:13–18.209965
*Kubiczak GA, Oesch F, Borlakoglu JT, . 1989. A unique approach to the synthesis of 2,3,4,5-substituted polybrominated biphenyls: Quantitation in FireMaster FF-1 and FireMaster BP-6. J Agric Food Chem 37:1160–1164.
Kucklick JR, Stahl KJ, McFee W, . 2002. Toxaphene and PBDEs in Atlantic white-sided and rough-toothed dolphins. Organohalogen Compounds 58:453–455.
Kuehl DW, Haebler R. 1995. Organochlorine, organobromine, metal and selenium residues in bottlenose dolphins (Tursiops truncatus) collected during an unusual mortality event in the Gulf of Mexico. Arch Environ Contam Toxicol 28(4):494–499.7755403
*Kuehl DW, Haebler R, Potter C. 1991. Chemical residues in dolphins from the U.S. Atlantic coast including Atlantic bottlenose obtained during the 1987/88 mass mortality. Chemosphere 22(11):1071–1984.
*Kuo C-H, Hook JB. 1982. Effects of drug-metabolizing enzyme inducers on cephaloridine toxicity in Fischer 344 rats. Toxicology 24:293–303.6100830
*Kuosmanen K, Hyotylainen T, Hartonen K, . 2002. Pressurized hot water extraction coupled on-line with liquid chromatography-gas chromatography for the determination of brominated flame retardants in sediment samples. J Chromatogr A 943(1):113–122.11820272
Kuroki H, Sakoda S, Nakaoka H, . 2002. Anti-thyroid hormonal activity of the flame retardants, tetrabromobisphenol A and related compounds by a yeast two-hybrid assay. Organohalogen Compounds 56:119–121.
Kuriyama S, Chahoud I. 2003. Maternal exposure to low dose 2,2’,4,4’,5 pentabromo diphenyl ether (PBDE 99) impairs male reproductive performance in adult rat offspring. In: Organohalogen Compounds. Dioxins 2003. Volumes 60–65.
Lacorte S, Guillamon M, Martinez E, . 2003. Occurrence and specific congener profile of 40 polybrominated diphenyl ethers in river and coastal sediments from Portugal. Environ Sci Technol 37:892–898.12666918
Lacorte S, Martinez E, Guillamon M, . 2002. Determination of 40 PBDE in river sediments from Portugal. Organohalogen Compounds 58:175–178.
Ladenson P, Singer P, Ain K, . 2000. American Thyroid Association guidelines for detection of thyroid dysfunction. Arch Intern Med 160:1573–1575.10847249
LaFranchi S. 1999. Congenital hypothyroidism: Etiologies, diagnosis, and management. Thyroid 9(7):735–740.10447022
La Guardia MJ, Hale RC, Harvey E, . 2000. Endocrine disruptors (octylphenol, nonylphenol, nonyl phenol ethoxylates and polybrominated diphenyl ethers) in land applied sewage sludge biosolids. In: Preprints of extended abstracts. American Chemical Society, Division of Environmental Chemistry. 220^th^ ACS National Meeting, Washington, DC. Vol. 40(2):97–99.
LaKind JS, Berlin CM. 2000. PBDEs in breast milk: Where do we go from here? Organohalogen Compounds 47:241–244.
*Lambert GH, Hsu CC, Humphrey H. 1992a. Cytochrome P450IA2 in vivo induction: A potential biomarker of polyhalogenated biphenyls and their related chemical’s effects on the human. Chemosphere 25(1–2):197–200.
*Lambert GH, Schoeller DA, Hsu CC, . 1992b. Cytochrome P4501A2 activity in humans exposed to PCBs and dioxins. Organohalogen Compounds 10:32–35.
*Lambert GH, Schoeller DA, Humphrey HEB, . 1990. The caffeine breath test and caffeine urinary metabolite ratios in the Michigan cohort exposed to polybrominated biphenyls: A preliminary study. Environ Health Perspect 89:175–181.1965165
*Lambrecht LK, Barsotti DA, Allen JR. 1978. Response of nonhuman primates to a polybrominated biphenyl mixture. Environ Health Perspect 23:139–145.209967
Lamesh RA. 1992. Polychlorinated biphenyls: An overview of metabolic toxicologic and health consequences. Vet Hum Toxicol 34:256–260.1609503
*Landrigan PJ, Wilcox KR, Silva J. 1979. Cohort study of Michigan residents exposed to polybrominated biphenyls: Epidemiologic and immunologic findings. Ann NY Acad Sci 320:284–294.222186
Lans MC, Spiertz C, Brouwer A, . 1994. Different competition of thyroxine binding to transthyretin and thyroxine-binding globulin by hydroxy-PCBs, PCDDs and PCDFs. Eur J Pharmacol 270:129–136.8039542
Larrazabal D, Angeles Martinez M, Fabrellas B. 2003. Innovative approach for the analysis of polybrominated diphenyl ethers (PBDEs) by quadrupole ion-trap mass spectrometry. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
Lau F, Destaillats H, Charles MJ. 2003. Experimentally determined Henry’s Law constants for six brominated diphenyl ether congeners. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
Law RJ, Allchin CR. 2001. Brominated flame retardants in the UK environment. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 139–141.
Law RJ, Allchin CR, Bennett ME, . 2000. Polybrominated diphenyl ethers in the blubber of harbour porpoises (Phocoena L.) stranded on the coasts of England and Wales. Organohalogen Compounds 47:249–252.
Law RJ, Allchin CR, Bennett ME, . 2002. Polybrominated diphenyl ethers in two species of marine top predators from England and Wales. Chemosphere 46(5):673–681.11999790
Laws SC, Ferrell JM, Hedge JM, . 2003. The effects of DE-71, a commercial polybrominated diphenyl ether mixture, on female pubertal development and thyroid function. Toxicologist 72(5–1):136.
Lebeuf M, Trottier S. 2001. The relationship between age and levels of polybrominated diphenyl ethers in Beluga whales from the St. Lawrence estuary, Canada. Organohalogen Compounds 52:22–25.
LeBoeuf RA, Kerchaert GA, Aardema MJ, . 1996. The pH 6.7 Syrian hamster embryo cell transformation assay for assessing the carcinogenic potential of chemicals. Mutat Res 356:85–127.8841476
*Lee KP, Hebert RR, Sherman H, . 1975a. Bromine tissue residue and hepatotoxic effects of octabromobiphenyl in rats. Toxicol Appl Pharmacol 34:115–127.1198609
*Lee KP, Hebert RR, Sherman H, . 1975b. Octabromobiphenyl-induced ultrastructural changes in rat liver. Arch Environ Health 30:465–471.1164048
Lee RGM, Jones KC. 2002. Atmospheric concentrations of PBDEs in Western Europe. Organohalogen Compounds 58:193–196.
Lee S-J, Kim B-H, Kim H-S, . 2002. Human blood levels of polybrominated diphenyl ethers in Korea. Organohalogen Compounds 58:205–208.
*Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Lemesh KA. 1992. Polychlorinated biphenyls: An overview of metabolic toxicologic and health consequences. Vet Hum Toxicol 34:256–268.1609503
Lenior D, Zier B, Bieniek D, . 1994. The influence of water and metals on PBDD/F concentration in incineration of decabromobiphenyl ether in polymeric matrices. Chemosphere 28(11):1921–1928.
Leonards PEG, Santillo D, Brigden K, . 2001. Brominated flame retardants in office samples. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 299–302.
Letcher RJ. 2003. The state-of-the-science and trends of brominated flame retardants in the environment: Present knowledge and future directions. Environ Int 29:663–664.12850085
Letcher RJ, D’Sa I, Valters K, . 2003. Polybrominated diphenyl ethers and hydroxylated and methoxylated analogues in Detroit River fish. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
Leung H-W. 1991. Development and utilization of physiologically based pharmacokinetic models for toxicological applications. J Toxicol Environ Health 32:247–267.2002511
*Leung H-W. 1993. Physiologically-based pharmacokinetic modeling. In: Ballentine B, Marro T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
*Lewis RG, Sovocool GW. 1982. Identification of polybrominated biphenyls in the adipose tissues of the general population of the United States. J Anal Toxicol 6:196–198.6289008
Lichtensteiger W, Ceccatelli R, Faass O, . 2003a. Effect of polybrominated diphenylether and PCB on the development of the brain-gonadal axis and gene expression in rats. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
Lichtensteiger W, Ceccatelli R, Faass O, . 2003b. Effects of polybrominated diphenylether (PBDE) on reproductive organ and brain development and gene expression in rats. Toxicologist 72(5–1):133.
Life Sciences Research Israel LTD. 1987. FR-1208: Teratology study in the rat. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4/8. OTS0513908.
Lind Y, Atuma S, Aune M, . 2001. Polybrominated diphenyl ethers (PBDEs) in breast milk from Uppsala women - extension and up-dating of data. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 117–264.
Lind Y, Darnerud PO, Atuma S, . 2003. Polybrominated diphenyl ethers in breast milk from Uppsala County, Sweden. Environ Res 93(2):186–194.12963403
Lindstöm GUM. 1999. Aspects of polybrominated diphenyl ethers as indoor, occupational, and environmental pollutants. Organohalogen Compounds 43:445–446.
Lindström G, Hardell L, Van Bavel B, . 1998. Current level of 2,2’4,4’-tetrabrominated diphenyl ether in human adipose tissue in Sweden. A risk factor for non-Hodgkin’s lymphoma? Organohalogen Compounds 35:431–434.
Lindström G, Van Bavel B, Hardell L, . 1997. Identification of the flame retardants polybrominated diphenyl ethers in adipose tissue from patients with non-Hodgkin’s lymphoma in Sweden. Oncol Rep 4:999–1000.21590182
Lindström G, Wingfors H, Dam M, . 1999. Identification of 19 polybrominated diphenyl ethers (PBDEs) in long-finned pilot whale (Globicephala melas) from the Atlantic. Arch Environ Contam Toxicol 36(3):355–363.10047605
Lioy PJ. 2002. Residues from the world trade center disaster in lower Manhattan and potential human exposures. Int J Toxicol 21(6):540.
Litz N. 2002. Some investigations into the behavior of pentabromodiphenyl ether (PEBDE) in soils. J Plant Nutr Soil Sci 165:692–696.
*Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
Loganathan BG, Kannn K, Watanabe, . 1995. Isomer-specific determination and toxic evaluation of polychlorinated biphenyls, polychlorinated/brominated dibenzo-p-dioxins and dibenzofurans, polybrominated biphenyl ethers, and extractable organic halogen in carp from the Buffalo River, New York. Environ Sci Technol 29(7):1832–1838.22176457
Llansola M, Erceg S, Montoliu C, . 2001. Comparative study of PBDE 99 and Aroclor 1254 neurotoxicity. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 263–264.
*Loose LD, Mudzinski SP, Silkworth JB. 1981. Influence of dietary polybrominated biphenyl on antibody and host defense responses in mice. Toxicol Appl Pharmacol 59:25–39.6266074
Lopes TJ, Furlong T, Edward T. 2001. Occurrence and potential adverse effects of semivolatile organic compounds in streambed sediment, United States, 1992-1995. Environ Toxicol Chem 20(4):727–737.11345447
Lorber M. 2003. Assessment of dioxin inhalation exposures and potential health impacts following the collapse of the world trade center towers. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
Luckey F, Fowler B, Litten S. 2001. Establishing baseline levels of polybrominated diphenyl ethers in Lake Ontario surface waters. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 337–339.
Ludewig G, Tampal NM, Robertson LW. 2003. Comparative study of PCB, PBB and PBDE mixtures on serum parameters in the rat. Toxicol Sci 72(S-1):365.
*Luijk R, Govers HAJ. 1992. The formation of polybrominated dibenzo-p-dioxins (PBDDs) and dibenzofurans (PBDFs) during pyrolysis of polymer blends containing brominated flame retardants. Chemosphere 25(3):361–374.
Luross JM, Alaee M, Cannon CM, . 2001. Spatial and temporal distribution of polybrominated diphenyl ethers and polybrominated biphenyls in lake trout from the Great Lakes. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 401–404.
Luross JM, Aalee M, Sergeant DB, . 2000. Spatial and temporal distribution of polybrominated diphenyl ethers in lake trout from the Great Lakes. Organohalogen Compounds 47:73–76.
*Luross JM, Alaee M, Sergeant DB, . 2002. Spatial distribution of polybrominated diphenyl ethers and polybrominated biphenyls in lake trout from the Laurentain Great Lakes. Chemosphere 46(5):665–672.11999789
*Luster MI, Boorman GA, Harris MW, . 1980. Laboratory studies on polybrominated biphenyl-induced immune alterations following low-level chronic or pre/postnatal exposure. Int J Immunopharmacol 2:69–80.
*Luster MI, Faith RE, Moore JA. 1978. Effects of polybrominated biphenyls (PBB) on immune response in rodents. Environ Health Perspect 23:227–232.209980
Lutes CC, Charles MJ, Odum JR, . 1992. Chamber aging studies on the atmospheric stability of polybrominated dibenzo-p-dioxins and dibenzofurans. Environ Sci Technol 26(5):991–998.
Lyman WJ, Reehl WF, Rosenblatt, DH. 1990. Handbook of chemical properties estimation methods. American Chemical Society: Washington, DC, 4-9, 15-1 to 15-29.
Mackay D. 1982. Correlation of bioconcentration factors. Environ Sci Technol 16:274–278.22257252
MacPhail R, Farmer JD, Padnos BK, . 2003. Lack of effect of perinatal exposure to a polybrominated diphenyl ether mixture (DE-71) on the habituation of motor activity in adult rats. Toxicol Sci 72(S-1):123.
Madra S, Smith AG. 1992. Induction of cytochrome P450 activities by polychlorinated biphenyls in isolated mouse hepatocytes. Influence of Ah-phenotype and iron. Biochem Pharmacol 44(3):455–464.1510696
Mamantov A. 1985. The photolysis of polychlorinated diphenyl ethers and chloroanisoles may proceed via carbenes. Chemosphere 14(6/7):905–908.
Manchester-Neesvig JB, Sonzogni WC, Hahm JL. 2003. A depth profile of polybrominated diphenyl ethers (PBDEs) and polychlorinated biphenyls (PCBs) in sediments from Lake Michigan. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
Manchester-Neesvig JB, Valters K, Sonzogni WC. 2001. Comparison of polybrominated diphenyl ethers (PBDEs) and polychlorinated biphenyls (PCBs) in Lake Michigan salmonids. Environ Sci Technol 35(6):1072–1077.11347916
Marcus M. 2003. Pubertal development and exposure to polybrominated biphenyls (PBBs). Toxicol Sci 72(S-1):334.
Marcus M, Cheslack-Postava K, Tolbert PE, . 2002. Breast-feeding and PBBs: Response to Rogan and Weil. Environ Health Perspect 110(9):A504.
Mariussen E, Fonnum F. 2002. The effect of pentabromodiphenyl ether, hexabromocyclododecane and tetrabromobisphenol-A on dopamine uptake into rat brain synaptosomes. Organohalogen Compounds 57:395–398.
Mariuseen E, Fonnum F. 2003. The effect of brominated flame retardants on neurotransmitter uptake into rat brain synaptosomes and vesicles. Neurochem Int 43(4–5):533–542.12742101
Mariussen E, Andersson PL, Patrik L, . 2003a. The effect of various substituents in ortho position of biphenyls on respiratory burst. Intracellular calcium elevation in human granulocytes, and uptake of dopamine into rat synaptic vesicles and synaptosomes. Environ Toxicol Pharmacol 14(1–2):43–50.21782661
Mariussen E, Fjeld E, Strand-Andersen M, . 2003b. Bioaccumulation of polybrominated diphenyl ethers in fish from the Norwegian Lake Mjosa. Organohalogen Compounds. Dioxins 2003. Boston, MA, 60–65.
Mariussen E, Fjeld E, Strand-Andersen M, . 2003c. Spatial distribution of polybrominated diphenyl ethers in trout from Norwegian lakes. Organohalogen Compounds. Dioxins 2003. Boston, MA, 60–65.
Marsh G, Bergman A, Bladh L-G, . 1998. Synthesis of p-hydroxybromodiphenyl ethers and binding to the thyroid receptor. Organohalogen Compounds 37:305–308.
Marsh G, Hu J, Jakobsson E, . 1999. Synthesis and characterization of 21-polybrominated diphenyl ethers. Environ Sci Technol 33(17):3033–3037.
MARSSIM. 1997. Multi-agency radiation survey and site investigation manual. Nuclear Regulatory Commission, Energy Department, Environmental Protection Agency, and Defense Department. NUREG 1575, EPA402R97016.
*Martino LJ, Wilson-Martino NA, Benitz KF. 1981. The presence of intranuclear lipid inclusions in hepatocytes of mice after chronic ingestion of polybrominated biphenyl. Arch Toxicol 47:155–158.6268014
Matthews EJ, Spalding JW, Tennant RW. 1993. Transformation of BALB/c-3T3 cells: V. Transformation responses of 168 chemicals compared with mutagenicity in Salmonella and carcinogenicity in rodent bioassays. Environ Health Perspect Suppl 101:347–482.8243403
*Matthews HB, Kato S, Morales NM, . 1977a. Distribution and excretion of 2,4,5,2’,4’,5’-hexabromobiphenyl, the major component of Firemaster BP-6. J Toxicol Environ Health 3:599–605.200764
*Matthews HB, Tuey DB, Anderson MW. 1977b. Pharmacokinetic models for lipophilic compounds. Environ Health Perspect 20:257–262.413710
*Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
Mazdai A, Dodder NG, Abernathy MP, . 2003. Polybrominated diphenyl ethers in maternal and fetal blood samples. Environ Health Perspect 111:1249–1252.12842781
McAllister D, Mazac CJ, Gorsich R . 1990. Analysis of polymers containing brominated diphenyl ethers as flame retardants after molding under various conditions. Chemosphere 10–12:1537–1541.
*McConnell EE, Harris MW, Moore JA. 1980. Studies on the use of activated charcoal and cholestyramine for reducing the body burden of polybrominated biphenyls. Drug Chem Toxicol 3:277–292.6256148
*McCormack KM, Hook JB. 1982. Effects of lactation and nursing on tissue concentrations of polybrominated biphenyls and on microsomal enzyme activity in mammary gland and liver in maternal rats. Environ Res 27:110–117.6802635
McCormack KM, Arneric SP, Hook JB. 1979. Action of exogenously administered steroid hormones following perinatal exposure to polybrominated biphenyls. J Toxicol Environ Health 5:1085–1094.231115
*McCormack KM, Kluwe WM, Rickert DE, . 1978. Renal and hepatic microsomal enzyme stimulation and renal function following three months of dietary exposure to polybrominated biphenyls. Toxicol Appl Pharmacol 44:539–553.210533
*McCormack KM, Lepper LF, Wilson DM, . 1981. Biochemical and physiological sequelae to perinatal exposure to polybrominated biphenyls: A multigeneration study in rats. Toxicol Appl Pharmacol 59:300–313.6266078
McCormack KM, Roth RA, Wallace KB, . 1982a. Nonrespiratory metabolic function and morphology of lung following exposure to polybrominated biphenyls in rats. J Toxicol Environ Health 9:27–39.6278155
*McCormack KM, Stickney JL, Bonhaus DW, . 1982b. Cardiac and hepatic effects of pre-and postnatal exposure to polybrominated biphenyls in rats. J Toxicol Environ Health 9:13–26.6278154
*McDonald TA. 2002. A perspective on the potential health risks of PBDEs. Chemosphere 46(5):745–755.11999798
McGregor DB, Brown A, Cattanach P, . 1988. Responses of the L5178Y tk+/tk^−^ mouse lymphoma cell forward mutation assay: III. 72 coded chemicals. Environ Mol Mutagen 12(1):85–154.3383842
McKinney RF, Chaw SJK, Rickenbacher U . 1987. Polychlorinated biphenyls and related compound interactions with specific binding sites for thyroxine in rat liver nuclear extracts. J Med Chem 30:79–86.3100800
*MDCH. 2002. http://www.michigan.gov.mdch. May 30, 2002.
Meerts IA, Lujiks E, Marsh G, . 1988. Polybrominated diphenylethers (PBDEs) as Ah-receptor agonists and antagonists. Organohalogen Compounds 37:147–150.
Meerts IA, Marsh G, van Leeuwen-Bol I, . 1998. Interaction of polybrominated diphenyl ether metabolites (PBDE-OH) with human transthyretin in vitro. Organohalogen Compounds 37:309–312.
Meerts IA, Letcher RJ, Hoving S, . 2001. In vitro estrogenicity of polybrominated diphenyl ethers, hydroxylated PDBEs and polybrominated bisphenol A compounds. Environ Health Perspect 109(4):399–407.11335189
Meerts IA, van Zanden JJ, Luijks EA, . 2000. Potent competitive interactions of some brominated flame retardants and related compounds with human transthyretin in vitro. Toxicol Sci 56(1):95–104.10869457
Meijer L, Hafkamp AM, Bosman WE, . 2003. Non-absorbable fat increases the disposal of 2,2’,4,4’-tetrabromodiphenyl (BDE-47) in rats through interruption of the enterohepatic circulation. Organohalogen Compounds. Dioxins 2003. Boston, MA, 60–65.
*Meironyte Guvenius DM, Noren K, Bergman A. 1999a. Analysis of polybrominated diphenyl ethers in Swedish human milk. A time related trend study, 1972-1997. J Toxicol Environ Health A 58(6):329–341.10580757
*Meironyte-Guvenius DM, Noren K. 1999b. Polybrominated diphenyl ethers in human liver and adipose tissues. A pilot study. Organohalogen Compounds 40:372–382.
Meironyte Guvenius DM, Noren K. 2001. Polybrominated diphenyl ethers in Swedish human milk. The follow-up study. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 303–305.
Meironyte Guvenius DM, Bergman A, Noren K. 1998. Analysis of polybrominated diphenyl ethers in human milk. Organohalogen Compounds 35:387–390.
Meironyte Guvenius DM, Bergman A, Noren K. 2001. Polybrominated diphenyl ethers in Swedish human liver and adipose tissue. Arch Environ Contam Toxicol 40:564–570.11525501
Meironyte Guvenius DM, Bergman A, Noren K. 2002. Occurrence and pre-and postnatal transfer of PBDEs, PCBs and OH-PCBs in humans. Organohalogen Compounds 55:271–274.
Meneses M, Wingfors H, Schuhmacher M, . 1999. Polybrominated diphenyl ethers detected in human adipose tissue from Spain. Chemosphere 39(13):2271–2278.10576099
Mennear JH, Lee C-C. 1994. Polybrominated dibenzo-p-dioxins and dibenzofurans: Literature review and health assessment. Environ Health Perspect Suppl 102:265–274.
*Mercer HD, Teske RJ, Condon A, . 1976. Herd health status of animals exposed to polybrominated biphenyls (PBB). J Toxicol Environ Health 2:335–349.189054
Merrill JC, Beck DJ, Kaminski DA, . 1995. Polybrominated biphenyl of cytochrome P450 mixed function oxidase activity in primary rat and human hepatocytes. Toxicology 33:147–153.
*Meserve LA, Murray BA, Landis JA. 1992. Influence of maternal ingestion of Aroclor 1254 (PCB) or FireMaster BP-6 (PBB) on unstimulated and stimulated corticosterone levels in young rats. Bull Environ Contam Toxicol 48(5):712–720.
Meylan WM, Howard PH. 1991. Bond contribution methods for estimating Henry’s Law constants. Environ Toxicol Chem 10:1283–1293.
Meylan WN, Howard PH. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26:2293–2299.
*Miceli JN, Marks BH. 1981. Tissue distribution and elimination kinetics of polybrominated biphenyls (PBB) from rat tissue. Toxicol Lett 9:315–320.6277044
*Miceli JN, Nolan DC, Marks B, . 1985. Persistence of polybrominated biphenyls (PBB) in human post-mortem tissue. Environ Health Perspect 60:399–403.2992925
Microbiological Associates Inc. 1996. Pentabromodiphenyloxide and octabromodiphenyl oxide. Maximization test in guinea pigs. Submitted to U.S. Environmental Protection Agency under TSCA Section FYI. OTS0001281.
Miguel R, Laboa G. 2001. Identification of brominated flame retardants in plastics from End of Life Electric and Electronic Equipments in view of WEEE directive. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 187–191.
*Millis CD, Mills RA, Sleight SD, . 1985. Toxicity of 3,4,5,3’,4’, 5’-hexabrominated biphenyl and 3,4,3’,4’-tetrabrominated biphenyl. Toxicol Appl Pharmacol 78:88–95.2994254
*Millischer R, Girault F, Heywood R, . 1980. Decabromobiphenyl: Toxicologic study. Toxicol Eur Res 2:155–161.
Mills RA, Millis CD, Dannan GA, . 1985. Studies on the structure-activity relationships for the metabolism of polybrominated biphenyls by rat liver microsomes. Toxicol Appl Pharmacol 78:96–104.2994255
*Mirsalis JC, Tyson CK, Loh EN, . 1985. Induction of hepatic cell proliferation and unscheduled DNA synthesis in mouse hepatocytes following in vivo treatment. Carcinogenesis 6:1521–1524.4042279
*Mirsalis JC, Tyson CK, Steinmetz KL, . 1989. Measurement of unscheduled DNA synthesis and s-phase synthesis in rodent hepatocytes following in vivo treatment: Testing of 24 compounds. Environ Mol Mutagen 14:155–164.2792091
Moisey J, Simon M, Wakeford B, . 2001. Spatial and temporal trends of polybrominated diphenyl ethers detected in Great Lakes herring gulls, 1981 to 2000. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 153–157.
Moon H-B, Choi H-G, Kim S-S, . 2002a. Contaminations of polybrominated diphenyl ethers in marine sediments from the southern coastal areas of Korea. Organohalogen Compounds 58:217–220.
Moon H-B, Choi H-G, Kim S-S, . 2002b. Polybrominated diphenyls in marine sediments and bivalves from the coastal areas of Korea. Organohalogen Compounds 58:221–224.
*Moore RW, Dannan GA, Aust SD. 1978. Induction of drug metabolizing enzymes in polybrominated biphenyl-fed lactating rats and their pups. Environ Health Perspect 23:159–165.209970
*Moore RW, Sleight SD, Aust SD. 1979. Effects of 2,2’-dibromobiphenyl and 2,2’,3,4,4’,5,5’-heptabromobiphenyl on liver microsomal drug metabolizing enzymes. Toxicol Appl Pharmacol 48:73–86.222013
*Moorhead PD, Willett LB, Brumm CJ, . 1977. Pathology of experimentally induced polybrominated biphenyl toxicosis in pregnant heifers. J Am Vet Med Assoc 170:307–313.188792
Morck A, Hakk H, Orn U, . 2003. Decabromodiphenyl ether in the rat: Absorption, distribution, metabolism, and excretion. Drug Metab Dispos 31:900–907.12814967
Morck A, Klasson Wehler E. 2001. Metabolism of decabromodiphenyl ether (BDE-209) in the rat. Organohalogen Compounds 52:9–12.
*Morreale de Escobar G, Obregon MJ, Escobar del Rey F. 2000. Is neuropsychological development related to maternal hypothyroidism or to maternal hypothyroxinemia? J Clin Endocrinol Metab 85(11):3975–3987.11095417
*Morris PJ, Quensen JF, Tiedje JM, . 1992. Reproductive debromination of the commercial polybrominated biphenyl mixture Firemaster BP6 by anaerobic microorganisms from sediments. Appl Environ Microbiol 58(10):3249–3256.1332608
*Morris PJ, Quensen JF III, Tiedje JM, . 1993. An assessment of the reduction debromination of polybrominated biphenyls in the Pine River Reservoir. Environ Sci Technol 27(8):1580–1586.
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
Muir D, Teixeira C, Chigak M, . 2003. Current deposition and historical profiles of decabromodiphenyl ether in sediment cores. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
Muir T, Alaee M. 2002. Costs and benefits of brominated flame retardants (BFRs) and alternatives. Organohalogen Compounds 58:237–240.
*Mulligan KJ, Caruso JA. 1980. Determination of polybrominated biphenyl and related compounds by gas-liquid chromatography with a plasma emission detector. Analyst 105:1060–1067.
*Murata T, Zabik ME, Zabik MY. 1977. Polybrominated biphenyls in raw milk and processed dairy products. J Dairy Sci 60(4):516–520.193876
Myhr B, McGregor D, Bowers L, . 1990. L5178Y Mouse lymphoma cell mutation assay results with 41 compounds. Environ Mol Mutagen 16:138–167.2128695
*Myhr BC, Caspary WJ. 1991. Chemical mutagenesis at the thymidine kinase locus in L5178Y mouse lymphoma cells: Results for 31 coded compounds in the National Toxicology Program. Environ Mol Mutagen 18:51–83.1864269
Nace CG, Maddaloni M, LaPosta D, . 2003. Measuring and evaluating impacts of dioxin-like compounds in residential apartments near the world trade center site. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
Nagayama J, Takasuga T, Tsuji H. 2001. Contamination levels of brominated flame retardants, dioxins and organochlorine compounds in the blood of Japanese adults. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 113–116.
Nagayama J, Tsuji H, Takasuga T. 2000. Comparison between brominated flame retardants and dioxins or organochlorine compounds in blood levels of Japanese adults. Organohalogen Compounds 48:27–30.
*NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press.
NATICH. 1988. NATICH data base report on state, local and EPA air toxics activities. Research Triangle Park, NC: National Air Toxics Information Clearinghouse, U.S. Environmental Protection Agency.
National Safety Council. 1999. Baseline report: Recycling of selected electronic products in the United States. Washington, DC: National Safety Council, 1–47.
*Needham LL, Hill RH, Orti DL, . 1982. Investigation of hyperkeratotic activity of polybrominated biphenyls in Firemaster FF-1. J Toxicol Environ Health 9:877–887.6288971
Nemec M, Holsen J, Naas D, . 1992. The developmental toxicity of FM-100 in the rat and rabbit following repeated exposure by inhalation. Teratology 45(5):475–476.
*Neufeld ML, Sittenfield M, Wolk KF. 1977. Market input/output studies: Task IV. Polybrominated biphenyls. Washington, DC. EPA-560677017.
NIES/EPA. 2002. Superfund Basic Research Program. Current research programs. http://benson.niehs.nih/sbrp/Program2000/program00.cfm.
Nikiforov VA, Karavan VS, Miltsov SA. 2003. Synthesis and characterization of methoxy- and hydroxy- polybromodiphenyl ethers. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
Noren K, Meironyte D. 1998. Contaminants in Swedish human milk. Decreasing levels of organochlorine and increasing levels of organochlorine compounds. Organohalogen Compounds 38:1–4.
Noren K, Meironyte D. 2000. Certain organochlorine and organobromine contaminants in Swedish human milk in perspective of past 20-30 years. Chemosphere 40:1111–1123.10739053
*Norris JM, Ehrmantraut JW, Gibbons CL, . 1973. Toxicological and environmental factors involved in the selection of decabromodiphenyl oxide as a fire retardant chemical. Appl Polym Symp 22:195–219.
*Norris JM, Ehrmantraut JW, Kociba RJ, . 1975a. Evaluation of decabromodiphenyl oxide as a flame-retardant chemical. Chem Hum Health Environ 1:100–116.
*Norris JM, Kociba RJ, Humiston CG, . 1975b. The toxicity of decabromo diphenyl and octabromo biphenyl as determined by subacute and chronic dietary feeding studies in rats. Toxicol Appl Pharmacol 33:170.
Norris JM, Kociba RJ, Schwetz BA, . 1975c. Toxicology of octabromobiphenyl and decabromodiphenyl oxide. Environ Health Perspect 11:153–161.126149
Norstrom RJ, Simon M, Moisey J, . 2002. Geographical distribution (2000) and temporal trends (1981-2000) of brominated diphenyl ethers in Great Lakes herring gull eggs. Environ Sci Technol 36:4783–4789.12487300
*NRC. 1993. Pesticides in the diets of infants and children. National Research Council. Washington, DC: National Academy Press.
NRC. 2000. Decabromodiphenyl oxide. In: Toxicological risks of selected flame-retardant chemicals. National Research Council (US): Subcommittee on Flame-Retardant Chemicals. Washington, DC: National Academy Press, 72–98.
*NTP. 1983. NTP technical report on the toxicology and carcinogenesis studies of a polybrominated biphenyl mixture (Firemaster FF-1) (CAS No. 67774-32-7) in F344/N rats and B6C3F1 mice (gavage studies). Research Triangle Park, NC: National Toxicology Program.
NTP. 1986. NTP technical report on the toxicology and carcinogenesis studies of decabromodiphenyl oxide (CAS No. 1163-19-5) in F344/N rats and B6C3F1 mice (feed studies). Research Triangle Park, NC: National Toxicology Program.
*NTP. 1992. NTP technical report on the perinatal toxicology and carcinogenesis studies of polybrominated biphenyls (Firemaster FF-1) (CAS No. 67774-32-7) in F344/N rats and B6C3F1 mice (feed studies). Research Triangle Park, NC: National Toxicology Program.
*NTP. 2002. Names and synonyms of carcinogens. National Toxicology Program. http://ntp-server.niehs.nih.gov/htdocs/8_RoC/RAHC_list.html. April 18, 2002.
NTP. 2004. 2,2’,4,4’,5,5’-Hexabromodiphenyl ether. National Toxicology Program. http://ntp-server.niehs.nih.gov/htdocs/Results_status/ResstatH/M010078.html. September 1, 2004.
Nylund K, Asplund L, Jansson B, . 1992. Analysis of some polyhalogenated organic pollutants in sediment and sewage sludge. Chemosphere 24(12):1721–1730.
Oberg T, Warman K, Bergstrom J. 1987. Brominated aromatics from combustion. Chemosphere 16(10–12):2451–2465.
Oberg K, Warman K, Oberg T. 2002. Distribution and levels of brominated flame retardants in sewage sludge. Chemosphere 48(8):805–809.12222774
O’Connor JC, Frame SR, Davis LG, . 1999. Detection of thyroid toxicants in a tier 1 screening battery and alterations in thyroid endpoints over 28 days of exposure. Toxicol Sci 51:54–70.10496677
Ohta S, Ishizuka D, Nishimura H, . 2000. Real situation of contamination by polybrominated diphenyl ethers as flame retardants in market fish and mother milk of Japan. Organohalogen Compounds 47:218–221.
Ohta S, Ishizuke D, Nishimura H, . 2002a. Comparison of polybrominated diphenyl ethers in fish, vegetables, and meats and levels in human milk of nursing women in Japan. Chemosphere 46(5):689–696.11999792
Ohta S, Nakao T, Nishimura H, . 2002b. Contamination levels of PBDEs, TBBPA, PCDDs/DFs, PBDDs/DFs and PXDDs/DFs in the environment of Japan. Organohalogen Compounds 57:57–60.
Ohta S, Nishimura H, Nakoa T, . 2001. Characterization of the photolysis of decabromodiphenyl ether and the levels of PBDEs as its photoproducts in atmospheric air of Japan. Organohalogen Compounds 52:321–324.
*O’Keefe PW. 1978. Formation of brominated dibenzofurans from pyrolysis of the polybrominated biphenyl fire retardant, Firemaster FF-1. Environ Health Perspect 23:347–350.209998
*Okey AB, Vella LM, Harper PA. 1989. Detection and characterization of a low affinity form of cytosolic Ah receptor in livers of mice nonresponsive to induction of cytochrome P1-450 by 3-methylcholanthrene. Mol Pharmacol 35:823–830.2543914
Oliaei F, King P, Phillips L. 2002. Occurrence and concentrations of polybrominated diphenyl (PBDEs) in Minnesota environment. Organohalogen Compounds 58:185–188.
Olsson A, Vitnish M, Plikshs M, . 1999. Halogenated environmental contaminants in perch (Perca fluviatilis) from Latvian coastal areas. Sci Total Environ 239(1–3):19–30.10570832
Olsson M, Karlsson B, Ahnland E. 1994. Diseases and environmental contaminants in seals from the Baltic and the Swedish west coast. Sci Total Environ 154:217–227.7973608
*Opperhuizen A, Velde EW, Gobas FAPC, . 1985. Relationship between bioconcentration in fish and steric factors of hydrophobic chemicals. Chemosphere 14(11/12):1871–1896.
Orn U, Klasson-Wehler E. 1998. Metabolism of 2,2’,4,4’-tetrabromodiphenyl ether in rat and mouse. Xenobiotica 1998:199–211.
*Orti DL, Hill RH, Patterson DG, . 1983. Structure elucidation of some minor components of the polybromobiphenyl mixture, Firemaster. Arch Environ Contam Toxicol 12:603–614.6316856
*OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment. OTABA438.
Ott MG, Zober A. 1996. Morbidity study of extruder personnel with potential exposure to brominated dioxins and furans. II. Results of clinical laboratory studies. Occup Environ Med 53(12):844–846.8994404
*Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Palha J, Fernandes R, de Escobar G, . 2000. Transthyretin regulates thyroid hormone levels in the choroid plexus, but not in the brain parenchyma: Study in a transthyretin-null mouse model. Endocrinology 141(9):3267–3272.10965897
Palha J, Hays M, Morreale de Escobar G, . 1997. Transthyretin is not essential for thyroxine to reach the brain and other tissues in transthyretin-null mice. Am J Physiol 272(3 Pt 1):E485–E493.9124556
Palm A, Cousins IT, Mackay D, . 2002. Assessing the environmental fate of chemicals of emerging concern: A case study of the polybrominated diphenyl ethers. Environ Pollut 117:195–213.11916035
Papke O, Bathe L, Bergman A, . 2001. Determination of PBDEs in human milk from the United States. Comparison of results from three laboratories. Organohalogen Compounds 52:197–200.
Pardini AT, Jones CS, Noble, . 2001. Persistent pollutants in land-sludges. Nature 412:140–141.11449259
*Parkinson A, Safe SH, Robertson LW, . 1983. Immunochemical quantitation of cytochrome P-450 isozymes and epoxide hydrolase in liver microsomes from polychlorinated or polybrominated biphenyl-treated rats. J Biol Chem 258(9):5967–5976.6304102
Patterson DG, Sjodin A, Bergman A. 2000. Brominated flame retardants in serum from US blood donors. Organohalogen Compounds 47:45–48.
Pazdernik TL, Rozman KK. 1985. Effect of thyroidectomy and thyroxine on 2,3,7,8-tetra-chlorodibenzo-p-dioxin-induced immunotoxicity. Life Sci 36:695–703.3881642
Pelota J, Yla-Mononen L. 2001. The commercial pentabromodiphenyl ether as a global POP. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 33–36.
Peng J-H, Cheng C-Y, Huang C-W, . 2003. Determination of polybrominated diphenyl ethers and polybrominated dibenzo-p-dioxins/dibenzofurans in flue gas analysis. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
Pereg D, Ryan JJ, Ayotte P, . 2003. Temporal and spatial changes of brominated diphenyl ethers (BDEs) and other POPs in human milk from Nunavik (Arctic) and southern Quebec. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
Peterman P, Orazio CE, Feltz KP. 2003. Sunlight photolysis of 39 mono-hepta PBDE congeners in lipid. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
Peters AJ, Coleman P, Jones KC. 1999. Organochlorine pesticides in UK air. Organohalogen Compounds 41:447–450.
Peters AK, Sanderson JT, Bergman A, . 2003a. Induction and inhibition of cytochrome P450 1A1, 1B1, and ethoxyresorufin-O-deethylation activity by polybrominated diphenyl ethers (PBDE) in MCF7 cells. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
Peters L, Sanderson T, Bergman A, . 2003b. Agonistic and antagonistic effects on polybrominated diphenyl ethers (PBDE) in MCF7 cells. Toxicol Sci 72(S-1):369–370.
Petreas M, She J, Brown FR, . 2002. High PBDE concentrations in California human and wildlife populations. Organohalogen Compounds 58:177–180.
Petreas M, She J, Brown FR, . 2003. High body burdens of 2,2’,4,4’-tetrabromodiphenyl ether (BDE-47) in California women. Environ Health Perspect 111(9):1175–1179.12842770
Pettersson A, Engwall M, Olsman H. 2001a. EROD-induction by polybrominated diphenyl ethers in cultured chick embryo livers. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 267–270.
Pettersson A, Karlsson M, van Bavel B, . 2002. Concentrations of polybrominated diphenylethers and thyroid hormones in human plasma from exposed workers. Organohalogen Compounds 58:269–272.
Pettersson A, Westberg H, Engwall M, . 2001b. Concentrations in air and dust of polybrominated diphenyl ethers and tetrabromobisphenol A. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 223–226.
Pettigrew A. 1993. Flame retardants (halogenated). In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. Explosives and propellants to flame retardants for textiles. Vol. 10. 4^th^ edition. New York, NY: John Wiley & Sons, 960–976.
Pharmakon Associates Inc. 1984. Initial submission: Acute oral toxicity in rats (14 days) of Saytex 115 (pentabromodiphenyloxide). Submitted to the U.S. Environmental Protection Agency under TSCA Section FYI. OTS0000972.
Pijenburg AM, Everts JW, de Boer J, . 1995. Polybrominated biphenyl and diphenylether flame retardants: Analysis, toxicity, and environmental occurrence. Rev Environ Contam Toxicol 141:1–26.7886253
Pirard C, De Pauw E, Focant J-F. 2003. Levels of selected PBDEs and PCBs in Belgian human milk. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
*Poland A, Glover E, Kende AS. 1976. Stereospecific, high affinity binding of 2,3,7,8-tetra-chlorodibenzo-p-dioxin by hepatic cytosol. Evidence that the binding species is receptor for induction of aryl hydrocarbon hydrolase. J Biol Chem 251:4936–4946.956169
*Poland A, Palen D, Glover E. 1982. Tumour promotion by TCDD in skin of HRS/J hairless mice. Nature 300:85–87.
*Polin D, Leavitt RA. 1984. Colestipol and energy restriction as an approach to hasten removal of PBBs from chickens. J Toxicol Environ Health 13:659–671.6092654
*Polin D, Bursian SJ, Underwood MS, . 1991. Elimination of PBBs in rats, effect of mineral oil and/or feed restriction. J Toxicol Environ Health 33:197–212.1646894
*Polin D, Lehning E, Pullen D, . 1985. Procedures to enhance withdrawal of xenobiotics from chickens. J Toxicol Environ Health 16:243–254.3001328
*Pomerantz I, Burke J, Firestone D, . 1978. Chemistry of PCBs and PBBs. Environ Health Perspect 24:133–146.17539141
Porterfield SP. 1994. Vulnerability of the developing brain to thyroid abnormalities: Environmental insults to the thyroid system. Environ Health Perspect Suppl 102:125–230.
Priest B. 2001. Brominated flame retardants: Commercially available analytical standards. BFR, 193–194.
Pullen S. 2001. Immunotoxic effects of polybrominated flame retardants. Naunyn-Schmiedebergs Arch Pharmacol 363(4):R141.
*Purdy R, Safe S. 1980. The in vitro metabolism of 2,2’,4,4’,5,5’-hexabromobiphenyl. J Environ Pathol Toxicol 4:277–284.
Quensen JP III, Morris PJ, Boyd SA. 1990. Dehalogenation of PCBs and PBBs by anaerobic microorganisms from sediments. In: Proceedings of the 90^th^ American Society for Microbiology Annual Meeting, Anaheim, CA [Abstract Q-44]. American Society for Microbiology, Washington, DC. 90:295.
*Raber BT, Carter JW. 1986. Localization of ultrastructural alterations induced in rat liver by dietary polybromobiphenyls (Firemaster BP-6). Arch Environ Contam Toxicol 15:725–732.3024589
Rahman F, Lanford KH, Scrimshaw MD, . 2001. Polybrominated diphenyl ether (PBDE) flame retardants. Sci Total Environ 275(1–3):1–17.11482396
Rangga-Tabbu C, Sleight SD. 1992. Development of preneoplastic lesions in the liver and nasal epithelium of rats initiated with N-nitrosodimethylamine or N-nitrosopyrrolidine and promoted with polybrominated biphenyls. Food Chem Toxicol 30(11):921–926.1335435
Rao P, Kodavanti S, Zhang P. 2003. Effects of polybrominated diphenyl ethers and polychlorinated biphenyls on [^3^H] phorbol ester binding in rat neurons. J Neurochem 85(suppl 1):13.
*Rappe C, Buser HR. 1980. Chemical properties and analytical methods. In: Kimbrough RD ed. Halogenated biphenyls, terphenyls, naphthalenes, dibenzodioxins and related products. Amsterdam: Elsevier/North-Holland Biomedical Press, 41–76.
Rayn JJ, Patry B. 2001. Body burdens and food exposure in Canada for polybrominated diphenyl ethers (BDES). Organohalogen Compounds 51:226–229.
Rayne S, Ikonomou MG. 2002. Reconstructing source polybrominated diphenyl ether congener patterns from semipermeable membrane devices in the Fraser River, British Columbia, Canada: Comparison to commercial mixtures. Environ Toxicol Chem 21(11):2292–2300.12389906
Rayne S, Ikonomou MG, Antcliffe B. 2003a. Rapidly increasing polybrominated diphenyl ether concentrations in the Columbia River system from 1992 to 2000. Environ Sci Technol 37(13):2847–2854.12875385
Rayne S, Ikonomou MG, Whale MD. 2003b. Anaerobic microbial and photochemical degradation of 4,4’-dibromodiphenyl ether. Water Res 37:551–560.12688689
Reistad T, Mariussen E, Fonnum F. 2002. The effect of brominated flame retardants on cell death and free radical formation in cerebellar granule cells. Organohalogen Compounds 57:391–394.
*Render JA, Aust SD, Sleight SD. 1982. Acute pathologic effects of 3,3’,4,4’,5,5’-hexabromobiphenyl in rats: Comparison of its effects with Firemaster BP-6 and 2,2’,4,4’,5,5’-hexabromobiphenyl. Toxicol Appl Pharmacol 62:428–444.6280340
Renner R. 2000a. Increasing levels of flame retardants found in North American environment. Environ Sci Technol 34(21):452A–453A.
Renner R. 2000b. What fate for brominated fire retardants? Environ Sci Technol 34(9):222A–226A.
Renner R. 2001. Firesafe but not failsafe. Flame retardants cause neurotoxic effects. Environ Health Perspect 109(9):A434–435.
*Rezabek MS, Sleight SD, Jensen RK. 1987. Short-term oral administration of polybrominated biphenyls enhances the development of hepatic enzyme-altered foci in initiated rats. J Toxicol Environ Health 20:347–356.3031323
*Rezabek MS, Sleight SD, Jensen RK, . 1989. Effects of dietary retinyl acetate on the promotion of hepatic enzyme-altered foci by polybrominated biphenyls in initiated rats. Food Chem Toxicol 27(8):539–544.2551804
Rice CP, Chernyak SM, Begnoche L, . 2002. Comparisons of PBDE composition and concentration in fish collected from the Detroit River, MI and Des Plaines River, IL. Chemosphere 49(7):731–737.12431009
Rickenbacher U, McKinney JD, Oatley, SJ . 1986. Structurally specific binding of halogenated biphenyls to thyroxine transport protein. J Med Chem 29:641–648.3009810
*Rickert DE, Dent JG, Cagen SZ, . 1978. Distribution of polybrominated biphenyls after dietary exposure in pregnant and lactating rats and their offspring. Environ Health Perspect 23:63–66.210002
Riess M, Ernst T, Popp R, . 2000. Analysis of flame retarded polymers and recycling materials. Chemosphere 40(9–11):937–941.10739029
*Ringer RK, Aurelich RJ, Bleavins MR. 1981. Biological effects of PCBs and PBBs on mink and ferrets- a review. In: Khan MAQ, Stanton RD, eds. Toxicology of halogenated hydrocarbons: Health and ecological effects. New York: Pergamon Press, 329–343.
*Robertson LW, Andres JL, Safe SH, . 1983a. Toxicity of 3,3’,4,4’- and 2,2’,5,5’-tetrabromobiphenyl: Correlation of activity with aryl hydrocarbon hydroxylase induction and lack of protection by antioxidants. J Toxicol Environ Health 11:81–91.6298436
*Robertson LW, Chittim B, Safe SH, . 1983b. Photodecomposition of a commercial polybrominated biphenyl fire retardant: High-resolution gas chromatographic analysis. J Agric Food Chem 31:454–457.
Robertson LW, Parkinson A, Bandiera S, . 1981. Potent induction of rat liver microsomal, drug-metabolizing enzymes by 2,3,3’,4,4’,5-hexabromobiphenyl, a component of Firemaster. Chem Biol Interact 35:13–24.6258818
*Robertson LW, Parkinson A, Bandiera S, . 1984a. PCBs and PBBs: Biological and toxic effects on C57BL/6J and DBA/2J inbred mice. Toxicology 31:191–206.6330936
*Robertson LW, Parkinson A, Campbell MA, . 1982. Polybrominated biphenyls as aryl hydrocarbon hydroxylase inducers: Structure-activity correlations. Chem Biol Interact 42:53–66.6295646
*Robertson LW, Safe SH, Parkinson A, . 1984b. Synthesis and identification of highly toxic polybrominated biphenyls in the fire retardant Firemaster BP-6. J Agric Food Chem 32:1107–1111.
Robertson LW, Silberhorn EM, Glauert HP. 1991. Do structure-activity relationships for the acute toxicity of PCBs and PBBs also apply for induction of hepatocellular carcinoma? Environ Toxicol Chem 10:715–728.
*Roboz J, Greaves J, Bekesi JG. 1985. Polybrominated biphenyls in model and environmentally contaminated human blood: Protein binding and immunotoxicological studies. Environ Health Perspect 60:107–113.2992920
Roboz J, Suzuki RK, Bekesi JG, . 1980. Mass spectrometric identification and quantification of polybrominated biphenyls in blood compartments of exposed Michigan chemical workers. J Environ Pathol Toxicol 3:363–378.7441091
Rodriguez H, Loechler EL. 1993. Mutational specificity of the (+)-anti-diol epoxide of benzo[a]pyrene in a supF gene of an Escherichia coli plasmid: DNA sequence context influences hotspots, mutagenic specificity and the extent of SOS enhancements of mutagenesis. Carcinogenesis 14(3):373–383.8453713
*Roes U, Dent JG, Netter KJ, . 1977. Effect of polybrominated biphenyls on bromobenzene lethality in mice. J Toxicol Environ Health 3:663–671.201766
Rogan WJ. 1995. Environmental poisoning of children- lessons from the past. Environ Health Perspect 103:19–23.
Rogan WJ. 1996. Pollutants in breast milk. Arch Pediatr Adolesc Med 150:981–990.8790132
Rogan WJ, Weil WB. 2001. Duration of breast-feeding and PBBs. Environ Health Perspect 110(9):A503.
Ronen Z, Abeliovich A. 2000. Anaerobic-aerobic process for microbial degradation of tetrabromobisphenol A. Appl Environ Microbiol 66(6):2372–2377.10831413
*Rosen DH, Flanders WD, Friede A, . 1995. Half-life of a polybrominated biphenyl in human sera. Environ Health Perspect 103(3):272–274.7768229
Rosenkranz HS, Klopman G. 1990. Structural basis of carcinogenicity in rodents of genotoxicants and non-genotoxicants. Mutat Res 228:105–124.
*Rosenman KD, Anderson HA, Selikoff IJ, . 1979. Spermatogenesis in men exposed to polybrominated biphenyl (PBB). Fertil Steril 32:209–213.223887
*Rossman TG, Molina M, Meyer L, . 1991. Performance of 133 compounds in the lambda prophage induction endpoint of the Microscreen assay and a comparison with S. typhimurium mutagenicity and rodent carcinogenicity assays. Mutat Res 260:349–367.1831244
Rozman K, Pfeifer B, Kerecsen L, . 1991. Is a serotonergic mechanism involved in 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD)-induced appetite suppression in the Sprague-Dawley rat? Arch Toxicol 65:124–128.2059152
Rozman K, Rozman T, Scheufler E, . 1985. Thyroid hormones modulate the toxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD). J Toxicol Environ Health 16:481–491.4087313
*Rozman KK, Rozman TA, Williams J, . 1982. Effect of mineral oil and/or cholestyramine in the diet on biliary and intestinal elimination of 2,4,5,2’,4’,5’-hexabromodiphenyl in the Rhesus monkey. J Toxicol Environ Health 9:611–618.6286985
RTECS. 1987. Registry of toxic effects of chemical substances 3:1985-1986. Centers for Disease Control, National Institute for Occupational Safety and Health, 2401–2402.
*Ruzo LO, Zabik MJ. 1975. Polyhalogenated biphenyls: Photolysis of hexabromo and hexachlorobiphenyls in methanol solution. Bull Environ Contam Toxicol 13(2):181–182.804942
*Ruzo LO, Sundstrom G, Hutzinger O, . 1976. Photodegradation of polybrominated biphenyl (PBB). J Agric Food Chem 24:1062–1065.965593
*RTI. 1993. Research Triangle Institute. http://www.rti.org. May 5, 2002.
Ryan JJ, Patry B. 2000. Determination of brominated diphenyl ethers (BDE’s) and levels in Canadian human milks. Organohalogen Compounds 47:57–60.
Ryan JJ, Patry B. 2001a. Body burdens and exposure from food for polybrominated diphenyl ethers (BDEs) in Canada. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 103–106.
Ryan JJ, Patry B. 2001b. Body burdens and exposure from food for polybrominated diphenyl ethers (BDEs) in Canada. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 103–106.
Ryan JJ, Patry B, Mills P, . 2002. Recent trends in levels of brominated diphenyl ethers (BDES) in human milks from Canada. Organohalogen Compounds 58:173–176.
*Safe S. 1984. Polychlorinated biphenyls (PCBs) and polybrominated biphenyls (PBBs): Biochemistry, toxicology, and mechanism of action. CRC Crit Rev Toxicol 13:319–395.
Safe S. 1993. Toxicology structure- function relationship and human and environmental health impacts of polychlorinated biphenyls progress and problems. Environ Health Perspect 100(0):259–268.8354174
*Safe S. 1990. Polychlorinated biphenyls (PCBs), dibenzo-p-dioxins (PCDDs), dibenzofurans (PCDFs), and related compounds: Environmental and mechanistic considerations which support the development of toxic equivalency factors (TEFs). Crit Rev Toxicol 21(1):51–88.2124811
*Safe S, Bandiera S, Sawyer T, . 1985. Effects of structure on binding to the 2,3,7,8-TCDD receptor protein and AHH induction-halogenated biphenyls. Environ Health Perspect 61:21–33.2998747
*Safe S, Kohli J, Crawford A. 1978. FireMaster BP-6: Fractionation, metabolic and enzyme induction studies. Environ Health Perspect 23:147–152.209968
Safe SH. 2000. Toxicology of persistent organic pollutants. Eur J Lipid Sci Technol :52–53.
*Safe SH, Zacharewski T. 1997. Organochlorine exposure and risk for breast cancer. In: Aldaz CM, Gould MN, McLachlan J, ., eds. Etiology of breast and gynecological cancers. New York, NY: Wiley-Liss Inc., 133–145.
Sakai S-I. 2000. Thermal behavior of brominated flame retardants and PBDDs/DFs. Organohalogen Compounds 47:210–213.
Sakai S-I, Morita M. 2003. Polybrominated dibenzo-p-dioxins, dibenzofurans, and diphenyl ethers in Japanese human adipose tissue. Environ Sci Technol 37:817–812.12666907
Sakai S-I, Hayakawa K, Okamoto K, . 2002. Time trends and horizontal distribution of polybrominated diphenyl ethers (PBDEs) in sediment cores from Osaka Bay, Japan. Organohalogen Compounds 58:189–192.
Sakai S-I, Hirai Y, Tani H, . 2003. Time trends and fate analysis of polybrominated diphenyl ethers (PBDEs) in sediment cores. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
Sakai S-I, Honda Y, Takatsuki H, . 2001a. Polybrominated substances in waste electrical and electronic plastics and their behavior in the incineration plants. Organohalogen Compounds 52:35–38.
Saki S-I, Watanabe J, Honda Y, . 2001b. Combustion of brominated flame retardant and behavior of its byproducts. Chemosphere 42(5–7):519–531.11219676
Sakai S-I, Watanabe J, Takatsuki H, . 2001c. Presence of PBDDs/DFs in flame retardant materials and their behavior in high temperature melting processes. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 59–63.
Sanderson JT, Aarts JMMJG, Brouwer A, . 1996. Comparison of Ah receptor-mediated luciferase and ethoxyresorufin-O-deethylase induction in H4IIE cells: Implications for their use as bioanalytical tools for the detection of polyhalogenated aromatic hydrocarbons. Toxicol Appl Pharmacol 137:316–325.8661358
*Sandholm A, Emanuelsson BM, Klasson-Wehler E. 2003. Bioavailability and half-life of decabromodiphenyl ether (BDE-209) in rat. Xenobiotica 33(11):1149–1158.14660178
Santos FJ, Abalos M, Malavia J, . 2003. Ion trap MS/MS vs. HRMS for the analysis of PCDDs/Fs and dioxin-like PCBs in food samples. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
*Sasaki S. 1978. The scientific aspects of the chemical substances control law in Japan. In: Hutzinger O, VonLetyveld LH, Zoetman BC, eds. Aquatic pollutants: Transformation and biological effects: Oxford: Pergamon Press, 283–298.
Schaefer A. 2001. Lake Michigan heavily contaminated with PBDEs. Environ Sci Technol 35(7):139A–140A.
Schantz SL, Jacobson JL, Humphrey HEB, . 1994. Determinants of polychlorinated biphenyls (PCBs) in the sera of mothers and children from Michigan farms with PCB-contaminated soils. Arch Environ Health 49:452–458.7818287
Schecter A, Pavuk M, Papke O, . 2003a. Congener specific measurement of polybrominated diphenyl ethers in 47 individual milk samples from nursing mothers in the U.S.A. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
Schecter A, Pavuk M, Papke O, . 2003b. Polybrominated diphenyl ethers (PBDEs) in U.S. mother’s milk. Environ Health Perspect 111(14):1723–1729.14594622
Schmidt S, Fortnagel P, Wittich R-M. 1993. Biodegradation and transformation of 4,4’-dihalodiphenyl ethers by Sphingomonas sp. strain SS33. Appl Environ Microbiol 59(11):3931–3933.8285696
*Schnare DW, Ben M, Shields MG. 1984. Body burden reductions of PCBs, PBBs and chlorinated pesticides in human subjects. Ambio 13:378–380.
*Schramm H, Robertson LW, Oesch F. 1985. Differential regulation of hepatic glutathione transferase and glutathione peroxidase activities in the rat. Biochem Pharmacol 34(20):3735–3739.4052112
Schroter-Kermani C, Helm D, Hermann T, . 2000. The German environmental specimen bank-application in trend monitoring of polybrominated diphenyl ethers in human blood. Organohalogen Compounds 47:49–52.
Schussler GC. 2000. The thyroxine-binding proteins. Thyroid 10:141–149.10718550
*Schwartz EM, Rae WA. 1983. Effect of polybrominated biphenyls (PBB) on developmental abilities in young children. Am J Public Health 73(3):277–281.6297320
*Seagull EAW. 1983. Developmental abilities of children exposed to polybrominated biphenyls (PBB). Am J Public Health 73(3):281–285.6297321
Selden JR, Dolbeare F, Miller JE, . 1994. Validation of a flow cytometric in vitro DNA repair (UDS) assay in rat hepatocytes. Mutat Res 315(2):147–167.7520997
Sellström U, Jansson B. 1995. Analysis of tetrabromobisphenol A in a product and environmental samples. Chemosphere 31(4):3085–3092.
Sellström U, Jansson B, Kierkegaard A, . 1993. Polybrominated diphenyl ethers (PBDE) in biological samples from the Swedish environment. Chemosphere 26(9):1703–1718.
Sellström U, Kierkegaard M, Alsberg T, . 1999. Brominated flame retardants in sediments from European estuaries, the Baltic Sea and in sewage sludge. Organohalogen Compounds 40:383–386.
Sellström U, Kierkkegaard A, De Wit C, . 1998a. Polybrominated diphenyl ethers and hexabromocyclododecane in sediment and fish from a Swedish river. Environ Toxicol Chem 17(6):1065–1072.
Sellström U, Lindberg P, Haggberg L, . 2001. Higher brominated PBDEs found in eggs of peregrine falcons (Falco peregrinus) breeding in Sweden. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 159–162.
Sellström U, Soderstrom G, de Wit C, . 1998b. Photolytic debromination of decabromodiphennyl ether (DeBDE). Organohalogen Compounds 35:447–450.
*Sepkovic DW, Byrne JJ. 1984. Kinetic parameters of L-[125I]triiodothyronine degradation in rats pretreated with polyhalogenated biphenyls. Food Chem Toxicol 22(9):743–747.6092245
*Setchell BP, Waites GMH. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society, 143–172.
*Shah BP. 1978. Environmental considerations for the disposal of PBB-contaminated animals and wastes. Environ Health Perspect 23:27–35.209986
She J, Holden A, Tanner M, . 2003. High PBDE levels in piscivorous seabird eggs from the San Francisco Bay and Washington State. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
She J, Petreas M, Winkler J, . 2000a. Harbor seals as indicators of halogenated contaminants in San Francisco Bay. Organohalogen Compounds 49:422–425.
She J, Petreas M, Winkler J, . 2002. PBDEs in the San Francisco Bay area: Measurement in harbor seal blubber and human breast adipose tissue. Chemosphere 46(5):697–707.11999793
She J, Wrinkler J, Visita P, . 2000b. Analysis of PBDEs in seal blubber and human breast adipose tissue samples. Organohalogen Compounds 47:53–56.
Sheehan DM. 2003. Four different dose-response curve shapes for endocrine-disrupting chemicals - consequences for risk assessment. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
Shelby MD, Witt KL. 1995. Comparison of results from mouse bone marrow chromosome aberration and micronucleus tests. Environ Mol Mutagen 25(4):302–313.7607185
Shelby MD, Erexson GL, Hook GJ, . 1993. Evaluation of a three-exposure mouse bone marrow micronucleus protocol: Results with 49 chemicals. Environ Mol Mutagen 21(2):160–179.8444144
*Shelton DR, Tiedje JM. 1981. Development of tests for determining anaerobic biodegradation potential. Washington, DC. EPA 568581813. PB84166495.
Shepherd EC, Phillips TD, Irvin TR. 1984. Aflatoxin B1 metabolism in the rat: Polyhalogenated biphenyl enhanced conversion to aflatoxin M1. Xenobiotica 14(9):741–750.6097059
Sherman JD. 1991. Polybrominated biphenyl exposure and human cancer: Report of a case and public health implications. Toxicol Ind Health 7(3):197–205.1658987
Silberhorn EM, Glauert HP, Robertson LW. 1990. Carcinogenicity of polyhalogenated biphenyls: PCBs and PBBs. Crit Rev Toxicol 20(6):439–496.
*Silva J, Kauffman CA, Simon DG, . 1979. Lymphocyte function in humans exposed to polybrominated biphenyls. J Reticuloendothel Soc 26(4):341–347.229219
*Simmons MS, Kotz KT. 1982. Association studies of polybrominated biphenyls in aquatic systems. Bull Environ Contam Toxicol 29:58–63.6288149
Sinjari T, Damerud P, Hallgren S. 1998. Competitive inhibition of ^125^I-thyroxin (T4) binding to choroid plexus by hydroxylated PCB metabolites. Organohalogen Compounds 37:241–244.
Sinkkonen S, Lahtipera M, Vattulainen A, . 2003. Analysis of known and new types of polyhalogenated aromatic substances in oven ash from recycled aluminum production. Chemosphere 52(4):761–775.12738289
*Sjodin A, Carlsson H, Thuresson K, . 2001a. Flame retardants in indoor air at an electronics recycling plant and at other work environments. Environ Sci Technol 35(3):448–454.11351713
*Sjodin A, Hagmar L, Klasson-Wehler E, . 1999a. Flame retardant exposure: Polybrominated diphenyl ethers in blood from Swedish workers. Environ Health Perspect 107(8):643–648.10417362
*Sjodin A, Hagmar L, Klasson-Wehler E, . 2000. Influence of the consumption of fatty Baltic Sea fish on plasma levels of halogenated environmental contaminants in Latvian and Swedish men. Environ Health Perspect 108:1035–1041.11102293
*Sjodin A, Jakobsson E, Kierkegaard A, . 1998. Gas chromatographic identification and quantification of polybrominated diphenyl ethers in a commercial product, Bromkal 70-5DE. J Chromatogr A 822(1):83–89.
Sjodin A, Patterson DG Jr., Bergman A. 2001b. Brominated flame retardants in serum from U.S. blood donors. Environ Sci Technol 35(19):3830–3833.11642440
Sjodin A, Patterson DG, Bergman A. 2003. A review on human exposure to brominated flame retardants—particularly polybrominated diphenyl ethers. Environ Int 29:829–838.12850099
Sjodin A, Thuresson K, Hagmar L, . 1999b. Occupational exposure to polybrominated diphenyl ethers at dismantling of electrons. Ambient air and human serum analysis. Organohalogen Compounds 43:447–451.
*Sleight S. 1985. Effects of PCBs and related compounds on hepatocarcinogenesis in rats and mice. Environ Health Perspect 60:35–39.2992924
*Sleight SD, Sanger VL. 1976. Pathologic features of polybrominated biphenyl toxicosis in the rat and guinea pig. J Am Vet Med Assoc 169:1231–1235.187567
*Sleight SD, Mangkoewidjojo S, Akoso BT, . 1978. Polybrominated biphenyl toxicosis in rats fed an iodine-deficient, iodine-adequate, or iodine-excess diet. Environ Health Perspect 23:341–346.209997
Smeds A, Saukko P. 2003. Brominated flame retardants and phenolic endocrine disrupters in Finnish human adipose tissue. Chemosphere 53:1123–1130.14512116
Smolnikar K, Dehnhardt M, Wiegand H. 2001. Perturbation by PBDE99 of calcium homeostasis after in vitro treatment. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 273.
Soderstrom G, Marklund S. 2002. PBCDD and PBCDF from incineration of waste-containing brominated flame retardants. Environ Sci Technol 36:1959–1964.12026978
Soderström G, Sellström U, De Wit CA, . 2004. Photolytic debromination of decabromodiphenyl ether (BDE 209). Environ Sci Technol 38:127–132.14740727
Solomon GM, Huddle AM. 2002. Low levels of persistent organic pollutants raise concerns for future generations. J Epidemiol Commun Health 56:826–827.
Sonzogni W, Manchester-Neesvig J. 2001. Polybrominated diphenyl ethers (PBDEs) in the Lake Michigan salmonids. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 377–378.
*Sparling J, Fung D, Safe S. 1980. Bromo and chlorobiphenyl metabolism: Gas chromatographic mass spectrometric identification of urinary metabolites and the effects of structure on their rates of excretion. Biomed Mass Spectrom 7(1):13–19.6249410
Spear PA, Higueret P, Garcin H. 1994. Effects of fasting and 3,3,4.4’-5,5’-hexabromobiphenyl on plasma transport of thyroxine and retinol: Fasting reverses elevation of retinol. J Toxicol Environ Health 42(2):173–183.8207753
*SRI. 2001. 2001 Directory of chemical producers- United States of America. Menlo Park, CA: Stanford Research Institution International, 462.
SRI. 2002. 2002 Directory of chemical producers- United States of America. Menlo Park, CA: Stanford Research Institution International.
Stafford, CJ. 1983. Halogenated diphenyl ethers identified in avian tissues and eggs by GC/MS. Chemosphere 12(11/12):1487–1495.
Stanley JS, Cramer PH, Thornburg KR, . 1991. Mass spectral confirmation of chlorinated and brominated diphenyl ethers in human adipose tissues. Chemosphere 23(8–10):1185–1186.
Stapleton HM, Baker JE. 2003. Comparing polybrominated diphenyl ether and polychlorinated biphenyl bioaccumulation in a food web in Grand Bay, Lake Michigan. Arch Environ Contam Toxicol 45(2):227–234.14565581
Stapleton HM, Alaee M, Letcher RJ, . 2003. Debromination of decabromodiphenyl ether by juvenile carp (Cyprinus carpio). Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
Stern GA, Ikonomou MG. 2000. Temporal trends of polybrominated diphenyl ethers in SE baffin beluga: Increasing evidence of long range atmospheric transport. Organohalogen Compounds 57:81–84.
Stoker TE, Ferrell J, Hedge JM, . 2003. Assessment of SE-71, a commercial polybrominated diphenyl ether (PBDE) mixture, in the EDSP male pubertal protocol. Toxicologist 72(S-1):135–136.
Strandberg B, Dodder NG, Basu I, . 2001. Concentrations and spatial variations of polybrominated diphenyl ethers and other organohalogen compounds in Great Lakes air. Environ Sci Technol 35(6):1078–1083.11347917
Strandman T, Kiviranta H, Kumpulainen J, . 2001. Polybrominated diphenyl ethers (PBDEs) in Finnish food items. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 307–310.
Strandman T, Koistinen J, Kiviranta H, . 1999. Levels of some polybrominated diphenyl ethers (PBDEs) in fish and human adipose tissue in Finland. Organohalogen Compounds 40(:):355–358.
Strandman T, Koistinen J, Variainen T. 2000. Polybrominated diphenyl ethers (PBDEs) in placenta and human milk. Organohalogen Compounds 47:61–64.
Strassner HT, Arnolds CW. 1992. Environment and pregnancy. Princ Pract Med Ther Preg 10:89–105.
Striebich RC, Rubey WA, Tirey DA, . 1991. High-temperature degradation of polybrominated flame retardant materials. Chemosphere 23(8–10):1197–1204.
*Stross JK, Nixon RK, Anderson MD. 1979. Neuropsychiatric findings in patients exposed to polybrominated biphenyls. Ann N Y Acad Sci 320:368–372.222191
*Stross JK, Smokler IA, Isbister J, . 1981. The human health effects of exposure to polybrominated biphenyls. Toxicol Appl Pharmacol 58:145–150.6262949
*Sugiura K. 1992. Microbial degradation of polychlorinated biphenyls in aquatic environments. Chemosphere 24:881–890.
Sun G, Yau A, Farias T. 2003. Analytical methods for trace levels of polybrominated diphenyl ethers (PBDEs). Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
*Sundstrom G, Hutzinger O, Safe S, . 1976a. Identification of 2,2’4,4’5,5’-hexabromobiphenyl as the major component of flame retardant Firemaster^®^ PB-6. Chemosphere 5:11–14.
*Sundstrom G, Hutzinger O, Safe S, . 1976b. The synthesis and gas chromatographic properties of bromobiphenyls. Sci Total Environ 6:15–29.
Swann RL, Laskowski DA, McCall PJ, . 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air, and water solubility. Res Rev 85:18–28.
Swanson MB, Davis GA, Kincaid LE, . 1997. A screening method for ranking and scoring chemicals by potential human health and environmental impacts. Environ Toxicol Chem 16(2):372–383.
Sweeney AM, Symanski E, Burau KD, . 2001. Changes in serum PBB and PCB levels over time among women of varying ages at exposure. Environ Res 86:128–139.11437459
*Takase I, Omori T, Minoda Y. 1986. Microbial degradation products from biphenyl-related compounds. Agric Biol Chem 50(3):681–686.
Takasuga T, Tsuji H, Nagayama J. 2002. Gender specific dynamics of PCDD/DFs, PCBs, PBDEs and organochlorines in blood of Japanese families over two-year study period. Organohalogen Compounds 58:297–300.
*Takenaka S, Takahashi K. 1991. Enhancement of fecal excretion of polychlorinated biphenyls by the addition of rice bran fiber to the diet in rats. Chemosphere 22(3–4):375–381.
Talsness CE, Shakibaei M, Kuriyama S, . 2003. Ultrastructural changes in the ovaries of adult offspring following a single maternal exposure to low dose 2,2’4,4’,5-pentabromodiphenyl ether. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
Taylor MJ, Lucier GW, Mahler JF, . 1992. Inhibition of acute TCDD toxicity by treatment with anti-tumor necrosis factor antibody or dexamethasone. Toxicol Appl Pharmacol 117:126–132.1440607
Taylor MM, Hedge JM, DeVitro MJ, . 2002. Perinatal exposure to a polybrominated diphenyl ether mixture (DE-71) disrupts thyroid hormones but not neurobehavioral development. Toxicol Sci, 133.
Taylor MM, Hedge JM, Gilbert ME, . 2003. Perinatal exposure to polybrominated diphenyl ether mixture (DE-71): Disruption of thyroid homeostasis and neurobehavioral development. Toxicol Sci 72(S-1):124.
Tennant RW. 1993. A perspective on nonmutagenic mechanisms in carcinogenesis. Environ Health Perspect Suppl 101:231–236.
ter Schure AFH, Larsson P. 2001. Atmospheric deposition of polybrominated diphenylethers (PBDEs). BFR:375–376.
ter Schure AFH, Larsson P. 2002. Polybrominated diphenyl ethers in precipitation in Southern Sweden (Skan, Lund). Atmos Environ 36:4015–4022.
ter Schure AFH, Larsson P, Merila J, . 2002. Latitudinal fractionation of polybrominated diphenyl ethers and polychlorinated biphenyls in frogs (Rana temporaria). Environ Sci Technol 36:5057–5061.12523420
Theiss JC, Stoner GD, Shimkin MB, . 1977. Test for carcinogenicity of organic contaminants of United States drinking waters by pulmonary tumor response in strain A mice. Cancer Res 37(8):2717–2720.872098
*Thoma H, Hutzinger O. 1987. Pyrolysis and GC/MS-analysis of brominated flame retardants in on-line operation. Chemosphere 16(6):1353–1360.
*Thoma H, Hauschulz G, Knorr E, . 1987. Polybrominated dibenzofurans (PBDF) and dibenzodioxins (PBDD) from the pyrolysis of neat brominated diphenylethers, biphenyls and plastic mixtures of these compounds. Chemosphere 16(1):277–285.
*Thomas AR, Marcus M, Zhang RH, . 2001. Breast-feeding among women exposed to polybrominated biphenyls in Michigan. Environ Health Perspect 109(11):1133–1137.11712998
Thomas GO, Moss SEW, Jones KC, . 2003. Absorption of PBDEs and PCBs by grey seals (Halichoerus gypus). Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
*Thomas RG. 1990. Volatilization from water. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods: Environmental behavior of organic compounds. Washington, DC: American Chemical Society.
Thomsen C, Froshaug M, Leknes H, . 2003. Brominated flame retardants in breast milk from Norway. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
Thomsen C, Haug LS, Leknes H, . 2002a. Comparing electron ionization high-resolution and electron capture low-resolution mass spectrometric determination of polybrominated diphenyl ethers in plasma, serum and milk. Chemosphere 46(5):641–648.11999787
Thomsen C, Leknes H, Lundanes E, . 2001a. Brominated flame retardants in laboratory air. J Chromatogr A 923(1–2):299–304.11510556
Thomsen C, Lundanes E, Becher G. 2001b. Brominated flame retardants in plasma samples from three different occupational groups in Norway. J Environ Monit 3(4):366–370.11523435
Thomsen C, Lundanes E, Becher G. 2001c. Plasma concentration of brominated flame retardants in three Norwegian occupational groups. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 311–314.
Thomsen C, Lundanes E, Becher G. 2001d. A simplified method for determination of tetrabromobisphenol A and polybrominated diphenyl ethers in human plasma and serum. J Sep Sci 24:282–290.
Thomsen C, Lundanes E, Becher G. 2001e. A time related study on brominated flame retardants in serum samples from the general population in Norway. Organohalogen Compounds 52:206–209.
Thomsen C, Lundanes E, Becher G. 2002b. Brominated flame retardants in archived serum samples from Norway: A study on temporal trends and the role of age. Environ Sci Technol 36:1414–1418.11999045
Thuresson K, Jakobsson K, Hagmar L, . 2002a. Decabromodiphenyl ether exposure to workers manufacturing rubber and in an industrial setting producing rubber coated electric wires. Organohalogen Compounds 58:165–168.
Thuresson K, Jakobsson K, Hagmar L, . 2002b. Work related exposure to brominated flame retardants when recycling metals from printed circuit boards. Organohalogen Compounds 58:249–252.
*Tilson HA. 1992. Study design considerations in developmental neurotoxicology. Neurotoxicol Teratol 14:199–203.1321946
*Tilson HA, Cabe PA. 1979. Studies on the neurobehavioral effects of polybrominated biphenyls in rats. Ann N Y Acad Sci 31:325–336.
Tittlemier SA, Tomy GT. 2000. Vapor pressure of six brominated diphenyl ether congeners. Organohalogen Compounds 47:206–209.
Tittlemier SA, Tomy GT. 2001. Vapor pressures of six brominated diphenyl ether congeners. Environ Toxicol Chem 20(1):146–148.11351402
*Tittlemier SA, Halldorson T, Stern GA, . 2002. Vapor pressures, aqueous solubilities, and Henry’s Law constants of some brominated flame retardants. Environ Toxicol Chem 21(9):1804–1810.12206419
Tollback P, Bjorklund J, Ostman C. 2003. Evaluation of gas chromatographic injection techniques for PBDE. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
Tomy GT, Palace VP, Halldorson T, . 2004. Bioaccumulation, biotransformation, and biochemical effects of brominated diphenyl ethers in juvenile lake trout (Salvelinus namaycush). Environ Sci Technol 38:1496–1504.15046352
Tomy G, Tittlemier S, Braekevelt E, . 2001. The physio-chemical properties of some brominated flame retardants. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 229–232.
TRI 01. 2004. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
Tritscher A, Stadler R, Scanlan F, . 2003. Determination of polybrominated diphenylethers in samples of raw cow’s milk, fish and egg. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
*Trotter WJ. 1977. Confirming low levels of hexabromobiphenyl by gas-liquid chromatography of photolysis products. Bull Environ Contam Toxicol 18:726–733.202355
Tsongas TA. 1996. PBBs: Potential effects in children. Environ Health Perspect 104(12):1267–1268.9118862
*Tuey DB, Matthews HB. 1980. Distribution and excretion of 2,2’,4,4’,5,5’-hexabromobiphenyl in rats and man: Pharmacokinetic model predictions. Toxicol Appl Pharmacol 53:420–431.6247786
Tullo A. 2003. Great Lakes to phase out two flame retardants. Chemical & Engineering News 81(45):13. http://www.pubs.acs.org/cen/topstory/8145/print/8145notw3.html.
Tysklind M, Sellstrom U, Soderstrom G, . 2001. Abiotic transformation of polybrominated diphenylethers (PBDEs): Photolytic debromination of decabromo diphenyl ether. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 51–54.
Ueno D, Kajiwara N, Tanaka H, . 2003. Global pollution monitoring of polybrominated diphenyl ethers (PBDEs) using skipjack tuna as a bioindicator. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
Ueno D, Kajiwara N, Tanaka H, . 2004. Global pollution monitoring of polybrominated diphenyl ethers using skipjack tuna as a bioindicator. Environ Sci Technol 38:2312–2316.15116835
Uno Y, Takaswas H, Miyagawa M, . 1994. An in vivo-in vitro replications DNA synthesis (RDS) test using rat hepatocytes as an early prediction assay for nongenotoxic hepatocarcinogens: Screening of 22 known positives and 25 noncarcinogens. Mutat Res 320(3):189–205.7508085
USDA. 1998. United States Department of Agriculture. http://www.usda.gov/OPHS/bluebook/histcom.htm.
*Valciukas JA, Lilis R, Anderson HA, . 1979. The neurotoxicity of polybrominated biphenyls: Results of a medical field survey. Ann N Y Acad Sci 320:337–367.222190
*Valciukas JA, Lilis R, Wolff MS, . 1978. Comparative neurobehavioral study of a polybrominated biphenyl-exposed population in Michigan and a nonexposed group in Wisconsin. Environ Health Perspect 23:199–210.209977
van Bavel B, Dam M, Tysklind M, . 2001. Levels of polybrominated diphenyl ethers in marine mammals. Organohalogen Compounds 52:99–103.
van Bavel B, Hardell L, Kitti A, . 2002. High levels of PBDEs in 5% of 220 blood samples from the Swedish population. Organohalogen Compounds 58:161–164.
van Bavel B, Sundelin E, Lillback J, . 1999. Supercritical fluid extraction of polybrominated diphenyl ethers PBDEs from long-finned pilot whale (Globicephala melas) from the Atlantic. Organohalogen Compounds 40:359–362.
van Birgelen APJM. 1999. Uncertainties in the toxic equivalency factor concept: Future directions. Organohalogen Compounds 44:505–508.
Van-Den-Berg KJ, van Raaij JAGM, Bragt PC, . 1991. Interactions of halogenated industrial chemicals with transthyretin and effects on thyroid hormone levels in vivo. Arch Toxicol 65:15–19.2043046
van den Hove MF, Beckers C, Devlieger H, . 1999. Hormone synthesis and storage in the thyroid of human preterm and term newborns: Effect of thyroxine treatment. Biochimie 81:563–570.10403191
Van Vliet G. 1999. Merck AG thyroid symposium. Neonatal hypothyroidism: Treatment and outcome. Thyroid 9:79–84.10037081
*Veith GD, DeFoe VD, Bergstedt BV. 1979. Measuring and estimating the bioconcentration factor of chemicals in fish. J Fish Res Board Can 36:1040–1048.
Vetter W. 2001. Pattern of brominated compounds in top predations of marine food webs from four continents. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 379–383.
Vetter W, Muller JF, Gaus C, . 2001. Bioaccumulative natural brominated compounds in marine mammals. Stockholm, Sweden. BFR, 385–389.
Viberg H, Fredriksson A, Eriksson P. 2002a. Developmental exposure to a brominated flame-retardant, 2,2’,4,4’,5,5’-Hexabromodiphenyl ether (PBDE 153) affects behaviour and cholinergic nicorinic receptors in brain of adult mice. Toxicol Sci (suppl)66:132.
Viberg H, Fredriksson A, Eriksson P. 2002b. Neonatal exposure to the brominated flame retardant 2,2’,4,4’,4-pentabromodiphenyl ether causes altered susceptibility if the cholinergic transmitter system in the adult mouse. Toxicol Sci 67:104–107.11961222
Viberg H, Fredrickson A, Eriksson P. 2003a. Neonatal PBDE 99 exposure causes dose-response related behavioural derangements that are not sex or strain specific in mice. Toxicol Sci 72(S-1):126.
Viberg H, Fredriksson A, Eriksson P. 2003b. Neurotoxicity of different polybrominated diphenyl ethers, including PBDE 209. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
Viberg H, Fredriksson A, Jakobsson E, . 2001a. Neonatal exposure to hexabromo-diphenyl ether (PBDE 153) affects behaviour and cholinergic nicotinic receptors in brain of adult mouse. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 275–278.
Viberg H, Fredricksson A, Jakobsson E, . 2001b. Brominated flame retardant: Uptake, retention and developmental neurotoxic effects of decabromodiphenyl ether (PBDE 209) in the neonatal mouse. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 279–282.
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
Villeneuve DL, Kannan K, Priest BT, . 2002. In vitro assessment of potential mechanism-specific effects of polybrominated diphenyl ethers. Environ Toxicol Chem 21(11):2431–2433.12389923
Vives I, Grimalt JO, Lacorte S, . 2004. Polybromodiphenyl ether flame retardants in fish from lakes in European high mountains and Greenland. Environ Sci Technol 38:2338–2344.15116838
von Meyerinck L, Hufnagel B, Schmoldt A, . 1990. Inductions of rat liver microsomal cytochrome P-450 by the pentabromo diphenyl ether bromkal 70 and half-lives of its components in the adipose tissue. Toxicology 61(2):259–274.2330598
Voorspoels S, Covaci A, Schepens P. 2003. Polybrominated diphenyl ethers (PBDEs) in marine fish species of the Belgian North Sea and the Western Scheldt Estuary: Levels, profiles, and distribution. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
*Vos JG, van Genderen H. 1973. Toxicological aspects of immunosuppression. Pesticide and environmental control symposium specialists. Miami, Florida, 527–545.
Vulsma T, Gons MH, DeVijder JJM. 1989. Maternal-fetal transfer of thyroxine in congenital hypothyroidism due to a total organification defect or thyroid agenesis. N Eng J Med 321:13–16.
Wania F, Dugani C. 2002. Assessing the long range transport potential of polybrominated diphenyl ethers: A comparison of four multimedia models. Final report. University of Toronto at Scarborough, Scarborough, Ontario.
*Waritz RS, Aftosmis JG, Culik R, . 1977. Toxicological evaluations of some brominated biphenyls. Am Ind Hyg Assoc J 38:307–320.197845
*Wasito, Sleight SD. 1989. Promoting effect of polybrominated biphenyls on tracheal papillomas in Syrian golden hamsters. J Toxicol Environ Health 27:173–187.2543833
Watanabe I. 1988. Behaviour of organobrominated compounds at the sediment phase in the environment. Koshu Eisei Hen 26:129–133.
Watanabe I, Sakai S-I. 2001. Environmental release and behavior of brominated flame retardants- an overview. Organohalogen Compounds 52:1–4.
Watanabe I, Sakai S-I. 2003. Environmental release and behavior of brominated flame retardants. Environ Int 29:665–682.12850086
Watanabe I, Tatsukawa R. 1987. Formation of brominated dibenzofurans from the photolysis of flame retardant decabromobiphenyl ether in hexane by UV and sun light. Bull Environ Contam Toxicol 39:953–959.3440151
Watanabe I, Tatsukawa R. 1990. Anthropogenic aromatics in the Japanese environment. Workshop on brominated aromatic flame retardants, Skokloster, Sweden. KEMI, National Council Inspectorate, Solna, Sweden, 1990, 63–71.
Watanabe I, Kashimoto T, Tatsukawa R. 1986. Confirmation of the presence of the flame retardant decabromiphenyl ether in river sediment from Osaka, Japan. Bull Environ Contam Toxicol 36(6):839–842.3719120
Watanabe I, Kashimoto T, Tatsukawa R. 1987. Polybrominated biphenyl ethers in marine fish, shellfish and river and marine sediments in Japan. Chemosphere 16(10–12):2389–2396.
Watanabe I, Kawano M, Tatsukawa R. 1995. Polybrominated and mixed polybromo/chlorinated dibenzo-p-dioxins and -dibenzofurans in the Japanese environment. Organohalogen Compounds 24:337–240.
Watanabe IAH, Kawano MC, Wang YD, . 1992. Polybrominated dibenzo-p-dioxins (PBDDs) and dibenzofurans (PBDFs) in atmospheric air in Taiwan and Japan. Organohalogen Compounds 9:309–312.
Weber LW, Greim H. 1997. The toxicity of brominated and mixed-halogenated dibenzo-p-dioxins and dibenzofurans: An overview. J Toxicol Environ Health 50(3):195–215.9055873
Weber LWD, Lebofsky M, Greim H, . 1991a. Key enzymes of gluconeogenesis are dose-dependent reduced in 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD)-treated rats. Arch Toxicol 65:119–123.2059151
Weber LWD, Lebofsky M, Stahl BU. 1991b. Reduced activities of key enzymes of gluconeogenesis as possible cause of acute toxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in rats. Toxicology 66:133–144.1849669
*Weil WB, Spencer M, Benjamin D, . 1981. The effect of polybrominated biphenyl on infants and young children. J Pediatr 98:47–51.6256513
Welch LW. 1998. Reproductive and developmental hazards - an overview for occupational and environmental health nurses. AAOHN J 46(2):57–65.9526274
+Welsch F, Morgan KT. 1985. Placental transfer and developmental toxicity of 2,2’,4,4’,5,5’-hexabromobiphenyl in B6C3F1 mice. Toxicol Appl Pharmacol 81:431–442.3001974
Wenning RJ. 2001a. Probabilistic human health risk assessment of penta-, octa-, and deca- brominated dphenyl ethers. Organohalogen Compounds 52:39–42.
Wenning RJ. 2001b. Risk assessment of three commercial PBDEs: Probabilistic analysis of chronic daily intakes from different sources and comparison with European commission results. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 397–399.
Wenning RJ. 2002. Uncertainties and data needs in risk assessment of three commercial polybrominated diphenyl ethers: Probabilistic exposure analysis and comparison with European commission results. Chemosphere 46(5):779–796.11999800
Wenning RJ, Von Burg A, Braithwaite S, . 2003. Health risk assessment of the commercial pentabromodiphenyl ether product in the United States. Organohalogen compounds. Dioxins 2003. Boston, MA, 60–65.
*Werner PR, Sleight SD. 1981. Toxicosis in sows and their pigs caused by feeding rations containing polybrominated biphenyls to sows during pregnancy and lactation. Am J Vet Res 42:183–189.6266287
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
*Wester RC, Maibach HI, Bucks DA, . 1990. Percutaneous absorption and skin decontamination of PCBs: In vitro studies with human skin and in vivo studies in the Rhesus monkey. J Toxicol Environ Health 31:235–246.2254950
*WHO. 1994a. Brominated diphenyl ethers. International Programme on Chemical Safety. Environmental Health Criteria. World Health Organization. http://www.inchem.org/documents/ehc/ehc.
*WHO. 1994b. Brominated diphenyl ethers. International programme on chemical safety. Environmental Health Criteria 162. World Health Organization. http://www.inchem.org/documents/ehc/ehc/.
WHO. 1998. Brominated diphenyl ethers. International programme on chemical safety. Environmental Health Criteria. World Health Organization. http://www.inchem.org/documents/ehc/ehc/ehc205.htm.
*Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York: Academic Press.
Wiegand H, Desaiah D, Dehnhardt M, . 2001. Polyhalogenated hydrocarbon induced perturbation of intracellular calcium homeostasis: From astrocytes to human macrophages. Organohalogen Compounds 53:182–184.
Wijesekera R, Halliwell C, Hunter S, . 2002. A preliminary assessment of UK human exposure to polybrominated diphenyl ethers (PBDEs). Organohalogen Compounds 55:239–242.
WIL Research Laboratories. 1986. A range-finding teratology study in rats with DE-79. Submitted to U.S. Environmental Protection Agency under TSCA Section 8D. OTS0522298.
Wilford BH, Thomas GO, Alcock RE, . 2003. Polyurethane foam as a source of PBDEs to the environment. Organohalogen compounds. Dioxins 2003. Stockholm, Sweden, 60–65.
*Willett LB, Durst KI. 1978. Effects of PBBs on cattle. IV. Distribution and clearance of components of FireMaster BP-6. Environ Health Perspect 23:67–74.210003
Willett LB, Irving HA. 1976. Distribution and clearance of polybrominated biphenyls in cows and calves. J Dairy Sci 59(8):1429–1439.956481
Willett LB, Brumm CJ, Williams CL. 1978. Method for extraction, isolation, and detection of free polybrominated biphenyls (PBBs) from plasma, feces, milk, and bile using disposable glassware. J Agric Food Chem 26(1):122–126.202619
Willett LB, Durst HI, Liu T-TY, . 1982. Performance and health of offspring of cows experimentally exposed to polybrominated biphenyls. J Dairy Sci 65:81–91.6281322
*Willett LB, Schanbacher FL, Durst HI, . 1988. Relationships between concentrations of polybrominated biphenyls detected in milk, blood and body fat of contaminated dairy cattle. In: Proceedings of the 75^th^ American Dairy Science Association Annual Meeting, Blacksburg, VA, June 15-18, 1980. [Abstract P134]. J Dairy Sci 63 (Suppl. 1):144.
*Williams DT, LeBel GL, Junkins E. 1988. Organohalogen residues in human adipose autopsy samples from six Ontario municipalities. J Assoc Off Anal Chem 71(2):410–414.3384793
*Williams GM, Tong C, Telang S. 1984. Polybrominated biphenyls are nongenotoxic and produce an epigenetic membrane effect in cultured liver cells. Environ Res 34:310–320.6086306
*Wilson-Martino NA, Martino LJ, Millman-Feder NG, . 1980. The presence of hepatic intramitochondrial crystalline inclusions in polybrominated biphenyl-treated mice. Arch Toxicol 45:233–239.6257209
*Wolff MS, Aubrey B. 1978. PBB homologs in sera of Michigan dairy farmers and Michigan chemical workers. Environ Health Perspect 23:211–215.209978
Wolff MS, Selikoff IJ. 1979. Variation of polybrominated biphenyl homolog peaks in blood of rats following treatment with Firemaster FF-1. Bull Environ Contam Toxicol 21:771–774.223694
*Wolff MS, Toniolo, PG. 1995. Environmental organochlorine exposure as a potential etiologic factor in breast cancer. Environ Health Perspect 103(7):141–145.8593861
*Wolff MS, Anderson HA, Camper F, . 1979a. Analysis of adipose tissue and serum from PBB (polybrominated biphenyl)-exposed workers. J Environ Pathol Toxicol 2:1397–1411.231083
*Wolff MS, Anderson HA, Rosenman KD, . 1979b. Equilibrium of polybrominated biphenyl (PBB) residues in serum and fat of Michigan residents. Bull Environ Contam Toxicol 21:775–781.223695
Wolff MS, Anderson HA, Selikoff IJ. 1982. Human tissue burdens of halogenated aromatic chemicals in Michigan. JAMA 247(15):2112–2116.6278170
Wolkers H, Van Bavel B, Derocher AE, . 2004. Congener-specific accumulation and food chain transfer of polybrominated diphenyl ethers in two Arctic food chains. Environ Sci Technol 38:1667–1674.15074673
Wong A, Duan Lei Y, Alaee M, . 2001. Vapor pressure of the polybrominated diphenylethers. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 195–198.
*Yagi O, Sudo R. 1980. Degradation of polychlorinated biphenyls by microorganisms. J Water Pollut Control Fed 52:1035–1043.
*Yamamoto H, Okumura T, Nishkawa Y, . 1997. Determination of decabromodiphenyl ether in water and sediment samples by gas chromatography with electron capture detection. J AOAC Int 80(1):102–106.9011064
*Zabik ME, Johnson TM, Smith S. 1978. Effects of processing and cooking on PBB residues. Environ Health Perspect 23:37–41.210000
*Zacharewski T, Harris M, Safe S, . 1988. Applications of the in vitro aryl hydrocarbon hydroxylates induction assay for determining “2,3,7,8-tetrachlorodibenzo-p-dioxin equivalents”: Pyrolyzed brominated flame retardants. Toxicology 51:177–189.2845603
Zegers BN, Lewis WE, Boon JP. 2000. Levels of some polybrominated diphenyl ether (PBDE) flame retardants in dated sediment cores. Organohalogen Compounds 47:229–232.
Zegers BN, Lewis WE, Tjoen-A-Choy MR, . 2001a. Levels of some polybrominated diphenyl ether (PBDE) flame-retardants in animals of different trophic levels of the North Sea food web. Organohalogen Compounds 52:18–21.
Zegers BN, Lewis WE, Tjoen-A-Choy MR, . 2001b. Levels of some polybrominated diphenyl ether (PBDE) flame retardants in animals of different trophic levels of the North Sea food web. The second international workshop on brominated flame retardants. BFR 2001. Stockholm, Sweden, 143–147.
Zeiger E. 1987. Carcinogenicity of mutagens predictive capability of the Salmonella mutagenesis assay for rodent carcinogenicity. Cancer Res 47:1287–1296.3815340
Zeiger E. 1990. Mutagenicity of 42 chemicals in Salmonella. Environ Mol Mutagen 16:32–54.
Zeiger E, Anderson B, Haworth S, . 1987. Salmonella mutagenicity tests: III. Results from the testing of 255 chemicals. Environ Mutagen 9:1–110.
Zelinski V, Lorenz W, Bahadir M. 1993. Brominated flame retardants and resulting PBDD in accidental fire residues from private residences. Chemosphere 27(8):1519–1528.
Zennegg M, Kohker M, Gerecke AC, . 2003. Polybrominated diphenyl ethers in whitefish from Swiss lakes and farmed rainbow trout. Chemosphere 51(7):545–553.12615108
Zhou T, Ross DG, De Vito MJ, . 2001. Effects of short-term in vivo exposure to polybrominated diphenyl ethers on thyroid hormones and hepatic enzyme activities in weaning rats. Toxicol Sci 61:76–82.11294977
Zhou T, Taylor MM, De Vito MJ, . 2000. Thyroid hormone disruptive effects of brominated diphenyl ethers following developmental exposure. Toxicologist 54(1):260–261.
Zhou T, Taylor MM, DeVito MJ, . 2002. Developmental exposure to brominated diphenyl ethers results in thyroid hormone disruption. Toxicol Sci 66:105–116.11861977
Zhu LY, Hites RA. 2004. Temporal trends and spatial distribution of brominated flame retardants in archived fishes from the Great Lakes. Environ Sci Technol 38:2779–2784.15212250
*Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
Zier B, Lenoir D, Lahaniatis ES, . 1991. Surface catalyzed halogenation-dehalogenation reactions of aromatic bromine compounds adsorbed on fly ash. Chemosphere 22(12):1121–1129.
Zitko V. 1977. The accumulation of polybrominated biphenyls in fish. Bull Environ Contam Toxicol 17(3):285–292.192397
*Zitko V. 1979. The fate of highly brominated aromatic hydrocarbons in fish. ACS Symp Ser 99:177–182.
Zitko V. 1999. Qualitative determination of 10,10’-oxybisphenoxarsine and decabromodiphenyl ether in plastics. Chemosphere 38(3):629–632.10901679
*Zitko V, Hutzinger O. 1976. Uptake of chloro- and bromobiphenyls, hexachloro- and hexabromobenzene by fish. Bull Environ Contam Toxicol 16(6):665–673.189865
Zober MA, Ott MG. 1997. Digestive tract neoplasma among employees with past exposure to brominated dioxins. Occup Environ Med 54(1):66.
Zober MA, Ott MG, Paepke O, . 1992. Morbidity study of extruder personnel with potential exposure to brominated dioxins and furans: I: Results of blood monitoring and immunological tests. Br J Ind Med 49(8):532–544.1515345
*Zoeller RT, Crofton RM. 2000. Thyroid hormone action in fetal brain development and potential for distribution by environmental chemicals. Neurotoxicology 21(6):935–946.11233763
Zweidinger R, Cooper SD, Erickson MD, . 1979. Sampling and analysis for semivolatile brominated organics in ambient air. Am Chem Soc Abstr Pap 94:217–231.